# Appendix D Quality Assessment Tables

Appendix D Table 1 Quality Ratings of Studies Assessing the Accuracy of Serologic Screening Tests for HSV-2 (Key Question 2)

First Author, Year | Was the cutpoint used to determine test positivity adequately described (or referenced)? | Were population selection criteria clearly described? | Did the whole or a random selection of the participants receive the Western blot? | Did all participants receive the Western blot regardless of serologic screening test results? | Were the serologic test results and Western blot results interpreted independently?
Lingappa, 2010^73^ | Yes | Yes | Yes | Yes | Yes
Mark, 2007^65^ | Yes | Yes | Yes | Yes | NR/CND
Ng’ayo, 2010^74^ | Yes | Yes | Yes | Yes | NR/CND
Delany-Moretlwe, 2009^75^ | Yes | Yes | Yes (random selection) | Yes | NR/CND
Summerton, 2007^95^ | Yes | NR/CND | See comments | No | NR/CND
Ashley-Morrow, 2004^66^ | Yes | Yes | NR/CND | Yes | Yes
Mujugira, 2011^67^ | Yes | Yes | Yes | Yes | Yes
Smith, 2009^68^ | Yes | Yes | Yes | Yes | NR/CND
Golden, 2005^69^ | Yes | Yes | Yes | No | NR/CND
Morrow, 2005^70^ | Yes | Yes | NR/CND | No | NR/CND
Hogrefe, 2002^71^ | Yes | Yes | Yes | Yes | NR/CND
Gamiel, 2008^96^ | Yes | No | Yes | Yes | NR/CND
Van Dyck, 2004^72^ | Yes | No | Yes | Yes | NR/CND
Ashley, 1998^97^ | No | No | No | Yes | NR/CND

First Author, Year | What was the overall attrition? | Were withdrawals from the study explained (post-enrollment)? | Were methods for calculating accuracy clearly reported and valid? | Did the study have high attrition raising concern for bias? | What was the method used to handle missing data? | Quality | Comments
Lingappa, 2010^73^ | 5% | Yes | Yes | No | Excluded | Good | 5% (N=26) of samples had equivocal WB results and were excluded from the analyses. The characteristics of the subset of participants included in this analysis were not described (only those of the overall community cross-sectional sample, N=1124). There was no description of whether participants had current or previous symptoms consistent with genital herpes.
Mark, 2007^65^ | 11% | Yes | Yes | No | Excluded | Good | NA
Ng’ayo, 2010^74^ | ≥6% (see comments) | Yes | Yes | Unclear | Excluded | Fair | Characteristics of population not described (included prior symptoms of genital herpes); all equivocal and indeterminate results (on both WB and serologic screening test) were excluded from sensitivity and specificity calculations. For higher cutoff values on the Focus test, the number of equivocal values was high (approximately 40% of the sample tested).
Delany-Moretlwe, 2009^75^ | Unclear | NA | Yes | No | NA | Fair | A random sample of results from the larger sample (N=210) was compared with WB; the results were used to extrapolate sensitivity/specificity in the full sample. Handling of Indeterminate or equivocal test results was not reported. Results for subgroups of participants (by age and HIV status) were given but no measure of variance (confidence interval) was reported for the subgroups.
Summerton, 2007^95^ | 1% | Yes | Yes | No | Excluded | Poor | Specificity outcome was not eligible due to sampling strategy. All participants who had a positive result on at least 1 of 3 serologic screening tests had the WB; participants who had a negative result on the 3 serologic tests were excluded.
Ashley-Morrow, 2004^66^ | See comments | Yes | Yes | No | NA | Fair | Samples from some sites (Barcelona and Hanoi) were not considered due to technical issues. 20 samples were excluded due to equivocal results (2.9%). Subset of samples were compared to the WB and results were used to estimate the sensitivity/specificity for the overall sample.
Mujugira, 2011^67^ | 4% | Yes | Yes | No | Excluded | Good | Unequivocal test results (4%) excluded from sensitivity/specificity calculations.
Smith, 2009^68^ | 2% | NA | Yes | No | Excluded | Fair | Blinding of outcome assessors is not reported (but the tests were conducted at different sites); does not appear that data were missing but equivocal results were excluded.
Golden, 2005^69^ | 5% | NR/CND | Yes | No | Excluded | Fair | Unclear if test results were interpreted blindly; excluded atypical WB results.
Morrow, 2005^70^ | 8% | NR/CND | Yes | No | Excluded | Fair | Testing was not performed on the whole sample; only the MSM sample was reported to be randomly selected (the other sample was not reported). All participants did not receive WB; assuming blinded.
Hogrefe, 2002^71^ | 2% | NR/CND | Yes | No | See comments | Fair | WB atypical tests were excluded; indeterminate HerpeSelect serologic test results were considered positive.
Gamiel, 2008^96^ | NR | NA | NR/CND | NA | NR | Poor | Methods for calculating sensitivity/specificity are not reported, specifically how indeterminate values were handled. Sample size for the Biokit HSV-2 Rapid Test analysis for HIV-negative subgroup is not reported.
Van Dyck, 2004^72^ | Unclear | NA | Yes | NR/CND | NR | Fair | Sensitivity was estimated by taking a random sample of serologic test results that were concordant (positives and negatives) and all those that were discordant compared with the monclonal antibody-blocking enzyme immunoassay and comparing those with the WB. The handling of indeterminate tests is unclear; however, it appears that a positive test was defined as ≥1.1, and lower results were considered negative.
Ashley, 1998^97^ | 2% | NA | Yes | No | Excluded | Poor | Characteristics of study sample are not reported. Risk of spectrum bias; samples were chosen based on known, clear profiles to HSV-1 and HSV-2.

Abbreviations: CND=cannot determine; N=number; NA=not applicable; NR=not reported; MSM=men who have sex with men; WB=Western blot.

Appendix D Table 2 Quality Ratings of Studies Assessing the Harms of Serologic Screening for HSV-2 (Key Question 3)

First Author, Year | Were eligibility criteria clearly described? | Were subjects^*^ representative of the overall source population? | Were criteria used to assess prior symptoms clearly described? | What was the overall attrition? | Did the study have high attrition raising concern for bias? | Were outcomes prespecified/defined and adequately described? | Were outcome measures valid and reliable? | Quality | Comments
Smith, 2000^98^ | Partially | NR/CND | No | 46% | Yes | Yes | Yes | Poor | High risk of selection bias and high attrition (with persons having significant anxiety less likely to follow up). Study population was recruited from persons presenting to sexual health clinics in Australia. How authors determined symptom status was not described.
Edlow, 2012^99^ | No | NR/CND | No | NR | NR/CND | Yes | Unclear | Poor | This is an abstract that has limited description of methods, including no description of eligibility criteria. Overall, there is a high risk of selection bias. Personal communication from the author indicated that “all comers” were enrolled. The author states that participants were not explicitly treatment-seeking or symptomatic; however, the percent with no prior or current symptoms is unknown. Validity of the GHQ-12 to assess harms (e.g., whether it is sensitive enough) in this context is uncertain.
Mark, 2008^77^ | Partially (see comments) | NR/CND | No | 72% | Yes | Yes | Yes | Poor | High risk of selection bias, high attrition, and no control group. Very small sample with just 3 WB confirmed positives completing the followup. Eligibility criteria are not clear about determination of history of genital sores or genital herpes or whether participants were required to be asymptomatic. Given the heavy reliance on flyers and ads for recruitment, population is more likely a group with possible reasons to want testing.
Rosenthal, 2006^79^ | No | NR/CND | No | 19% | Yes | Yes | Yes | Fair for HRQOL outcomes; poor for all other outcomes | High risk of selection bias, very high attrition, no concurrent control group that was not screened. Participants required to have no known history of genital herpes; criteria used to determine symptoms was not described. We rated herpes-related QOL data as fair quality; the lack of a control group for this outcome is less concerning since the questions are specific to having a genital herpes diagnosis.
Melville, 2003^78^ | Yes | No | No | 67% of those invited participated (24/36) | Yes | Yes | Yes | Fair | High risk of selection bias; participants were selected from various sites using different recruitment procedures. It is unclear how many were eligible at each site. Authors note 67% of those invited agreed to participate. Authors used predefined semistructured interviews to elicit psychosocial outcomes related to serologic testing. The questionnaire is not shown. Only themes reported by ≥3 participants were reported, so less common outcomes and potentially serious outcomes (suicidality) may have occurred in as many as 2 participants without being reported.
Hallfors, 2015^45^ | Yes | No | No | Unclear | NR/CND | No | Unclear | Poor | Participants were orphans selected from 26 primary schools in Nyanza Province, Kenya. It is unclear whether participants were asked about history of signs/symptoms of genital herpes. Proportion of youth who declined to participate was not reported. Data on the psychosocial response at disclosure appears to have been collected on all 28 participants who tested positive. Outcome measures are not described; research staff and interviewers coded participant and caregiver responses to disclosure. Results were not based on patient-reported (or caregiver reported) measures of psychosocial harms.
Richards, 2007^88^ | Yes | NR/CND | No | Of those testing HSV-2 positive (N=87), 89% completed followup | Yes | Yes | Mixed | Poor | High risk of selection bias; unclear if subjects who agreed to participate are similar to the overall source population. Recruitment was not based on the presence or absence of prior symptoms; half of participants were HSV-2 positive or had a prior diagnosis of genital herpes. Criteria for determining prior diagnosis of genital herpes are not described. Of those contacted via letter (N=5703), 17% responded and agreed to be contacted. Of those who agreed to be contacted (N=955), 36% agreed to enroll and have HSV-2 testing, 29% declined to participate, 33% could not be contacted, and 2% were ineligible. Of those who tested HSV-2 positive (N=87), 89% completed followup. Many outcomes were general QOL or mood state; it is unclear if these are valid measures of the harms associated with HSV-2 screening.

* Are they generally asymptomatic persons with no prior history of genital herpes recruited from primary care settings? Is the sample that participated similar to the overall source population?

Abbreviations: CND=cannot determine; N=number; NA=not applicable; NR=not reported; QOL=quality of life; WB=Western Blot.

Appendix D Table 3 Quality Ratings of Studies of Antiviral Medications on HSV-2 Viral Shedding, Symptomatic Episodes, and Transmission (Key Questions 4 and 5)

First Author, Year | Was randomization adequate? | Was allocation concealment adequate? | Are baseline characteristics similar between groups? | What was the overall attrition? | What was the differential attrition?
Corey, 2004^76^ Kim, 2008^83^ | Yes | Yes | Yes | 22% | 2%
Mujugira^84^ | Yes | NR/CND | Yes | 66% | 2%
Sperling, 2008^81^ | Yes | NR/CND | Yes | 29% | 1.3%
Leone, 2007^82^ | Yes | Yes | Yes | 23% | NR

Abbreviations: CND=cannot determine; NR=not reported.

First Author, Year | Did the study have high differential attrition (>10%) or overall high attrition (generally 20%) raising concern for bias? | Did the study have crossovers or contamination raising concern for bias? | Were outcome measures valid and reliable? | Were patients masked? | Were providers masked? | Were outcome assessors masked? | Was the duration of followup adequate to assess the outcome?
Corey, 2004^76^ Kim, 2008^83^ | No | No | Yes | Yes | NR/CND | Yes | Yes
Mujugira^84^ | Yes | NR/CND | Yes | Yes | Yes | NR/CND | Yes
Sperling, 2008^81^ | Yes | No | Yes | Yes | Yes | NR/CND | Yes
Leone, 2007^82^ | Yes | NR/CND | Yes | Yes | Yes | NR/CND | Yes

Abbreviations: CND=cannot determine; NR=not reported.

First Author, Year | What was the method used to handle missing data? | Did the study use acceptable statistical methods? ITT vs. per protocol; adjustment for factors? | Was compliance to study medication adequate? | Quality | Comments
Corey, 2004^76^ Kim, 2008^83^ | Data for subjects who did not reach an end point were censored as event-free periods ending on the last day that the absence of the end point was confirmed. | Yes | Yes | Fair | More couples randomized to placebo withdrew; per authors withdrawal occurred because more source partners had frequent symptoms. Missing data were censored (as event-free periods). However, differential attrition was relatively low (2%).
Mujugira^84^ | Modeling was used to impute some data. | Yes | Yes | Fair | Overall attrition is high; analysis accounted for some of the missing data.
Sperling, 2008^81^ | Missing data were excluded. | Yes | NR/CND | Fair | This is a crossover RCT. There was an overall high rate of attrition (29 %); differential attrition was low.
Leone, 2007^82^ | Unclear; modeling was used to estimate differences between groups and likely some data was imputed. However, participants who provided no swabs were excluded from analysis. | Yes | Yes | Fair for KQ 4 and 5 outcomes | This is a cross-over RCT; overall attrition is high (23%). Handling of missing data is unclear for some outcomes.

Abbreviations: CND=cannot determine; NR=not reported; RCT=randomized, controlled trial.

Appendix D Table 4 Quality Ratings of Studies of Assessing Harms Of Preventive Interventions (Key Question 6)

First Author, Year | Were harms prespecified and defined? | Were ascertainment techniques for harms adequately described? | Were ascertainment techniques for harms equal, valid, and reliable? | Was duration of followup adequate for harms assessment? | Quality | Comments
Sperling, 2008^81^ | No | No | NR/CND | Yes | Fair | Adverse events were assessed at every visit after discussion with the subject and review of the subject’s diary. Harms do not appear to have been prespecified.
Leone, 2007^82^ | No | No | NR/CND | Yes | Poor | Harms are reported but not prespecified for well-defined; harms are only reported for the overall sample and not the subgroup of participants with no prior history of genital herpes.

Abbreviations: CND=cannot determine; NR=not reported.