# Appendix C Excluded Studies

Exclusion codes:

X1 Not original research
X2 Wrong population
X3 Wrong screening test
X4 Wrong or no intervention
X5 Wrong or no comparator
X6 Wrong outcome
X7 Wrong study design
X8 Non-English
X9 Poor quality

1 (1985). Oral acyclovir for genital herpes simplex infection. Med Lett Drugs Ther.
2 (2000). ACOG practice bulletin. Management of herpes in pregnancy. Number 8 October 1999. Clinical management guidelines for obstetrician-gynecologists. Int J Gynaecol Obstet.
3 Cochrane Sexually Transmitted Infections Group. (2012). About The Cochrane Collaboration.
4 Abbai NS, Wand H, Ramjee G. (2015). Socio-demographic and behavioural characteristics associated with HSV-2 sero-prevalence in high risk women in KwaZulu-Natal. BMC Res Notes.
5 Altomare GF, Polenghi MM, Pigatto PD, et al. (1985). Giornale italiano di dermatologia e venereologia : organo ufficiale, Società italiana di dermatologia e sifilografia.
6 Amudha VP, Rashetha, Sucilathangam G, et al. (2014). Serological profile of HSV-2 in STD patients: Evaluation of diagnostic utility of HSV-2 IgM and IgG detection. Journal of Clinical and Diagnostic Research.
7 Andrews W, Kimberlin D, Whitley R, et al. (2002). Valaciclovir suppressive therapy in pregnant women reduces recurrent genital herpes (hsv): results of a randomized trial [abstract]. Am J Obstet Gynecol.
8 Andrews WW, Kimberlin DF, Whitley R, et al. (2006). Valacyclovir therapy to reduce recurrent genital herpes in pregnant women. Am J Obstet Gynecol.
9 Ashley R, Mertz GJ, Corey L. (1987). Detection of asymptomatic herpes simplex virus infections after vaccination. J Virol.
10 Ashley RL. (1993). Laboratory techniques in the diagnosis of herpes simplex infection. Genitourin Med.
11 Ashley RL. (2002). Performance and use of HSV type-specific serology test kits. Herpes.
12 Ashley RL, Militoni J, Lee F, et al. (1988). Comparison of Western blot (immunoblot) and glycoprotein G-specific immunodot enzyme assay for detecting antibodies to herpes simplex virus types 1 and 2 in human sera. J Clin Microbiol.
13 Ashley RL, Wald A, Eagleton M. (2000). Premarket evaluation of the POCkit HSV-2 type-specific serologic test in culture-documented cases of genital herpes simplex virus type 2 [see comment]. Sex Transm Dis.
14 Ashley RL, Wu L, Pickering JW, et al. (1998). Premarket evaluation of a commercial glycoprotein G-based enzyme immunoassay for herpes simplex virus type-specific antibodies. J Clin Microbiol.
15 Aurelius E, Franzen-Rohl E, Glimaker M, et al. (2012). Long-term valacyclovir suppressive treatment after herpes simplex virus type 2 meningitis: a double-blind, randomized controlled trial. Clin Infect Dis.
16 Baeten JM, Reid SE, Delany-Moretlwe S, et al. (2012). Clinical and virologic response to episodic acyclovir for genital ulcers among HIV-1 seronegative, herpes simplex virus type 2 seropositive African women: a randomized, placebo-controlled trial. Sex Transm Dis.
17 Baird SJ, Garfein RS, McIntosh CT, et al. (2012). Effect of a cash transfer programme for schooling on prevalence of HIV and herpes simplex type 2 in Malawi: a cluster randomised trial. Lancet.
18 Baker D, Brown Z, Hollier LM, et al. (2004). Cost-effectiveness of herpes simplex virus type 2 serologic testing and antiviral therapy in pregnancy (Structured abstract). Am J Obstet Gynecol.
19 Baker DA, Pressley A, Meek L, et al. (2011). HSV serologic testing for pregnant women: willingness to be tested and factors affecting testing. Infect Dis Obstet Gynecol.
20 Banhidy F, Duda SI, Czeizel AE. (2011). Preconceptional screening of sexually transmitted infections/diseases. Central European Journal of Medicine.
21 Barnabas RV, Carabin H, Garnett GP. (2002). The potential role of suppressive therapy for sex partners in the prevention of neonatal herpes: a health economic analysis (Structured abstract). Sex Transm Infect.
22 Barton SE, Davis JM, Moss VW, et al. (1987). Asymptomatic shedding and subsequent transmission of genital herpes simplex virus. Genitourin Med.
23 Belec L, Gresenguet G, Mbopi Keou FX, et al. (2000). High frequency of asymptomatic shedding of herpes simplex virus type 2 in African women [4]. Clin Microbiol Infect.
24 Bodeus M, Laffineur K, Kabamba-Mukadi B, et al. (2004). Seroepidemiology of herpes simplex type 2 in pregnant women in Belgium. Sex Transm Dis.
25 Bornstein J, Ben-Porath E, Nizri M, et al. (1993). Evaluation of a monoclonal antibody-based enzyme immunoassay for early detection of herpes simplex virus genital infection. Isr J Med Sci.
26 Boyer CB, Barrett DC, Peterman TA, et al. (1997). Sexually transmitted disease (STD) and HIV risk in heterosexual adults attending a public STD clinic: evaluation of a randomized controlled behavioral risk-reduction intervention trial. AIDS.
27 Braig S, Chanzy B. (2004). Management of genital herpes during pregnancy: The French experience. Herpes.
28 Braig S, Luton D, Sibony O, et al. (2001). Acyclovir prophylaxis in late pregnancy prevents recurrent genital herpes and viral shedding. Eur J Obstet Gynecol Reprod Biol.
29 Branson BM, Peterman TA, Cannon RO, et al. (1998). Group counseling to prevent sexually transmitted disease and HIV: a randomized controlled trial. Sex Transm Dis.
30 Brocklehurst P, Carney O, Helson K, et al. (1990). Acyclovir, herpes, and pregnancy. Lancet.
31 Brocklehurst P, Kinghorn G, Carney O, et al. (1998). A randomised placebo controlled trial of suppressive acyclovir in late pregnancy in women with recurrent genital herpes infection. Br J Obstet Gynaecol.
32 Brown D. (1996). Oral famciclovir for recurrent genital herpes. J Fam Pract.
33 Brown EL, Wald A, Hughes JP, et al. (2006). High risk of human immunodeficiency virus in men who have sex with men with herpes simplex virus type 2 in the EXPLORE study. Am J Epidemiol.
34 Brown ZA. (2000). HSV-2 specific serology should be offered routinely to antenatal patients. Rev Med Virol.
35 Brown ZA, Benedetti J, Ashley R, et al. (1991). Neonatal herpes simplex virus infection in relation to asymptomatic maternal infection at the time of labor. N Engl J Med.
36 Brown ZA, Benedetti J, Selke S, et al. (1996). Asymptomatic maternal shedding of herpes simplex virus at the onset of labor: relationship to preterm labor. Obstet Gynecol.
37 Brown ZA, Benedetti JK, Watts DH, et al. (1995). A comparison between detailed and simple histories in the diagnosis of genital herpes complicating pregnancy. Am J Obstet Gynecol.
38 Brown ZA, Selke S, Zeh J, et al. (1997). The acquisition of herpes simplex virus during pregnancy. N Engl J Med.
39 Brown ZA, Vontver LA, Benedetti J, et al. (1985). Genital herpes in pregnancy: risk factors associated with recurrences and asymptomatic viral shedding. Am J Obstet Gynecol.
40 Brown ZA, Wald A, Morrow RA, et al. (2003). Effect of serologic status and cesarean delivery on transmission rates of herpes simplex virus from mother to infant. JAMA.
41 Brown ZA, Watts DH. (1990). Antiviral therapy in pregnancy. Clin Obstet Gynecol.
42 Brugha R, Brown D, Meheus A, et al. (1999). Should we be screening for asymptomatic HSV infections?. Sex Transm Infect.
43 Bryson Y, Dillon M, Bernstein DI, et al. (1993). Risk of acquisition of genital herpes simplex virus type 2 in sex partners of persons with genital herpes: a prospective couple study. J Infect Dis.
44 Bryson YJ, Dillon M, Lovett M, et al. (1983). Treatment of first episodes of genital herpes simplex virus infection with oral acyclovir. A randomized double-blind controlled trial in normal subjects. N Engl J Med.
45 Budd B. (2000). Genital herpes in adolescents. Adv Nurse Pract.
46 Burton MJ, Penman A, Sunesara I, et al. (2014). A pilot study examining the safety and tolerability of valacyclovir in veterans with hepatitis C virus/herpes simplex virus type 2 coinfection. Am J Med Sci.
47 CS. (1997). Type-specific herpes simplex virus antibodies: comparison of different ELISA systems and a Western blot. J Lab Med.
48 Carvalho M, de Carvalho S, Pannuti CS, et al. (1998). Prevalence of herpes simplex type 2 antibodies and a clinical history of herpes in three different populations in Campinas City, Brazil. Int J Infect Dis.
49 Catallozzi M, Ebel SC, Chavez NR, et al. (2013). Understanding perceptions of genital herpes disclosure through analysis of an online video contest. Sex Transm Infect.
50 Cattan P, Cuillerier E, Cellier C, et al. (1999). Black esophagus associated with herpes esophagitis. Gastrointest Endosc.
51 Celum C, Morrow RA, Donnell D, et al. (2014). Daily oral tenofovir and emtricitabine-tenofovir preexposure prophylaxis reduces herpes simplex virus type 2 acquisition among heterosexual HIV-1-uninfected men and women: a subgroup analysis of a randomized trial. Ann Intern Med.
52 Celum C, Wald A, Hughes J, et al. (2008). Effect of aciclovir on HIV-1 acquisition in herpes simplex virus 2 seropositive women and men who have sex with men: a randomised, double-blind, placebo-controlled trial. Lancet.
53 Celum C, Wald A, Lingappa JR, et al. (2010). Acyclovir and transmission of HIV-1 from persons infected with HIV-1 and HSV-2. N Engl J Med.
54 Chen XS, Yin YP, Chen LP, et al. (2007). Herpes simplex virus 2 infection in women attending an antenatal clinic in Fuzhou, China. Sex Transm Infect.
55 Cherpes TL, Melan MA, Kant JA, et al. (2005). Genital tract shedding of herpes simplex virus type 2 in women: effects of hormonal contraception, bacterial vaginosis, and vaginal group B Streptococcus colonization. Clin Infect Dis.
56 Chopra S, Devi P, Devi B. (2013). Herpes simplex virus 2 : a boon to develop other sexually transmitted infections. J Indian Med Assoc.
57 Christie SN, McCaughey C, McBride M, et al. (1997). Herpes simplex type 1 and genital herpes in Northern Ireland [2]. Int J STD AIDS.
58 Cirelli R, Herne K, McCrary M, et al. (1996). Famciclovir: Review of clinical efficacy and safety. Antiviral Res.
59 Cone RW, Hobson AC, Brown Z, et al. (1994). Frequent detection of genital herpes simplex virus DNA by polymerase chain reaction among pregnant women. JAMA.
60 Cook C. (2013). Diagnostic classification, viral sexually transmitted infections and discourses of femininity: limits of normalisation to erase stigma. Nurs Inq.
61 Cook RL, Pollock NK, Rao AK, et al. (2002). Increased prevalence of herpes simplex virus type 2 among adolescent women with alcohol use disorders. J Adolesc Health.
62 Copas AJ, Cowan FM, Cunningham AL, et al. (2002). An evidence based approach to testing for antibody to herpes simplex virus type 2. Sex Transm Infect.
63 Corey L, Nahmias AJ, Guinan ME, et al. (1982). A trial of topical acyclovir in genital herpes simplex virus infections. N Engl J Med.
64 Cotton S, Connelly BL, Cohen SS, et al. (2002). Screening for Neonatal Herpes: Physicians’ Descriptions of Discussions with Parents. Herpes.
65 Crosby RA, DiClemente RJ, Wingood GM, et al. (2003). Testing for HSV-2 infection among pregnant teens: implications for clinical practice. J Pediatr Adolesc Gynecol.
66 Crosby RA, Head S, Diclemente RJ, et al. (2008). Do protective behaviors follow the experience of testing positive for herpes simplex type 2?. Sex Transm Dis.
67 Cusini M, Cusan M, Parolin C, et al. (2000). Seroprevalence of herpes simplex virus type 2 infection among attendees of a sexually transmitted disease clinic in Italy. Italian Herpes Forum. Sex Transm Dis.
68 Cuyugan MG, Mulugeta W, Thabolingam-Haridas M, et al. (2011). Knowledge of HSV-2 serostatus in asymptomatic adults may result in change in sexual behaviour and possible risk reduction. Sex Transm Infect.
69 Da Rosa-Santos OL, Goncalves Da Silva A, Pereira AC. (1996). Herpes simplex virus type 2 in Brazil: seroepidemiologic survey. Int J Dermatol.
70 Daubin C. (2006). Authors’ reply to the comment by Dr. Oud [7]. Intensive Care Med.
71 Davies SC, Taylor JA, Sedyaningsih-Mamahit ER, et al. (2007). Prevalence and risk factors for herpes simplex virus type 2 antibodies among low- and high-risk populations in Indonesia. Sex Transm Dis.
72 De Ory F, Guisasola ME, Casas I, et al. (1997). Evaluation of new reagents for typing IgG to HSV-1 and HSV-2. Opportunistic Pathogens.
73 de Ory F, Pachon I, Echevarria JM, et al. (1999). Seroepidemiological study of herpes simplex virus in the female population in the autonomous region of Madrid, Spain. Eur J Clin Microbiol Infect Dis.
74 Delaney S, Gardella C, Daruthayan C, et al. (2012). A prospective cohort study of partner testing for herpes simplex virus and sexual behavior during pregnancy. J Infect Dis.
75 Diagnostics M. (2000). HSV-2 ELISA IgG 510(k) Summary of Safety and Effectiveness. MRL Diagnostics.
76 Diagnostics M. (2000). HSV-1 & HSV-2 Differentiation Immunoblot IgG 510(k) Summary of Safety and Effectiveness.
77 DiClemente RJ, Salazar LF, Crosby RA. (2007). A review of STD/HIV preventive interventions for adolescents: sustaining effects using an ecological approach. J Pediatr Psychol.
78 Doerr HW, Lehmair H, Schmitz H, et al. (1977). Simple mathematical deductions in the seroepidemiology of viral infections. I. Herpesvirus group (herpesvirus hominis, varicella-zoster virus, cytomegalovris, Epstein-Barr-Virus). Zentralbl Bakteriol Orig A.
79 Donigan JM, Pascoe VL, Kimball AB. (2015). Psoriasis and herpes simplex virus are highly stigmatizing compared with other common dermatologic conditions: A survey-based study. J Am Acad Dermatol.
80 Doyle AM, Ross DA, Maganja K, et al. (2010). Long-term biological and behavioural impact of an adolescent sexual health intervention in Tanzania: follow-up survey of the community-based MEMA kwa Vijana Trial. PLoS Med.
81 Doyle AM, Weiss HA, Maganja K, et al. (2011). The long-term impact of the MEMA kwa Vijana adolescent sexual and reproductive health intervention: effect of dose and time since intervention exposure. PLoS One.
82 Eberhart-Phillips J, Dickson NP, Paul C, et al. (1998). Herpes simplex type 2 infection in a cohort aged 21 years. Sex Transm Infect.
83 Edlow A, Kaimal A, Lee H, et al. (2012). Screening for herpes simplex virus in pregnancy does not impact quality of life. Reprod Sci.
84 Edmiston N, O’Sullivan M, Charters D, et al. (2003). Study of knowledge of genital herpes infection and attitudes to testing for genital herpes among antenatal clinic attendees. Aust N Z J Obstet Gynaecol.
85 Eis-Hubinger AM, Daumer M, Matz B, et al. (1999). Evaluation of three glycoprotein G2-based enzyme immunoassays for detection of antibodies to herpes simplex virus type 2 in human sera. J Clin Microbiol.
86 Eis-Hubinger AM, Nyankiye E, Bitoungui DM, et al. (2002). Prevalence of herpes simplex virus type 2 antibody in Cameroon. Sex Transm Dis.
87 Enright AM, Prober CG. (2002). Neonatal herpes infection: diagnosis, treatment and prevention. Semin Neonatol.
88 Eskild A, Jeansson S, Hagen JA, et al. (2000). Herpes simplex virus type-2 antibodies in pregnant women: The impact of the stage of pregnancy. Epidemiol Infect.
89 Fairley I, Monteiro EF. (1997). Patient attitudes to type specific serological tests in the diagnosis of genital herpes. Genitourin Med.
90 Ferrucci M, Zavarini A. (1982). ELISA and TORCH complex: a comparison with the customary tests. Quad Sclavo Diagn.
91 Fife KH, Warren TJ, Justus SE, et al. (2008). An international, randomized, double-blind, placebo-controlled, study of valacyclovir for the suppression of herpes simplex virus type 2 genital herpes in newly diagnosed patients. Sex Transm Dis.
92 Fisman DN, Hook EW, Goldie SJ. (2003). Estimating the costs and benefits of screening monogamous, heterosexual couples for unrecognised infection with herpes simplex virus Type 2 (Structured abstract). Sex Transm Infect.
93 Frenkel LM, Brown ZA, Bryson YJ, et al. (1991). Pharmacokinetics of acyclovir in the term human pregnancy and neonate. Am J Obstet Gynecol.
94 Frenkel LM, Garratty EM, Jie Ping S, et al. (1993). Clinical reactivation of herpes simplex virus type 2 infection in seropositive pregnant women with no history of genital herpes. Ann Intern Med.
95 Fuchs J, Celum C, Wang J, et al. (2010). Clinical and virologic efficacy of herpes simplex virus type 2 suppression by acyclovir in a multicontinent clinical trial. J Infect Dis.
96 Gamiel JL, Tobian AA, Laeyendecker OB, et al. (2008). Improved performance of enzyme-linked immunosorbent assays and the effect of human immunodeficiency virus coinfection on the serologic detection of herpes simplex virus type 2 in Rakai, Uganda. Clin Vaccine Immunol.
97 Garcia-Corbeira P, Hogrefe W, Aguilar L, et al. (1999). Whole cell lysate enzyme immunoassays vs. recombinant glycoprotein G2-based immunoassays for HSV-2 seroprevalence studies. J Med Virol.
98 Gardella C, Krantz E, Daruthayan C, et al. (2009). The acceptance of HSV-testing partners of HSV-2 seronegative pregnant women. Sex Transm Dis.
99 Garland SM, Lee TN, Ashley RL, et al. (1995). Automated microneutralization: method and comparison with western blot for type-specific detection of herpes simplex antibodies in two pregnant populations. J Virol Methods.
100 Ghazi HO, Telmesani AM, Mahomed MF. (2002). TORCH agents in pregnant Saudi women. Med Princ Pract.
101 Gilbert LK, Schulz SL, Ebel C. (2002). Education and Counselling for Genital Herpes: Perspectives from Patients. Herpes.
102 Gimenes F, Medina FS, De Abreu ALP, et al. (2014). Sensitive simultaneous detection of seven sexually transmitted agents in Semen by multiplex-PCR and of HPV by single PCR. PLoS One.
103 Gorander S, Mbwana J, Lyamuya E, et al. (2006). Mature glycoprotein g presents high performance in diagnosing herpes simplex virus type 2 infection in sera of different tanzanian cohorts. Clin Vaccine Immunol.
104 Gottlieb SL, Douglas JM, Foster M, et al. (2004). Incidence of herpes simplex virus type 2 infection in 5 sexually transmitted disease (STD) clinics and the effect of HIV/STD risk-reduction counseling. J Infect Dis.
105 Gottlieb SL, Douglas JM, Schmid DS, et al. (2002). Seroprevalence and correlates of herpes simplex virus type 2 infection in five sexually transmitted-disease clinics. J Infect Dis.
106 Green J, Ferrier S, Kocsis A, et al. (2003). Determinants of disclosure of genital herpes to partners. Sex Transm Infect.
107 Groen J, Van Dijk G, Niesters HG, et al. (1998). Comparison of two enzyme-linked immunosorbent assays and one rapid immunoblot assay for detection of herpes simplex virus type 2-specific antibodies in serum. J Clin Microbiol.
108 Guerry SL, Bauer HM, Klausner JD, et al. (2005). Recommendations for the selective use of herpes simplex virus type 2 serological tests. Clin Infect Dis.
109 Guirguis-Blake J, Wolff TA. (2005). Screening for genital herpes. Am Fam Physician.
110 Gumber S, Arora U, Devi P. (2008). Occurrence of cytomegalo virus and herpes simplex virus infections in pregnancy. Indian J Med Microbiol.
111 Gupta R, Wald A, Krantz E, et al. (2004). Valacyclovir and acyclovir for suppression of shedding of herpes simplex virus in the genital tract. J Infect Dis.
112 Hallfors DD, Cho H, Mbai II, et al. (2015). Disclosure of HSV-2 serological test results in the context of an adolescent HIV prevention trial in Kenya. Sex Transm Infect.
113 Halsos AM, Gundersen T, Tjotta EA, et al. (1985). Z Hautkr.
114 Handsfield HH, Warren T, Werner M, et al. (2007). Suppressive therapy with valacyclovir in early genital herpes: a pilot study of clinical efficacy and herpes-related quality of life. Sex Transm Dis.
115 Hintz M, Connor JD, Spector SA, et al. (1982). Neonatal acyclovir pharmacokinetics in patients with herpes virus infections. Am J Med.
116 Hollier LM, Wendel GD. (2008). Third trimester antiviral prophylaxis for preventing maternal genital herpes simplex virus (HSV) recurrences and neonatal infection. Cochrane Database Syst Rev.
117 Holt M, Bernard D, Race K. (2010). Gay men’s perceptions of sexually transmissible infections and their experiences of diagnosis: ‘Part of the way of life’ to feeling ‘dirty and ashamed’. Sexual Health.
118 Howard M, Sellors JW, Jang D, et al. (2003). Regional distribution of antibodies to herpes simplex virus type 1 (HSV-1) and HSV-2 in men and women in Ontario, Canada. J Clin Microbiol.
119 Isacsohn M, Bar On E, Yaeger Y, et al. (1994). A seroprevalence study of herpes virus type 2 infection in Israeli women: implications for routine screening. Isr J Med Sci.
120 Jacob M, Rao PSS, Sridharan G, et al. (1989). Epidemiology & clinical profile of genital herpes. Indian Journal of Medical Research - Section A Infectious Diseases.
121 Jewkes R, Nduna M, Levin J, et al. (2008). Impact of Stepping Stones on incidence of HIV and HSV-2 and sexual behaviour in rural South Africa: Cluster randomised controlled trial. BMJ.
122 Johnson FB, Visick EM. (1992). A rapid culture alternative to the shell-vial method for the detection of herpes simplex virus. Diagn Microbiol Infect Dis.
123 Johnston C, Saracino M, Kuntz S, et al. (2012). Standard-dose and high-dose daily antiviral therapy for short episodes of genital HSV-2 reactivation: three randomised, open-label, cross-over trials. Lancet.
124 Kamali A, Quigley M, Nakiyingi J, et al. (2003). Syndromic management of sexually-transmitted infections and behaviour change interventions on transmission of HIV-1 in rural Uganda: a community randomised trial. Lancet.
125 Kamb ML, Fishbein M, Douglas JM, et al. (1998). Efficacy of risk-reduction counseling to prevent human immunodeficiency virus and sexually transmitted diseases: a randomized controlled trial. Project RESPECT Study Group. JAMA.
126 Kelly NC, Zimet GD, Aalsma MC, et al. (2009). Intent to accept and acceptance of herpes testing in adolescents and young adults. Sex Transm Infect.
127 Khryanin AA, Reshetnikov OV. (2007). Seroprevalence of herpes simplex virus type 2 infection in Russia. Int J STD AIDS.
128 Kim ID, Chang HS, Hwang KJ. (2012). Herpes simplex virus 2 infection rate and necessity of screening during pregnancy: a clinical and seroepidemiologic study. Yonsei Med J.
129 Kimberlin D, Powell D, Gruber W, et al. (1996). Administration of oral acyclovir suppressive therapy after neonatal herpes simplex virus disease limited to the skin, eyes and mouth: results of a phase I/II trial. Pediatr Infect Dis J.
130 Kimberlin DF, Weller S, Whitley RJ, et al. (1998). Pharmacokinetics of oral valacyclovir and acyclovir in late pregnancy. Am J Obstet Gynecol.
131 Kimberlin DW. (2004). Neonatal HSV infections: The global picture. Herpes.
132 Kimberlin DW, Rouse DJ. (2004). Clinical practice. Genital herpes. N Engl J Med.
133 Kinghorn GR, Abeywickreme I, Jeavons M, et al. (1986). Efficacy of oral treatment with acyclovir and co-trimoxazole in first episode genital herpes. Genitourin Med.
134 Kinghorn GR, Woolley PD, Thin RN, et al. (1992). Acyclovir vs isoprinosine (immunovir) for suppression of recurrent genital herpes simplex infection. Genitourin Med.
135 Kircik L, Jones TM, Jarratt M, et al. (2012). Treatment with a novel topical nanoemulsion (NB-001) speeds time to healing of recurrent cold sores. J Drugs Dermatol.
136 Kucera P, Gerber S, Marques-Vidal P, et al. (2012). Seroepidemiology of herpes simplex virus type 1 and 2 in pregnant women in Switzerland: an obstetric clinic based study. Eur J Obstet Gynecol Reprod Biol.
137 Kulhanjian JA, Soroush V, Au DS, et al. (1992). Identification of women at unsuspected risk of primary infection with herpes simplex virus type 2 during pregnancy. N Engl J Med.
138 Lam NN, Weir MA, Yao Z, et al. (2013). Risk of acute kidney injury from oral acyclovir: a population-based study. Am J Kidney Dis.
139 Le Cleach L, Trinquart L, Do G, et al. (2014). Oral antiviral therapy for prevention of genital herpes outbreaks in immunocompetent and nonpregnant patients. Cochrane Database Syst Rev.
140 Leach CT, Ashley RL, Baillargeon J, et al. (2002). Performance of two commercial glycoprotein G-based enzyme immunoassays for detecting antibodies to herpes simplex viruses 1 and 2 in children and young adolescents. Clin Diagn Lab Immunol.
141 Lebrun-Vignes B, Bouzamondo A, Dupuy A, et al. (2007). A meta-analysis to assess the efficacy of oral antiviral treatment to prevent genital herpes outbreaks. J Am Acad Dermatol.
142 LeGoff J, Gresenguet G, Gody C, et al. (2011). Performance of the BioPlex 2200 multiplexing immunoassay platform for the detection of herpes simplex virus type 2 specific antibodies in African settings. Clin Vaccine Immunol.
143 LeGoff J, Saussereau E, Boulanger MC, et al. (2007). Unexpected high prevalence of herpes simplex virus (HSV) type 2 seropositivity and HSV genital shedding in pregnant women living in an East Paris suburban area. Int J STD AIDS.
144 Leung DT, Henning PA, Wagner EC, et al. (2009). Inadequacy of plasma acyclovir levels at delivery in patients with genital herpes receiving oral acyclovir suppressive therapy in late pregnancy. J Obstet Gynaecol Can.
145 Levi M, Ruden U, Carlberg H, et al. (1999). The use of peptides from glycoproteins G-2 and D-1 for detecting herpes simplex virus type 2 and type-common antibodies. J Clin Virol.
146 Li Z, Yan R, Yan C, et al. (2015). Evaluation of an Automated Chemiluminescent Immunoassay in Typing Detection of IgG Antibodies Against Herpes Simplex Virus. J Clin Lab Anal.
147 Liermann K, Schafler A, Henke A, et al. (2014). Evaluation of commercial herpes simplex virus IgG and IgM enzyme immunoassays. J Virol Methods.
148 Lissauer T, Jeffries D. (1989). Preventing neonatal herpes infection. Br J Obstet Gynaecol.
149 LLC EU. ELISA 510(k) Substantial Equivalence Determination Decision Summary.
150 Loveless M, Sacks SL, Harris JRW. (1997). Famciclovir in the management of first-episode genital herpes. Infectious Diseases in Clinical Practice.
151 Lowhagen GB, Berntsson M, Bonde E, et al. (2005). Acceptance and outcome of herpes simplex virus type 2 antibody testing in patients attending an STD clinic--recognized and unrecognized infections. Acta Derm Venereol.
152 Maher JE, Peterman TA, Osewe PL, et al. (2003). Evaluation of a community-based organization’s intervention to reduce the incidence of sexually transmitted diseases: a randomized, controlled trial. South Med J.
153 Marcus JL, Glidden DV, McMahan V, et al. (2014). Daily oral emtricitabine/tenofovir preexposure prophylaxis and herpes simplex virus type 2 among men who have sex with men. PLoS One.
154 Mark H, Gilbert L, Nanda J. (2009). Psychosocial well-being and quality of life among women newly diagnosed with genital herpes. JOGNN - Journal of Obstetric, Gynecologic, and Neonatal Nursing.
155 Martens MG, Fife KH, Leone PA, et al. (2009). Once daily valacyclovir for reducing viral shedding in subjects newly diagnosed with genital herpes. Infect Dis Obstet Gynecol.
156 Martin ET, Krantz E, Gottlieb SL, et al. (2009). A pooled analysis of the effect of condoms in preventing HSV-2 acquisition. Arch Intern Med.
157 Martin ET, Krantz E, Gottlieb SL, et al. (2009). A pooled analysis of the effect of condoms in preventing HSV-2 acquisition (Structured abstract). Arch Intern Med.
158 Maters AW, Wright CV, Lee MT, et al. (2012). Detection of type-specific antibodies to HSV-1 and HSV-2: comparative analysis of a chemiluminescence immunoassay with a conventional ELISA. Diagn Microbiol Infect Dis.
159 Mayer AR, Duff P. (1982). Longitudinal screening for herpes simplex virus in obstetric patients. Mil Med.
160 Mehta SD, Moses S, Agot K, et al. (2013). Medical male circumcision and herpes simplex virus 2 acquisition: posttrial surveillance in Kisumu, Kenya. J Infect Dis.
161 Mehta SD, Moses S, Parker CB, et al. (2012). Circumcision status and incident herpes simplex virus type 2 infection, genital ulcer disease, and HIV infection. AIDS.
162 Mennemeyer ST, Cyr LP, Whitley RJ. (1997). Antiviral therapy for neonatal herpes simplex virus: a cost-effectiveness analysis. Am J Manag Care.
163 Merin A, Pachankis JE. (2011). The psychological impact of genital herpes stigma. J Health Psychol.
164 Metsch LR, Feaster DJ, Gooden L, et al. (2013). Effect of risk-reduction counseling with rapid HIV testing on risk of acquiring sexually transmitted infections: The AWARE randomized clinical trial. JAMA - Journal of the American Medical Association.
165 Meyer JL, Crosby RA, Whittington WL, et al. (2005). The psychosocial impact of serological herpes simplex type 2 testing in an urban HIV clinic. Sex Transm Infect.
166 Mindel A, Brocklehurst P. (1995). The treatment of herpes simplex virus infections. Antiviral Chemotherapy.
167 Mindel A. (1996). Psychological and psychosexual implications of herpes simplex virus infections. Scand J Infect Dis Suppl.
168 Mindel A, Taylor J. (2002). Debate: the argument against. Should every STD clinic patient be considered for type-specific serological screening for HSV?. Herpes.
169 Mindel A, Weller IV, Faherty A, et al. (1986). Acyclovir in first attacks of genital herpes and prevention of recurrences. Genitourin Med.
170 Miskulin M, Puntaric D, Bozikov J, et al. (2012). Objective identification of sexual risk behavior among blood donors in Croatia: is it reality?. Clin Lab.
171 Miyai T, Turner KR, Kent CK, et al. (2004). The psychosocial impact of testing individuals with no history of genital herpes for herpes simplex virus type 2. Sex Transm Dis.
172 Molina M, Romaguera RA, Valentine J, et al. (2011). Seroprevalence of herpes simplex virus 2 among Hispanics in the USA: National Health and Nutrition Examination Survey, 2007–2008. Int J STD AIDS.
173 Narouz N, Allan PS, Wade AH, et al. (2003). Genital herpes serotesting: A study of the epidemiology and patients’ knowledge and attitude among STD clinic attenders in Coventry, UK. Sex Transm Infect.
174 Newton DC, McCabe MP. (2008). Sexually transmitted infections: Impact on individuals and their relationships. J Health Psychol.
175 Nogueira De Souza NC, Botelho CAO, Honer MR. (2004). Retrospective study of a pioneer antenatal screening program with 8,477 pregnant women in Brazil. Clin Exp Obstet Gynecol.
176 Okonko IO, Cookey TI, Okerentugba PO, et al. (2015). Serum HSV-1 and -2 IgM in Pregnant Women in Port Harcourt, Nigeria. Journal of Immunoassay and Immunochemistry.
177 Patrick DM, Rosenthal SL, Stanberry LR, et al. (2004). Patient satisfaction with care for genital herpes: Insights from a global survey. Sex Transm Infect.
178 Perkins NL, Coughlan EP, Franklin RA, et al. (1996). Seroprevalence of herpes simplex virus type 2 antibodies in New Zealand sexual health clinic patients. N Z Med J.
179 Peterman TA, Lin LS, Newman DR, et al. (2000). Does measured behavior reflect STD risk? An analysis of data from a randomized controlled behavioral intervention study. Project RESPECT Study Group. Sex Transm Dis.
180 Philip SS, Ahrens K, Shayevich C, et al. (2008). Evaluation of a new point-of-care serologic assay for herpes simplex virus type 2 infection. Clin Infect Dis.
181 Phipps W, Nakku-Joloba E, Krantz EM, et al. (2016). Genital herpes simplex virus type 2 shedding among adults with and without HIV Infection in Uganda. J Infect Dis.
182 Picerno I, Donia D, Spataro P, et al. (1992). Comparison between DNA-PROBE, direct immunofluorescence, ELISA and cell culture as diagnostic tools for the gynecological herpes simplex virus infections. J Prev Med Hyg.
183 Pinninti SG, Angara R, Feja KN, et al. (2012). Neonatal herpes disease following maternal antenatal antiviral suppressive therapy: a multicenter case series. J Pediatr.
184 Pinninti SG, Kimberlin DW. (2014). Preventing herpes simplex virus in the newborn. Clin Perinatol.
185 Prince HE, Ernst CE, Hogrefe WR. (2000). Evaluation of an enzyme immunoassay system for measuring herpes simplex virus (HSV) type 1-specific and HSV type 2-specific IgG antibodies. J Clin Lab Anal.
186 Proper CG, Arvin AM. (1989). Genital herpes and pregnant women. Curr Clin Top Infect Dis.
187 Provenzale A, Evans K, Russell J, et al. (2011). Psychosocial impact of a positive HSV-2 diagnosis on adults with unrecognized HSV-2 infection. Public Health Nurs.
188 Quinlan JD. (2005). Sexually transmitted diseases in pregnancy. Clinics in Family Practice.
189 Ramos OM. (2009). Maternal and neonatal herpes simplex infection. Int Pediatr.
190 Ramos S, Lukefahr JL, Morrow RA, et al. (2006). Prevalence of herpes simplex virus types 1 and 2 among children and adolescents attending a sexual abuse clinic. Pediatr Infect Dis J.
191 Randolph AG, Hartshorn RM, Washington AE. (1996). Acyclovir prophylaxis in late pregnancy to prevent neonatal herpes: a cost-effectiveness analysis (Structured abstract). Obstet Gynecol.
192 Read JS, Cannon MJ, Stanberry LR, et al. (2008). Prevention of mother-to-child transmission of viral infections. Curr Probl Pediatr Adolesc Health Care.
193 Revello MG, Gualandri R, Manservigi R, et al. (1991). Development and evaluation of an ELISA using secreted recombinant glycoprotein B for determination of IgG antibody to herpes simplex virus. J Virol Methods.
194 Richards J, Scholes D, Caka S, et al. (2007). HSV-2 serologic testing in an HMO population: uptake and psychosocial sequelae. Sex Transm Dis.
195 Riedel A, Bohnert M, Scholz C, et al. (2013). Evaluation of elecsys (registered trademark) immunoassay system for determination of type-specific IgG antibodies to HSV-1 and HSV-2. Sex Transm Infect.
196 Riesbeck K, Hammas B. (2007). Comparison of an automated Borrelia indirect chemiluminescent immunoassay (CLIA) with a VlsE/C6 ELISA and Immunoblot. Eur J Clin Microbiol Infect Dis.
197 Ritzmann P. (1999). Praxis.
198 Romanowski B, Zdanowicz YM, Owens ST. (2008). In search of optimal genital herpes management and standard of care (INSIGHTS): Doctors’ and patients’ perceptions of genital herpes. Sex Transm Infect.
199 Rooney JF, Felser JM, Ostrove JM, et al. (1986). Acquisition of genital herpes from an asymptomatic sexual partner. N Engl J Med.
200 Rosenberry KR, Bryan CK, Sohn CA. (1982). Acyclovir: evaluation of a new antiviral agent. Clin Pharm.
201 Rosenthal SL, Stanberry LR, Biro FM, et al. (1997). Seroprevalence of herpes simplex virus types 1 and 2 and cytomegalovirus in adolescents. Clin Infect Dis.
202 Ross DA, Changalucha J, Obasi AI, et al. (2007). Biological and behavioural impact of an adolescent sexual health intervention in Tanzania: a community-randomized trial. AIDS.
203 Ross K, Johnston C, Wald A. (2011). Herpes simplex virus type 2 serological testing and psychosocial harm: a systematic review. Sex Transm Infect.
204 Roth AM, Van Der Pol B, Fortenberry JD, et al. (2013). Herpes simplex virus type 2 serological testing at a community court: Predictors of test acceptance and seropositivity among female defendants. Int J STD AIDS.
205 Rouse DJ, Stringer JS. (2000). An appraisal of screening for maternal type-specific herpes simplex virus antibodies to prevent neonatal herpes. Am J Obstet Gynecol.
206 Royer HR, Falk EC, Heidrich SM. (2013). Genital herpes beliefs: implications for sexual health. J Pediatr Adolesc Gynecol.
207 Russell DB, Tabrizi SN, Russell JM, et al. (2001). Seroprevalence of herpes simplex virus types 1 and 2 in HIV-infected and uninfected homosexual men in a primary care setting. J Clin Virol.
208 Ryan CE, Simbiken CS, Agius PA, et al. (2014). Comparative performance of the Kalon and HerpeSelect enzyme-linked immunosorbant assays to determine the prevalence of herpes simplex virus type 2 in Papua New Guinea. Sexual Health.
209 Saltzman R, Jurewicz R, Boon R. (1994). Safety of famciclovir in patients with herpes zoster and genital herpes. Antimicrob Agents Chemother.
210 Sauerbrei A, Schmitt S, Scheper T, et al. (2011). Seroprevalence of herpes simplex virus type 1 and type 2 in Thuringia, Germany, 1999 to 2006. Euro Surveill.
211 Sauerbrei A, Wutzler P. (2004). Serological detection of type-specific IgG to herpes simplex virus by novel ELISAs based on recombinant and highly purified glycoprotein G. Clinical Laboratory.
212 Sawleshwarkar S, Dwyer DE. (2015). Antivirals for herpes simplex viruses. BMJ (Online).
213 Schalkwyk J, Amiri N, Lalji S, et al. (2008). Acceptance of a rapid herpes test in labour: survey of attitudes of patients and health care providers. J Obstet Gynaecol Can.
214 Schiffer JT, Magaret A, Selke S, et al. (2011). Detailed analysis of mucosal herpes simplex virus-2 replication kinetics with and without antiviral therapy. J Antimicrob Chemother.
215 Schmid DS, Brown DR, Nisenbaum R, et al. (1999). Limits in reliability of glycoprotein G-based type-specific serologic assays for herpes simplex virus types 1 and 2. J Clin Microbiol.
216 Schrag SJ, Arnold KE, Mohle-Boetani JC, et al. (2003). Prenatal screening for infectious diseases and opportunities for prevention. Obstet Gynecol.
217 Scott LL. (1999). Prevention of perinatal herpes. Prophylactic antiviral therapy?. Clin Obstet Gynecol.
218 Scott LL, Hollier LM, Baum A, et al. (1998). Prevention of recurrent genital herpes at delivery using acyclovir suppression for herpes infection diagnosed prior to pregnancy - an interim analysis. American J Obstet Gynecol.
219 Scott LL, Hollier LM, McIntire D, et al. (2002). Acyclovir suppression to prevent recurrent genital herpes at delivery. Infect Dis Obstet Gynecol.
220 Scott LL, Sanchez PJ, Jackson GL, et al. (1996). Acyclovir suppression to prevent cesarean delivery after first-episode genital herpes. Obstet Gynecol.
221 Scoular A. (2002). Using the evidence base on genital herpes: optimising the use of diagnostic tests and information provision. Sex Transm Infect.
222 Shahraki AD, Moghim S, Akbari P. (2010). A survey on herpes simplex type 2 antibody among pregnant women in Isfahan, Iran. J Res Med Sci.
223 Shain RN, Piper JM, Newton ER, et al. (1999). A randomized, controlled trial of a behavioral intervention to prevent sexually transmitted disease among minority women. N Engl J Med.
224 Sheffield JS, Hollier LM, Stuart GS, et al. (2004). Acyclovir in late pregnancy reduces HSV recurrence, viral shedding, and cesarean delivery for HSV - Meta-analysis. Evidence-based Obstetrics and Gynecology.
225 Silins I, Tedeschi RM, Kallings I, et al. (2002). Clustering of seropositivities for sexually transmitted infections. Sex Transm Dis.
226 Slomka MJ, Ashley RL, Cowan FM, et al. (1995). Monoclonal antibody blocking tests for the detection of HSV-1- and HSV-2-specific humoral responses: comparison with western blot assay. J Virol Methods.
227 Smith A, Denham I, Keogh L, et al. (2000). Psychosocial impact of type-specific herpes simplex serological testing on asymptomatic sexual health clinic attendees. Int J STD AIDS.
228 Smith JS, Herrero R, Munoz N, et al. (2001). Prevalence and risk factors for herpes simplex virus type 2 infection among middle-age women in Brazil and the Philippines. Sex Transm Dis.
229 Song B, Dwyer DE, Mindel A. (2004). HSV type specific serology in sexual health clinics: use, benefits, and who gets tested. Sex Transm Infect.
230 Soto-Hernandez JL. (2000). Follow-up in herpes simplex virus encephalitis. Clin Infect Dis.
231 Stephenson-Famy A, Gardella C. (2014). Herpes simplex virus infection during pregnancy. Obstet Gynecol Clin North Am.
232 Stray-Pedersen B. (1990). Acyclovir in late pregnancy to prevent neonatal herpes simplex. Lancet.
233 Summerton J, Riedesel M, Laeyendecker O, et al. (2007). Effect of sexually transmitted disease (STD) coinfections on performance of three commercially available immunosorbent assays used for detection of herpes simplex virus type 2-specific antibody in men attending Baltimore, Maryland, STD clinics. Clin Vaccine Immunol.
234 Tanton C, Weiss HA, LeGoff J, et al. (2011). Patterns of herpes simplex virus shedding over 1 month and the impact of acyclovir and HIV in HSV-2-seropositive women in Tanzania. Sex Transm Infect.
235 Tarchini G. (2010). Asymptomatic herpes simplex virus type 2 shedding-potential pitfalls of broader testing and aggressive suppression. J Infect Dis.
236 Theng CT, Sen PR, Chio TW, et al. (2006). Seroprevalence of herpes simplex virus-1 and -2 in attendees of a sexually transmitted infection clinic in Singapore. Sex Health.
237 Thin RN, Nabarro JM, Parker JD, et al. (1983). Topical acyclovir in the treatment of initial genital herpes. Br J Vener Dis.
238 Thomas D, Michou V, Tegos V, et al. (2004). The effect of valacyclovir treatment on natural killer cells of infertile women. Am J Reprod Immunol.
239 Thung SF, Grobman WA. (2005). The cost-effectiveness of routine antenatal screening for maternal herpes simplex virus-1 and -2 antibodies (Structured abstract). Am J Obstet Gynecol.
240 Tita AT, Grobman WA, Rouse DJ. (2006). Antenatal herpes serologic screening: an appraisal of the evidence. Obstet Gynecol.
241 Tronstein E, Johnston C, Huang ML, et al. (2011). Genital shedding of herpes simplex virus among symptomatic and asymptomatic persons with HSV-2 infection. JAMA.
242 Tuite AR, McCabe CJ, Ku J, et al. (2011). Projected cost-savings with herpes simplex virus screening in pregnancy: towards a new screening paradigm (Structured abstract). Sex Transm Infect.
243 Van Berkel C. (2000). A psychoeducational program increased knowledge and decreased sexual risk behaviors in young adults with genital herpes. West J Med.
244 Verano L, Michalski FJ. (1995). Comparison of a direct antigen enzyme immunoassay, Herpchek, with cell culture for detection of herpes simplex virus from clinical specimens. J Clin Microbiol.
245 Vial P, Torres-Pereyra J, Stagno S, et al. (1986). Serologic screening for cytomegalovirus, rubella virus, herpes simplex virus, hepatitis B virus, and Toxoplasma gondii in two urban populations of pregnant women in Chile. Bull Pan Am Health Organ.
246 Vonau B, Low-Beer N, Barton SE, et al. (1997). Antenatal serum screening for genital herpes: a study of knowledge and attitudes of women at a central London hospital. Br J Obstet Gynaecol.
247 Wald A. (2004). Herpes simplex virus type 2 transmission: risk factors and virus shedding. Herpes.
248 Wald A, Ashley-Morrow R. (2002). Serological testing for herpes simplex virus (HSV)-1 and HSV-2 infection. Clin Infect Dis.
249 Wald A, Langenberg AG, Krantz E, et al. (2005). The relationship between condom use and herpes simplex virus acquisition. Ann Intern Med.
250 Wald A, Langenberg AGM, Link K, et al. (2001). Effect of condoms on reducing the transmission of herpes simplex virus type 2 from men to women. J Am Med Assoc.
251 Wald A, Selke S, Warren T, et al. (2006). Comparative efficacy of famciclovir and valacyclovir for suppression of recurrent genital herpes and viral shedding. Sex Transm Dis.
252 Wald A, Zeh J, Barnum G, et al. (1996). Suppression of subclinical shedding of herpes simplex virus type 2 with acyclovir. Ann Intern Med.
253 Wald A, Zeh J, Selke S, et al. (2002). Genital shedding of herpes simplex virus among men. J Infect Dis.
254 Wald A, Zeh J, Selke S, et al. (2000). Reactivation of genital herpes simplex virus type 2 infection in asymptomatic seropositive persons. N Engl J Med.
255 Warford AL, Levy RA, Rekrut KA, et al. (1986). Herpes simplex virus testing of an obstetric population with an antigen enzyme-linked immunosorbent assay. Am J Obstet Gynecol.
256 Warren T. (2004). Importance and practicalities of patient counseling in the prevention and management of genital herpes.
257 Watson-Jones D, Weiss HA, Rusizoka M, et al. (2008). Effect of herpes simplex suppression on incidence of HIV among women in Tanzania. N Engl J Med.
258 Watts DH, Brown ZA, Money D, et al. (2003). A double-blind, randomized, placebo-controlled trial of acyclovir in late pregnancy for the reduction of herpes simplex virus shedding and cesarean delivery. Am J Obstet Gynecol.
259 Weinberg A, Canto CL, Pannuti CS, et al. (1993). Herpes simplex virus type 2 infection in pregnancy: asymptomatic viral excretion at delivery and seroepidemiologic survey of two socioeconomically distinct populations in Sao Paulo, Brazil. Rev Inst Med Trop Sao Paulo.
260 Whatley JD, Thin RN. (1991). Episodic acyclovir therapy to abort recurrent attacks of genital herpes simplex infection. J Antimicrob Chemother.
261 Whitley R, Arvin A, Prober C, et al. (1991). A controlled trial comparing vidarabine with acyclovir in neonatal herpes simplex virus infection. Infectious Diseases Collaborative Antiviral Study Group. N Engl J Med.
262 Whitley RJ, Nahmias AJ, Soong SJ, et al. (1980). Vidarabine therapy of neonatal herpes simplex virus infection. Pediatrics.
263 Whittington WL, Celum CL, Cent A, et al. (2001). Use of a glycoprotein G-based type-specific assay to detect antibodies to herpes simplex virus type 2 among persons attending sexually transmitted disease clinics. Sex Transm Dis.
264 Wilkinson D, Barton S, Chard S, et al. (2000). The psychological consequences in patient undergoing a POCKit HSV-2 test. Int J STD AIDS.
265 Williams JR, Jordan JC, Davis EA, et al. (2007). Suppressive valacyclovir therapy: impact on the population spread of HSV-2 infection. Sex Transm Dis.
266 Witwer M. (1989). Serologic testing reveals higher than expected herpes virus infection rates in U.S. population. Fam Plann Perspect.
267 Wolff MH, Schmitt J, Rahaus M, et al. (2002). Clinical and subclinical reactivation of genital herpes virus. Intervirology.
268 Wutzler P, Doerr HW, Farber I, et al. (2000). Seroprevalence of herpes simplex virus type 1 and type 2 in selected German populations-relevance for the incidence of genital herpes. J Med Virol.
269 Yin YP, Wu Z, Lin C, et al. (2008). Syndromic and laboratory diagnosis of sexually transmitted infection: A comparative study in China. Int J STD AIDS.
270 Youngkin EQ, Henry JK, Gracely-Kilgore K. (1998). Women with HSV and HPV: a strategy to increase self-esteem. Clin Excell Nurse Pract.
271 Zimet GD, Rosenthal SL, Fortenberry JD, et al. (2004). Factors predicting the acceptance of herpes simplex virus type 2 antibody testing among adolescents and young adults. Sex Transm Dis.