# Appendix B Detailed Methods

## Appendix B1 Detailed Methods

### Search Strategies

#### PubMed intervention/treatment search, 4/30/15

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search "Herpes Genitalis"[Mesh] OR "genital herpes simplex" OR "Herpesvirus 2, Human"[Mesh] OR "HSV-2"[All Fields] OR HSV2[All Fields] OR Simplexvirus[Mesh] OR "genital herpes"[tiab] OR “Herpes Simplex”[Mesh:NoExp] | 36678 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search screen* | 557339 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (("Polymerase Chain Reaction/methods"[Mesh] OR "Immunoenzyme Techniques"[Mesh] OR "Immunoassay/methods"[Mesh] OR "Antibodies, Viral/analysis"[Mesh] OR "Antibodies, Viral/blood"[Mesh] OR "Enzyme-Linked Immunosorbent Assay/methods"[Mesh] OR "Viral Envelope Proteins/diagnostic use"[Majr] OR "Viral Envelope Proteins/analysis"[Majr] OR "Viral Envelope Proteins/immunology"[Majr] OR "Serologic Tests/methods"[Majr] OR "Serologic Tests/standards"[Majr] OR "DNA, Viral/analysis"[Majr] OR "Reagent Kits, Diagnostic"[Majr])) | 351976 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and (#2 or #3)) | 5545 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR "controlled clinical trial"[publication type] OR "Randomized Controlled Trial"[Publication Type] OR "Single-Blind Method"[MeSH] OR "Double-Blind Method"[MeSH] OR "Random Allocation"[MeSH]) | 598487 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#4 and #5) | 104 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #3) | 4689 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #3) Filters: Systematic Reviews | 16 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 and #5) | 85 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ("Case-Control Studies"[MeSH] OR "Cohort Studies"[MeSH] OR "comparative study"[pt] OR "Epidemiologic Studies"[MeSH] OR "Cross-Over Studies"[MeSH] OR "Follow-Up Studies"[MeSH] OR “observational study” OR “observational studies” OR "cohort"[tw] OR "case control"[tw]) | 3274355 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 and #10) | 1335 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 or #9 or #11) | 1391 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#12 not #6) | 1306 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ("Herpes Simplex/diagnosis"[Majr] OR "Herpes Simplex/virology"[Mesh] OR "Herpesvirus 2, Human/immunology"[Majr] OR "Herpes Genitalis/diagnosis"[Majr] OR "Simplexvirus/immunology"[Majr] OR "Herpes Genitalis/virology"[Majr]) | 8482 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ("Herpes Simplex/diagnosis"[Majr] OR "Herpes Simplex/virology"[Mesh] OR "Herpesvirus 2, Human/immunology"[Majr] OR "Herpes Genitalis/diagnosis"[Majr] OR "Simplexvirus/immunology"[Majr] OR "Herpes Genitalis/virology"[Majr]) Filters: Systematic Reviews | 50 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#14 and #5) | 147 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#14 and #10) | 1453 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#15 or #16 or #17) | 1577 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#12 or #18) | 2262 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#19 not #6) | 2176 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((psychosocial AND test*) OR (emotional AND test*) OR (emotional AND impact) OR (diagnosis AND psychosocial) OR (screen* AND psychosocial) OR (test* AND impact) OR "Social Stigma"[Mesh] OR stigma[tiab] OR labeling[tiab] OR "Anxiety/etiology"[Majr] OR Stereotyping[Mesh]) | 269132 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #21) | 379 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #21) Filters: Publication date from 2010/01/01^a^ | 77 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ("Virus Shedding"[Mesh] OR "viral shedding"[All Fields] OR "Disease Transmission, Infectious"[Mesh]) | 54661 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#25 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #24) | 820 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)
#26 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#25 and #5) | 125 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=26)
#27 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((acyclovir OR famciclovir OR valacyclovir) OR “Antiviral Agents”[Mesh:NoExp] OR “Antiviral Agents ”[Pharmacological Action] OR “suppressive treatment”[Title/Abstract] OR “suppressive therapy”[Title/Abstract] OR suppressive agent*[Title/Abstract] OR suppressive drug*[Title/Abstract] OR antiviral drug*[Title/Abstract] OR therapy[Title/Abstract] OR “antiviral treatment”[Title/Abstract] OR antiviral agent*[Title/Abstract]) | 1549825 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=27)
#28 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #27) | 12155 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=28)
#29 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ("Patient Education as Topic"[Mesh] OR "Patient Education Handout" [Publication Type] OR "patient education"[All Fields] OR Counseling[Mesh] OR "Secondary Prevention"[Mesh] OR "Disclosure"[Mesh] OR disclosure[All Fields] OR "Contact Tracing"[Mesh] OR "partner notification"[All Fields]) | 169152 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#30 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #29) | 322 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=30)
#31 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ("Contraception, Barrier"[Mesh] OR "barrier protection" OR "Condoms"[Mesh] OR "Condoms, Female"[Mesh] OR condom*) | 18461 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=31)
#32 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #31) | 302 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=32)
#33 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#28 or #30 or #32) | 12555 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=33)
#34 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#33 and #5) | 589 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=34)
#35 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#6 or #8 or #12 or #20 or #23 or #26 or #34) | 2821 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=35)
#36 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#6 or #8 or #12 or #20 or #23 or #26 or #34) Filters: Humans | 2474 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=36)
#37 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#6 or #8 or #12 or #20 or #23 or #26 or #34) Filters: Humans; Adolescent: 13–18 years | 693 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=37)
#38 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#6 or #8 or #12 or #20 or #23 or #26 or #34) Filters: Humans; Adolescent: 13–18 years; Adult: 19+ years | 1523 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=38)
#39 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ("Pregnant Women"[Mesh] OR "Pregnancy"[Mesh] OR "Pregnancy Complications, Infectious"[Mesh:NoExp] OR "Pregnancy Outcome"[Mesh]) | 724894 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=39)
#40 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#35 and #39) | 215 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=40)
#41 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#40 not #38) | 77 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=41)
#42 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#38 or #41) | 1600 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=42)
#43 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#38 or #41) Filters: English | 1461 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=43)
#44 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#42 not #43) | 139 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=44)

a Publication date limits only apply to systematic review publications for KQ3.”

#### PubMed intervention/treatment search, 3/31/16

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ("Herpes Genitalis"[Mesh] OR "genital herpes simplex" OR "Herpesvirus 2, Human"[Mesh] OR "HSV-2"[All Fields] OR HSV2[All Fields] OR Simplexvirus[Mesh] OR "genital herpes"[tiab] OR “Herpes Simplex”[Mesh:NoExp]) | 37919 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search screen* | 598637 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((("Polymerase Chain Reaction/methods"[Mesh] OR "Immunoenzyme Techniques"[Mesh] OR "Immunoassay/methods"[Mesh] OR "Antibodies, Viral/analysis"[Mesh] OR "Antibodies, Viral/blood"[Mesh] OR "Enzyme-Linked Immunosorbent Assay/methods"[Mesh] OR "Viral Envelope Proteins/diagnostic use"[Majr] OR "Viral Envelope Proteins/analysis"[Majr] OR "Viral Envelope Proteins/immunology"[Majr] OR "Serologic Tests/methods"[Majr] OR "Serologic Tests/standards"[Majr] OR "DNA, Viral/analysis"[Majr] OR "Reagent Kits, Diagnostic"[Majr]))) | 362549 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and (#2 or #3)) | 5650 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR "controlled clinical trial"[publication type] OR "Randomized Controlled Trial"[Publication Type] OR "Single-Blind Method"[MeSH] OR "Double-Blind Method"[MeSH] OR "Random Allocation"[MeSH])) | 632093 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#4 and #5) | 108 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #3) | 4758 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #3) Sort by: PublicationDate Filters: Systematic Reviews | 17 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 and #5) | 89 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (("Case-Control Studies"[MeSH] OR "Cohort Studies"[MeSH] OR "comparative study"[pt] OR "Epidemiologic Studies"[MeSH] OR "Cross-Over Studies"[MeSH] OR "Follow-Up Studies"[MeSH] OR “observational study” OR “observational studies” OR "cohort"[tw] OR "case control"[tw])) | 3442776 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 and #10) | 1361 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 or #9 or #11) | 1419 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#12 not #6) | 1330 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (("Herpes Simplex/diagnosis"[Majr] OR "Herpes Simplex/virology"[Mesh] OR "Herpesvirus 2, Human/immunology"[Majr] OR "Herpes Genitalis/diagnosis"[Majr] OR "Simplexvirus/immunology"[Majr] OR "Herpes Genitalis/virology"[Majr])) | 8703 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (("Herpes Simplex/diagnosis"[Majr] OR "Herpes Simplex/virology"[Mesh] OR "Herpesvirus 2, Human/immunology"[Majr] OR "Herpes Genitalis/diagnosis"[Majr] OR "Simplexvirus/immunology"[Majr] OR "Herpes Genitalis/virology"[Majr])) Sort by: PublicationDate Filters: Systematic Reviews | 51 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#14 and #5) | 151 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#14 and #10) | 1490 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#15 or #16 or #17) | 1615 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#12 or #18) | 2313 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#19 not #6) | 2223 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((psychosocial AND test*) OR (emotional AND test*) OR (emotional AND impact) OR (diagnosis AND psychosocial) OR (screen* AND psychosocial) OR (test* AND impact) OR "Social Stigma"[Mesh] OR stigma[tiab] OR labeling[tiab] OR "Anxiety/etiology"[Majr] OR Stereotyping[Mesh])) | 289684 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #21) | 402 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #21) Sort by: PublicationDate Filters: Publication date from 2015/02/28 | 19 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (("Virus Shedding"[Mesh] OR "viral shedding"[All Fields] OR "Disease Transmission, Infectious"[Mesh])) | 57328 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#25 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #24) | 851 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)
#26 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#25 and #5) | 128 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=26)
#27 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((acyclovir OR famciclovir OR valacyclovir) OR “Antiviral Agents”[Mesh:NoExp] OR “Antiviral Agents ”[Pharmacological Action] OR “suppressive treatment”[Title/Abstract] OR “suppressive therapy”[Title/Abstract] OR suppressive agent*[Title/Abstract] OR suppressive drug*[Title/Abstract] OR antiviral drug*[Title/Abstract] OR therapy[Title/Abstract] OR “antiviral treatment”[Title/Abstract] OR antiviral agent*[Title/Abstract])) | 1757360 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=27)
#28 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #27) | 12495 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=28)
#29 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (("Patient Education as Topic"[Mesh] OR "Patient Education Handout" [Publication Type] OR "patient education"[All Fields] OR Counseling[Mesh] OR "Secondary Prevention"[Mesh] OR "Disclosure"[Mesh] OR disclosure[All Fields] OR "Contact Tracing"[Mesh] OR "partner notification"[All Fields])) | 177556 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#30 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #29) | 327 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=30)
#31 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (("Contraception, Barrier"[Mesh] OR "barrier protection" OR "Condoms"[Mesh] OR "Condoms, Female"[Mesh] OR condom*)) | 19583 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=31)
#32 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #31) | 321 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=32)
#33 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#28 or #30 or #32) | 12917 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=33)
#34 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#33 and #5) | 606 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=34)
#35 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#6 or #8 or #12 or #20 or #23 or #26 or #34) | 2836 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=35)
#36 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#6 or #8 or #12 or #20 or #23 or #26 or #34) Sort by: PublicationDate Filters: Humans | 2505 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=36)
#37 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#6 or #8 or #12 or #20 or #23 or #26 or #34) Sort by: PublicationDate Filters: Humans; Adolescent: 13–18 years | 702 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=37)
#38 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#6 or #8 or #12 or #20 or #23 or #26 or #34) Sort by: PublicationDate Filters: Humans; Adolescent: 13–18 years; Adult: 19+ years | 1553 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=38)
#39 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (("Pregnant Women"[Mesh] OR "Pregnancy"[Mesh] OR "Pregnancy Complications, Infectious"[Mesh:NoExp] OR "Pregnancy Outcome"[Mesh])) | 782129 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=39)
#40 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#35 and #39) | 218 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=40)
#41 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#40 not #38) | 79 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=41)
#42 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#38 or #41) | 1632 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=42)
#43 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#38 or #41) Sort by: PublicationDate Filters: English | 1494 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=43)
#44 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#42 not #43) | 138 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=44)
#45 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“retraction”[All Fields] OR “Retracted Publication”[pt] OR Duplicate Publication [PT] OR Erratum[All Fields]) | 42552 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=45)
#46 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#43 and #45) | 0 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=46)
#47 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#44 and #45) | 0 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=47)
#48 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#38 or #41) Sort by: PublicationDate Filters: Publication date from 2015/02/28; English | 35 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=48)
#49 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#42 not #43) Sort by: PublicationDate Filters: Publication date from 2015/02/28 | 0 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=49)

#### Cochrane search, 4-30-15

ID | Search | Hits
#1 | [mh "Herpes Genitalis"] or "genital herpes simplex" or [mh "Herpesvirus 2, Human"] or "HSV-2" or HSV2 or [mh Simplexvirus] or "genital herpes" or [mh ^"Herpes Simplex"] | 875
#2 | screen* | 31885
#3 | [mh "Polymerase Chain Reaction"/MT] or [mh "Immunoenzyme Techniques"] or [mh Immunoassay/MT] or [mh "Antibodies, Viral"/AN] or [mh "Antibodies, Viral"/BL] or [mh "Enzyme-Linked Immunosorbent Assay"/MT] or [mh "Viral Envelope Proteins"/DU] or [mh "Viral Envelope Proteins"/AN] or [mh "Viral Envelope Proteins" [mj]/IM] or [mh "Serologic Tests" [mj]/MT] or [mh "Serologic Tests" [mj]/ST] or [mh "DNA, Viral" [mj]/AN] or [mh "Reagent Kits, Diagnostic" [mj]] | 5172
#4 | #1 and (#2 or #3) | 126
#5 | [mh "Herpes Simplex"/DI] or [mh "Herpes Simplex"/VI] or [mh "Herpesvirus 2, Human"/IM] or [mh "Herpes Genitalis"/DI] or [mh Simplexvirus/IM] or [mh "Herpes Genitalis"/VI] | 158
#6 | (psychosocial and test*) or (emotional and test*) or (emotional and impact) or (diagnosis and psychosocial) or (screen* and psychosocial) or (test* and impact) or [mh "Social Stigma"] or stigma or labeling or [mh Anxiety/ET] or [mh Stereotyping] | 27129
#7 | #1 and #6 | 79
#8 | #1 and #6 Publication Year from 2010 to 2015 ^a^ | 56
#9 | [mh "Virus Shedding"] or "viral shedding" or [mh "Disease Transmission, Infectious"] | 1114
#10 | #1 and #9 | 134
#11 | #1 and #9 in Trials | 120
#12 | (acyclovir or famciclovir or valacyclovir) or [mh ^"Antiviral Agents"] or "Antiviral Agents" or "antiviral agent" or "suppressive treatment" or "suppressive therapy" or "suppressive agent" or "suppressive agents" or "suppressive drug" or "suppressive drugs" or "antiviral drug" or "antiviral drugs" or therapy:ti or therapy:ab or "antiviral treatment" | 146699
#13 | #1 and #12 | 526
#14 | [mh "Patient Education as Topic"] or [mh "Patient Education Handout"] or "patient education" or [mh Counseling] or [mh "Secondary Prevention"] or [mh Disclosure] or disclosure or [mh "Contact Tracing"] or "partner notification" | 14041
#15 | #1 and #14 | 23
#16 | [mh "Contraception, Barrier"] or "barrier protection" or [mh Condoms] or [mh "Condoms, Female"] or condom* | 1486
#17 | #1 and #16 | 52
#18 | #13 or #15 or #17 | 577
#19 | #13 or #15 or #17 in Trials | 512
#20 | #4 or #5 or #8 or #11 or #19 | 663
#21 | Adult*:ti,ab,kw or adolescen*:ti,ab,kw or teen:ti,ab,kw or teens:ti,ab,kw or teenage*:ti,ab,kw | 378104
#22 | #20 and #21 | 432
#23 | [mh "Pregnant Women"] or [mh Pregnancy] or [mh ^"Pregnancy Complications, Infectious"] or [mh "Pregnancy Outcome"] or pregnan* | 30774
#24 | #20 and #23 | 86
#25 | #22 or #24 | 476

a Publication date limits only apply to systematic review publications for KQ3

#### Cochrane search, 3-31-16

ID | Search | Hits
#1 | [mh "Herpes Genitalis"] or "genital herpes simplex" or [mh "Herpesvirus 2, Human"] or "HSV-2" or HSV2 or [mh Simplexvirus] or "genital herpes" or [mh ^"Herpes Simplex"] | 921
#2 | screen* | 36090
#3 | [mh "Polymerase Chain Reaction"/MT] or [mh "Immunoenzyme Techniques"] or [mh Immunoassay/MT] or [mh "Antibodies, Viral"/AN] or [mh "Antibodies, Viral"/BL] or [mh "Enzyme-Linked Immunosorbent Assay"/MT] or [mh "Viral Envelope Proteins"/DU] or [mh "Viral Envelope Proteins"/AN] or [mh "Viral Envelope Proteins" [mj]/IM] or [mh "Serologic Tests" [mj]/MT] or [mh "Serologic Tests" [mj]/ST] or [mh "DNA, Viral" [mj]/AN] or [mh "Reagent Kits, Diagnostic" [mj]] | 5813
#4 | #1 and (#2 or #3) | 140
#5 | [mh "Herpes Simplex"/DI] or [mh "Herpes Simplex"/VI] or [mh "Herpesvirus 2, Human"/IM] or [mh "Herpes Genitalis"/DI] or [mh Simplexvirus/IM] or [mh "Herpes Genitalis"/VI] | 167
#6 | (psychosocial and test*) or (emotional and test*) or (emotional and impact) or (diagnosis and psychosocial) or (screen* and psychosocial) or (test* and impact) or [mh "Social Stigma"] or stigma or labeling or [mh Anxiety/ET] or [mh Stereotyping] | 31245
#7 | #1 and #6 | 88
#8 | #1 and #6 Publication Year from 2015 to 2016 | 14
#9 | [mh "Virus Shedding"] or "viral shedding" or [mh "Disease Transmission, Infectious"] | 1207
#10 | #1 and #9 | 138
#11 | #1 and #9 in Trials | 123
#12 | (acyclovir or famciclovir or valacyclovir) or [mh ^"Antiviral Agents"] or "Antiviral Agents" or "antiviral agent" or "suppressive treatment" or "suppressive therapy" or "suppressive agent" or "suppressive agents" or "suppressive drug" or "suppressive drugs" or "antiviral drug" or "antiviral drugs" or therapy:ti or therapy:ab or "antiviral treatment" | 163346
#13 | #1 and #12 | 549
#14 | [mh "Patient Education as Topic"] or [mh "Patient Education Handout"] or "patient education" or [mh Counseling] or [mh "Secondary Prevention"] or [mh Disclosure] or disclosure or [mh "Contact Tracing"] or "partner notification" | 17887
#15 | #1 and #14 | 46
#16 | [mh "Contraception, Barrier"] or "barrier protection" or [mh Condoms] or [mh "Condoms, Female"] or condom* | 1613
#17 | #1 and #16 | 54
#18 | #13 or #15 or #17 | 609
#19 | #13 or #15 or #17 in Trials | 543
#20 | #4 or #5 or #8 or #11 or #19 | 688
#21 | Adult*:ti,ab,kw or adolescen*:ti,ab,kw or teen:ti,ab,kw or teens:ti,ab,kw or teenage*:ti,ab,kw | 420923
#22 | #20 and #21 | 457
#23 | [mh "Pregnant Women"] or [mh Pregnancy] or [mh ^"Pregnancy Complications, Infectious"] or [mh "Pregnancy Outcome"] or pregnan* | 33976
#24 | #20 and #23 | 79
#25 | #22 or #24 | 493
#26 | #22 or #24 Publication Year from 2015 to 2016 | 18

#### EMBASE Intervention Search, 5-1-15

Query | Results | No.
#1 | 'genital herpes'/exp OR 'genital herpes simplex' OR 'herpes simplex virus 2'/exp OR 'hsv-2' OR 'simplexvirus'/exp OR 'genital herpes' OR 'herpes simplex'/de | 56,735
#2 | Screen* | 879,538
#3 | 'polymerase chain reaction'/exp OR 'enzyme immunoassay'/exp OR 'immunoassay'/exp OR 'virus antibody'/exp OR 'enzyme linked immunosorbent assay'/exp OR 'virus envelope protein'/exp OR 'serology'/exp/mj OR 'virus dna'/exp OR 'diagnostic kit'/exp | 813,744
#4 | #1 AND (#2 OR #3) | 12,548
#5 | 'randomized controlled trial'/exp OR 'single blind procedure'/exp OR 'double blind procedure'/exp OR 'random allocation'/exp OR 'controlled trial'/exp OR 'control trial' OR ('control':ab,ti OR 'controlled':ab,ti AND 'trial':ab,ti) | 4,870,361
#6 | #4 AND #5 | 3,317
#7 | #1 AND #3 | 10,322
#8 | #7 AND 'systematic review'/exp | 24
#9 | #7 AND #5 | 2,751
#10 | 'case control study'/exp OR 'cohort analysis'/exp OR 'epidemiological study' OR 'cross-sectional study'/exp OR 'organizational case study' OR 'crossover procedure'/exp OR 'seroepidemiologic study' OR 'epidemiology'/exp OR 'multicenter study'/exp OR 'multicenter study (topic)'/exp OR 'evaluation research'/exp | 2,513,760
#11 | #7 AND #10 | 1,682
#12 | #8 OR #9 OR #11 | 3,832
#13 | #12 NOT #6 | 1,081
#14 | 'herpes simplex'/exp/mj/dm_di OR ('herpes simplex'/exp/mj AND virology) AND 'herpes simplex virus 2'/exp/mj AND immunology OR 'genital herpes'/exp/mj/dm_di OR ('simplexvirus'/exp/mj AND immunology) OR ('genital herpes'/exp/mj AND virology) | 3,962
#15 | #14 AND 'systematic review'/exp | 5
#16 | #14 AND #5 | 1,171
#17 | #14 AND #10 | 367
#18 | #15 OR #16 OR #17 | 1,420
#19 | #12 OR #18 | 4,827
#20 | #19 NOT #6 | 2,054
#21 | psychosocial AND test* OR (emotional AND test*) OR (emotional AND impact) OR (diagnosis AND psychosocial) OR (screen* AND psychosocial) OR (test* AND impact) OR 'social stigma'/exp OR 'stigma':ab,ti OR 'labeling':ab,ti OR 'anxiety'/exp/mj/dm_et OR 'stereotyping'/exp | 363,258
#22 | #1 AND #21 | 665
#23 | #22 AND [2010–2015]/py 1 | 248
#24 | 'virus shedding'/exp OR 'viral shedding' OR 'disease transmission'/exp | 185,507
#25 | #1 AND #24 | 3,489
#26 | #25 AND #5 | 786
#27 | acyclovir OR famciclovir OR valacyclovir OR 'antivirus agent'/de OR 'suppressive treatment':ab,ti OR 'suppressive therapy':ab,ti OR suppressive AND agent*:ab,ti OR suppressive AND drug*:ab,ti OR antiviral AND drug*:ab,ti OR therapy:ab,ti OR 'antiviral treatment':ab,ti OR antiviral AND agent*:ab,ti | 182,851
#28 | #1 AND #27 | 2,624
#29 | 'patient education'/exp OR 'patient education' OR 'counseling'/exp OR 'secondary prevention'/exp OR 'interpersonal communication'/exp OR disclosure OR 'contact examination'/exp OR 'partner notification' | 649,474
#30 | #1 AND #29 | 871
#31 | 'barrier contraception'/exp OR 'barrier protection':ab,ti OR 'condom'/exp OR 'female condom'/exp OR condom* | 22,987
#32 | #1 AND #31 | 670
#33 | #28 OR #30 OR #32 | 4,014
#34 | #33 AND #5 | 1,000
#35 | #6 OR #8 OR #12 OR #20 OR #23 OR #26 OR #34 | 6,651
#36 | #6 OR #8 OR #12 OR #20 OR #23 OR #26 OR #34 AND [humans]/lim | 4,574
#37 | #36 AND ([adolescent]/lim OR [adult]/lim) | 2,008
#38 | 'pregnant woman'/exp OR 'pregnancy'/exp OR 'pregnancy complication'/de OR 'pregnancy outcome'/exp | 657,903
#39 | #35 AND #38 | 305
#40 | #39 NOT #37 | 165
#41 | #37 OR #40 | 2,173
#42 | #41 AND [medline]/lim | 1,871
#43 | #41 NOT #42 | 302
#44 | #37 OR #43 | 2,061
#45 | #44 AND [english]/lim | 1,974
#46 | #44 NOT #45 | 87

1 Publication date limits only apply to systematic review publications for KQ3

#### EMBASE Intervention Search, 3-31-16

Query | Results | No.
#1 | 'genital herpes simplex'/exp OR 'genital herpes simplex' OR 'herpes simplex virus 2'/exp OR 'herpes simplex virus 2' OR 'hsv-2'/exp OR 'hsv-2' OR 'simplexvirus'/exp OR 'simplexvirus' OR 'genital herpes'/exp OR 'genital herpes' OR 'herpes simplex'/exp OR 'herpes simplex' | 69,804
#2 | screen* | 952,275
#3 | 'polymerase chain reaction'/exp OR 'enzyme immunoassay'/exp OR 'immunoassay'/exp OR 'virus antibody'/exp OR 'enzyme linked immunosorbent assay'/exp OR 'virus envelope protein'/exp OR 'serology'/exp/mj OR 'virus dna'/exp OR 'diagnostic kit'/exp | 863,767
#4 | #1 AND (#2 OR #3) | 14,647
#5 | 'randomized controlled trial'/exp OR 'single blind procedure'/exp OR 'double blind procedure'/exp OR 'random allocation'/exp OR 'controlled trial'/exp OR 'control trial' OR ('control':ab,ti OR 'controlled':ab,ti AND 'trial':ab,ti) | 5,222,268
#6 | #4 AND #5 | 3,855
#7 | #1 AND #3 | 12,028
#8 | #7 AND 'systematic review'/exp | 25
#9 | #7 AND #5 | 3,184
#10 | 'case control study'/exp OR 'cohort analysis'/exp OR 'epidemiological study' OR 'cross-sectional study'/exp OR 'organizational case study' OR 'crossover procedure'/exp OR 'seroepidemiologic study' OR 'epidemiology'/exp OR 'multicenter study'/exp OR 'multicenter study (topic)'/exp OR 'evaluation research'/exp | 2,756,145
#11 | #7 AND #10 | 1,929
#12 | #8 OR #9 OR #11 | 4,431
#13 | #12 NOT #6 | 1,247
#14 | 'herpes simplex'/exp/mj/dm_di OR ('herpes simplex'/exp/mj AND virology) AND 'herpes simplex virus 2'/exp/mj AND immunology OR 'genital herpes'/exp/mj/dm_di OR ('simplexvirus'/exp/mj AND immunology) OR ('genital herpes'/exp/mj AND virology) | 4,062
#15 | #14 AND 'systematic review'/exp | 5
#16 | #14 AND #5 | 1,237
#17 | #14 AND #10 | 373
#18 | #15 OR #16 OR #17 | 1,490
#19 | #12 OR #18 | 5,477
#20 | #19 NOT #6 | 2,269
#21 | psychosocial AND test* OR (emotional AND test*) OR (emotional AND impact) OR (diagnosis AND psychosocial) OR (screen* AND psychosocial) OR (test* AND impact) OR 'social stigma'/exp OR 'stigma':ab,ti OR 'labeling':ab,ti OR 'anxiety'/exp/mj/dm_et OR 'stereotyping'/exp | 400,515
#22 | #1 AND #21 | 823
#23 | #1 AND #21 AND [2015–2016]/py | 62
#24 | 'virus shedding'/exp OR 'viral shedding' OR 'disease transmission'/exp | 194,375
#25 | #1 AND #24 | 3,819
#26 | #25 AND #5 | 871
#27 | acyclovir OR famciclovir OR valacyclovir OR 'antivirus agent'/de OR 'suppressive treatment':ab,ti OR 'suppressive therapy':ab,ti OR suppressive AND agent*:ab,ti OR suppressive AND drug*:ab,ti OR antiviral AND drug*:ab,ti OR therapy:ab,ti OR 'antiviral treatment':ab,ti OR antiviral AND agent*:ab,ti | 197,974
#28 | #1 AND #27 | 3,176
#29 | 'patient education'/exp OR 'patient education' OR 'counseling'/exp OR 'secondary prevention'/exp OR 'interpersonal communication'/exp OR disclosure OR 'contact examination'/exp OR 'partner notification' | 699,499
#30 | #1 AND #29 | 1,081
#31 | 'barrier contraception'/exp OR 'barrier protection':ab,ti OR 'condom'/exp OR 'female condom'/exp OR condom* | 24,747
#32 | #1 AND #31 | 757
#33 | #28 OR #30 OR #32 | 4,843
#34 | #33 AND #5 | 1,194
#35 | #6 OR #8 OR #12 OR #20 OR #23 OR #26 OR #34 | 7,457
#36 | #6 OR #8 OR #12 OR #20 OR #23 OR #26 OR #34 AND [humans]/lim | 5,187
#37 | #36 AND ([adolescent]/lim OR [adult]/lim) | 2,292
#38 | 'pregnant woman'/exp OR 'pregnancy'/exp OR 'pregnancy complication'/de OR 'pregnancy outcome'/exp | 694,355
#39 | #35 AND #38 | 323
#40 | #39 NOT #37 | 175
#41 | #37 OR #40 | 2,467
#42 | #41 AND [medline]/lim | 2,071
#43 | #41 NOT #42 | 396
#44 | #37 OR #43 | 2,346
#45 | #44 AND [english]/lim | 2,248
#46 | #44 NOT #45 | 98
#47 | #45 AND [2015–2016]/py | 185
#48 | #46 AND [2015–2016]/py | 0

#### Grey Literature Searches, 5/6/15

[underlined: ClinicalTrials.gov] – searched 5/6/15 with only herpes terms in Advanced Search, no other limits. Search terms: “Herpes Genitalis” or “genital herpes simplex” or “Herpesvirus 2, Human” or “HSV-2” or HSV2 or Simplexvirus or “genital herpes” or “Herpes Simplex” (Yield 20)

[underlined: WHO ICTRP] searched 6/9/15 – Herpes search string as above for ClinicalTrials.gov, searched in the Condition box, and limited to ALL studies (459 records for 357 trials found). Search terms: Herpes Genitalis OR genital herpes simplex OR Herpesvirus 2, Human OR HSV-2 OR HSV2 OR Simplexvirus OR genital herpes OR Herpes Simplex

#### Grey Literature Searches, 3/31/16

[underlined: Clinicaltrials.gov] – searched on 3/31/16 with only herpes terms in Advanced Search, and last updated from 2/28/2015. 1 result found.

[underlined: WHO ICTRP] searched on 3/31/16 with the herpes terms in the Condition box, and limited to all studies.

23 results found. Search terms: Herpes Genitalis OR genital herpes simplex OR Herpesvirus 2, Human OR HSV-2 OR HSV2 OR Simplexvirus OR genital herpes OR Herpes Simplex

## Appendix B2 Eligibility Criteria

| Include | Exclude
Populations | All KQs: Asymptomatic^*^ sexually active adults or adolescents with no clinical history of genital herpes^†^, including asymptomatic partners of persons with known genital herpes (i.e., discordant couples) KQs 1b, 3b, 5b, 6b: Asymptomatic pregnant women only KQ 2: Asymptomatic persons or those previously diagnosed with genital herpes | All KQs: Children (age <13 years); persons with HIV infection or other immunosuppressive disorders KQs 1, 3–7: Persons previously diagnosed with genital herpes or with current symptoms (e.g., genital ulcers)
Screening | KQs 1–3: FDA-approved serologic tests for HSV-2 or “paired testing” for HSV-1 and HSV-2^‡^ | KQs 2b, 3: Serologic tests for HSV-2 that are not commercially available or approved by the FDA; nonserologic tests indicated for the diagnosis of HSV in persons with genital lesions (e.g., cell culture or PCR-based testing); HSV serologic tests that are not type-specific
Interventions | KQs 4–6: FDA-approved oral antiviral medications (acyclovir, famciclovir, or valacyclovir) to prevent symptomatic episodes of genital herpes or reduce risk for transmission KQs 5, 6: Behavioral counseling interventions, including the following: patient education or counseling; partner notification; barrier protection (e.g., condoms); or combinations of these components KQ 5b: Behavioral counseling interventions for seronegative pregnant women that aim to prevent primary genital HSV infection during pregnancy | KQs 4–6: Vaccinations; non–FDA-approved pharmacotherapy KQs 5, 6: Routine periodic pelvic examinations to screen for gynecologic conditions (e.g., external inspection for genital ulcers)
Comparisons | KQ 1: Screened vs. nonscreened groups KQ 2: FDA-approved HSV-2 serologic tests vs. HSV Western blot KQs 3 a, b (psychosocial outcomes): Any (or no) comparator KQ 3b (Cesarean delivery rate): Screened vs. nonscreened groups KQs 4–6a: Oral antiviral medications vs. placebo KQ 6b: Oral antiviral medications vs. placebo or no intervention KQs 5, 6: Behavioral counseling interventions vs. attention controls or usual care (e.g., provision of a patient handout on genital herpes) KQ 7: Higher vs. lower rates (or frequency) of subclinical viral shedding (e.g., percentage of days of subclinical viral shedding) | KQs 1, 2, 4–7: No comparison; nonconcordant historical controls; comparative studies of various interventions (e.g., comparing two antiviral drugs or two different type-specific HSV-2 serologic tests)
Outcomes | KQs 1a, 5a, 7: Reduced rates of symptomatic genital herpes; reduced rates of genital herpes transmission measured by partner symptom recognition (or clinician diagnosis) or HSV seroconversion KQs 1b, 5b: Reduced rates of neonatal HSV infection; reduced rates of symptomatic genital herpes at delivery KQ 2: Sensitivity, specificity, positive predictive value, and negative predictive value KQ 3: Labeling, anxiety, or false-positive results leading to unnecessary treatment, partner discord, or distress or anxiety around the meaning of HSV-1 results when screening involves a “paired test” (HSV-1 and HSV-2 results reported together), or other psychosocial harms KQ 3b: Increased rates of Cesarean delivery (in women with no evidence of active genital lesions at the time of delivery) KQ 4: Reduced rates (or frequency) of subclinical HSV-2 viral shedding KQ 6: Treatment-related adverse events (e.g., adverse drug reactions related to antiviral medications); psychosocial harms related to counseling or behavioral interventions | All KQs: Cost-effectiveness or cost-related outcomes; transmission of other sexually transmitted infections (e.g., HIV) KQ 3: Acceptability of HSV serologic testing
Study designs | KQs 1, 4–6a: Randomized, controlled trials KQs 2, 3: Good-quality, recent (within 5 years) systematic reviews^§^; trials or observational studies published since the most recent review KQ 6b: Randomized, controlled trials and multi-institution antiviral medication pregnancy exposure registries KQ 7: Treatment studies included in KQs 4–6 reporting both change in HSV-2 viral shedding and change in a health outcome; prospective cohort studies that follow participants for at least 1 year | All other designs
Setting | Primary care outpatient settings (or similar settings that are applicable to primary care) | All other settings
Language | English | Languages other than English

* “Asymptomatic” refers to persons who have never had clinical symptoms of genital herpes (e.g., genital ulcers), not persons with genital herpes who have symptom-free periods between symptomatic recurrences.

† Eligible studies with mixed populations (e.g., studies that enroll a subset of participants who are seropositive for HSV without a clinical history of genital herpes) will be included when results are provided separately or can be obtained from the authors.

‡ Studies that test for both HSV-1 and HSV-2 (simultaneously) will be included if they meet other eligibility criteria; however, only the accuracy of test characteristics related to HSV-2 serologic tests will be evaluated.

§ Previous systematic reviews will be included if they are recent (published within 5 years), of good quality, and are similar in scope to our review. Initial database searches will not be limited by date of publication for these KQs. If no recent, good-quality systematic reviews are identified, all eligible primary studies that address the KQs will be included.

Abbreviations: FDA=U.S. Food and Drug Administration; HSV=herpes simples virus; KQ=key question; PCR=polymerase chain reaction.

## Appendix B3 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized, Controlled Trials

#### Criteria

- Initial assembly of comparable groups: Randomized controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: Equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

#### Definition of Ratings Based on Above Criteria

Good: | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
Poor: | Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

Sources: U.S. Preventive Services Task Force, Procedure Manual, Appendix VII http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual---appendix-vii Harris et al., 2001.^62^

### Studies of Diagnostic Tests

#### Criteria

- Screening test relevant, available for primary care, adequately described.
- Study uses a credible reference standard, performed regardless of test results.
- Reference standard interpreted independently of screening test.
- Handles indeterminate results in a reasonable manner.
- Spectrum of patients included in study.
- Sample size: Although this is one of the criteria listed in the current procedures manual, we did not consider sample size when assessing study quality, as sample size affects precision of the estimate.
- Administration of reliable screening test.

In addition to the criteria listed in the USPSTF procedures manual, we also considered the criteria described in our Appendix D (which details assessments of individual studies).

#### Definition of Ratings Based on Above Criteria

Good: | Relevant and adequately described study populations for the outcome of interest (i.e., Sensitivity, Specificity), screening test well described in terms of test procedures followed and threshold used for a “positive” or “negative” test, credible reference standard used for outcome of interest (i.e., Sensitivity or Specificity), generally interprets reference standard independently of screening test, outcomes clearly reported and valid, handles indeterminate results in a reasonable manner.
Fair: | Mostly includes a relevant and adequately described study population for the outcome of interest (i.e., Sensitivity, Specificity), screening test described although may include some ambiguity about test procedures followed or threshold for a “positive” or “negative” test, credible reference standard mostly used for outcome of interest (i.e., Sensitivity or specificity), interpretation of reference standard may or may not be independent of screening test, outcomes mostly clearly reported although may have some ambiguity regarding how indeterminate results were handled.
Poor: | Has fatal flaw such as study population not appropriate for outcome of interest (i.e., Sensitivity, Specificity), screening test improperly administered or not at all described, use of noncredible reference standard, reference and screening test not independently assessed, outcomes not clearly or accurately reported with no information about how indeterminate tests were handled.

Criteria Adapted from: U.S. Preventive Services Task Force, Procedure Manual Appendix VII http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual---appendix-vii Harris et al., 2001.^62^