# Appendix A Additional Background and Contextual Questions

## Contextual Questions

During the review process, we identified literature addressing the Contextual Questions (CQs) below. These CQs were not a part of our systematic review. They are intended to provide additional background information related to the prevalence, incidence, and natural history of genital herpes in the United States.

### CQ1 What Proportion of Asymptomatic Adults, Adolescents, and Pregnant Women Who Are Identified as Being Seropositive for HSV-2, HSV-1, or Both Will Have a Recognized Symptomatic Episode of Genital Herpes?

Evidence addressing CQ 1 is summarized in Table A1. To address this question, we identified trials or prospective cohort studies enrolling asymptomatic adults, adolescents, or pregnant women who had serologic testing for HSV-2 but reported no prior history of genital herpes. We required studies to follow participants over time and report the incidence of symptoms consistent with genital herpes. We identified six relevant studies; all enrolled adults seropositive for HSV-2 and most determined (or confirmed) HSV-2 seropositivity using the Western blot. Two studies included participants who were tested for HSV-2 in a clinical setting for various reasons (e.g., women suspected of transmitting HSV-2 to a partner).^92, 93^ and the others recruited participants from both clinical and research settings in the context of recruitment or enrollment in clinical trials focused on genital herpes. All studies focused only on participants who were seropositive and did not follow participants who were seronegative for HSV-2 to ascertain the proportion of participants who seroconverted or developed genital symptoms over time.

Across all six studies, 16 to 87 percent of participants developed signs or symptoms of genital herpes over a follow-up duration of 5 months or less (Table 1A). Studies varied in how symptom occurrence was measured, which may explain some of the heterogeneity in the observed rate of symptom occurrence. Of note, all six studies delivered counseling about the clinical signs and symptoms of genital herpes to all participants, and instructed participants to return for a clinical exam if signs or symptoms occurred. The three studies with the highest incidence of symptom occurrence (52 to 82%) included detailed counseling sessions on genital herpes, including education on atypical symptoms (e.g., vulvar irritation);^11, 92, 94^ two of which described showing participants photographs of genital herpes lesions.^11, 94^

Appendix A Table 1 Incidence of Symptomatic Episodes Among Asymptomatic Persons Identified as Seropositive for HSV-2

Author, Year Study Design | Population (N) | Ascertainment of Herpes-Related Symptoms and HSV-2 Infection Followup Duration | Proportion With Incident Genital Herpes Symptoms
Langenberg, 1989^92^ Cohort | Women recruited from an urban city-county hospital and gynecology clinic who were identified as HSV-2 seropositive but reported no history of genital herpes (62) | Self-report; Western Blot 5 months | 52% (32) developed symptomatic genital herpes
Leone, 2007^82^ RCT US | Men and women identified as HSV-2 seropositive who reported no prior history of genital herpes enrolled in a trial assessing viral shedding (66) | Self-report; Western Blot 42 days | 17.2% (11 during placebo treatment); 17.5% (12 during antiviral medication treatment)
Frenkel, 1993^93^ Cohort US | Pregnant women recruited from 3 private obstetrics practices (264) | Self-report; Western Blot NR (followed until delivery) | 16%^*^ (63)
Tronstein, 2011^94^ Cohort US | Adult men and women study participants from the University of Washington Virology Research Clinic^†^ (88) | Self-report; Western Blot Median: 57 days (IQR, 47–62) | 68% (95% CI, 58 to 78) (60)
Sperling, 2008^81^ RCT US | Adult men and women from 13 centers in the US (various clinical settings) identified as HSV-2 seropositive who reported no current or past symptoms consistent with genital herpes enrolled in a trial assessing viral shedding (56) | Self-report; HerpeSelect ELISA (index values 1.1 to 3.5 confirmed with HSV-2 IgG inhibition assay) 2 months | 23% (13 overall)
Wald, 2000^11^ Cohort US | Adults seropositive for HSV-2 with no history of genital herpes, recruited from either 1) a primary care clinic or 2) participants evaluated for entry in a HSV-2 vaccine trial unexpectedly found to be HSV-2 positive^‡^ (53) | Self-report; Western blot 3 months | 87% (46) reported having either genital lesions or localized genital symptoms during followup

* 56% (N=24) of women recognized HSV lesions during the 3rd trimester; 16 women had their babies by cesarean delivery because of genital herpes.

† Participants were enrolled in prospective studies of the natural history of genital HSV infection.

‡ All subjects attended an individual standardized educational session on genital herpes that included reviewing photographs of herpetic lesions. Photographs of both typical lesions (e.g., blisters and genital herpes ulcers) and atypical lesions (e.g., fissures) were shown, and the common symptoms (e.g., itching and tingling) were discussed.

Abbreviations: CI=confidence interval; HSV=herpes simplex virus; IQR=interquartile range; N=number; NR=not reported.

### CQ 2 Among Asymptomatic Adults, Adolescents, and Pregnant Women Who Are Identified as Being Seropositive for One Virus Subtype, What Proportion of Recognized Symptomatic Episodes Is Due to a New HSV Infection With a Different Subtype Versus a Recurrent Infection?

None of the studies above reporting on the incidence of symptoms among asymptomatic persons who test positive for HSV-2 reported on whether incident symptoms were attributable to HSV-1 versus HSV-2. We found no other studies addressing this CQ.

### CQ 3 What Is the Estimated Incidence Rate of Neonatal HSV Infection in the United States?

We found no recent (published in 2014 or later), multistate registry (or multi-institutional) study reporting on the incidence of HSV infection in the United States. Estimates of neonatal HSV incidence in the United States vary widely (1 out of every 3,200 to 10,000 live births), and rates are measured using heterogeneous methods.^16, 42–44^

The most recent estimate is based on a clinical laboratory reporting system initiated in New York City in 2006.^45^ Between April 2006 and September 2010, 76 cases were detected and the average incidence was estimated at 13.3 per100,000 live births (or 1 per 7,519 live births). The most recent multistate estimate comes from a study using a pediatric inpatient discharge database to identify cases of neonatal HSV infection in 2006.^42^ The estimated incidence of neonatal HSV was 9.6 per 100,000 births (95% CI, 4.3 to 12.0). Incidence rates varied by geographic region and race but the differences were not statistically significant; however, rates were significantly higher among cases for which the expected primary payer was Medicaid (15.1 cases per 100,000 live births) compared with private insurance or managed health care (5.4 cases per 100,000 live births).^42^

### CQ 4 What Proportion of Neonatal HSV Infections in the United States Is Attributed to HSV-1 and HSV-2?

We identified one study that described the proportion of neonatal HSV infection attributed to HSV-1 and HSV-2; this study used New York City neonatal surveillance data and is described above (in CQ 3).^45^ Starting in 2006, clinical laboratories were required to report positive results for HSV on specimens from infants aged ≤60 days who were New York City residents, and health care providers were required to report diagnoses of neonatal HSV infection for the same age group, regardless of whether laboratory results confirmed infection. Between 2006 and 2010, New York City neonatal HSV surveillance detected 76 cases (estimated incidence of 13.3 per 100,000 live births). Most reported cases were laboratory confirmed (91%); 41 percent (28 cases) were HSV-1 and 39 percent (27 cases) were HSV-2 (20% of cases were not typed).^45^

### CQ 5 Are Externally Validated, Reliable Risk Stratification Tools Available That Distinguish Persons Who Are More or Less Likely to Have Genital Herpes?

We did not identify any externally validated, reliable risk stratification tools that distinguish persons who are more or less likely to have genital herpes.

### CQ 6 What Populations Are at Higher Risk for Genital Herpes Infection?

To address this question, we identified studies reporting on the incidence or prevalence of genital herpes (or HSV-2 seropositivity) in in the United States based on demographic or other issues. We limited the search to multisite studies published in the past 5 years. We identified few studies assessing the prevalence or incidence of genital herpes. Most evidence comes from cross-sectional seroprevalence studies; none reported on the risk of demographic or behavioral factors based on a multivariate analysis.

Estimates of HSV-2 seroprevalence based on NHANES data from 2005 to 2010^19^ vary by age, gender, race and ethnicity, and geographic region. Among people 14 to 19 years of age, HSV-2 seroprevalence is estimated to be 1.4 percent compared with 26.1 percent in people 40 to 49 years of age.^19^ Women have a higher estimated prevalence than men (20.9% vs. 11.5%), which is attributed to anatomic factors predisposing women to be more susceptible to HSV-2 infection than men. Non-Hispanic Blacks have the highest estimated seroprevalence of HSV-2 infection (39.2%), which is three times that of non-Hispanic Whites (12.3%).^19^