# References

1 American College of Obstetricians and Gynecologists. Hypertension in Pregnancy. Washington, DC: 2013.
2 Homer CS, Brown MA, Mangos G, . Non-proteinuric pre-eclampsia: a novel risk indicator in women with gestational hypertension. J Hypertens 2008 Feb;26(2):295-302. PMID: 18192844.18192844
3 Akaishi R, Yamada T, Morikawa M, . Clinical features of isolated gestational proteinuria progressing to pre-eclampsia: retrospective observational study. BMJ Open 2014;4(4):e004870. PMID: 24747797.24747797
4 Airoldi J, Weinstein L. Clinical significance of proteinuria in pregnancy. Obstet Gynecol Surv 2007 Feb;62(2):117-24. PMID: 17229328.17229328
5 Thangaratinam S, Coomarasamy A, O'Mahony F, . Estimation of proteinuria as a predictor of complications of pre-eclampsia: a systematic review. BMC Medicine 2009 Mar 24;7:10. PMID: 19317889.19317889
6 Hutcheon JA, Lisonkova S, Joseph KS. Epidemiology of pre-eclampsia and the other hypertensive disorders of pregnancy. Best Pract Res Clin Obstet Gynaecol 2011 Aug;25(4):391-403. PMID: 21333604.21333604
7 Trogstad L, Magnus P, Stoltenberg C. Pre-eclampsia: Risk factors and causal models. Best Pract Res Clin Obstet Gynaecol 2011 Jun;25(3):329-42. PMID: 21349772.21349772
8 Steegers EA, von DP, Duvekot JJ, . Pre-eclampsia. Lancet 2010 Aug 21;376(9741):631-44. PMID: 20598363.20598363
9 Lazdam M, de la Horra A, Diesch J, . Unique blood pressure characteristics in mother and offspring after early onset preeclampsia. Hypertension 2012 Nov;60(5):1338-45. PMID: 23045462.23045462
10 Warrington JP, George EM, Palei AC, . Recent advances in the understanding of the pathophysiology of preeclampsia. Hypertension 2013 Oct;62(4):666-73. PMID: 23897068.23897068
11 Huppertz B. Placental origins of preeclampsia: challenging the current hypothesis. Hypertension 2008 Apr;51(4):970-5. PMID: 18259009.18259009
12 Ghulmiyyah L, Sibai B. Maternal mortality from preeclampsia/eclampsia. Semin Perinatol 2012 Feb;36(1):56-9. PMID: 22280867.22280867
13 Ananth CV, Keyes KM, Wapner RJ. Pre-eclampsia rates in the United States, 1980-2010: age-period-cohort analysis. BMJ 2013;347:f6564. PMID: 24201165.24201165
14 Creanga AA, Berg CJ, Ko JY, . Maternal mortality and morbidity in the United States: where are we now? J Womens Health (Larchmt) 2014 Jan;23(1):3-9. PMID: 24383493.24383493
15 MacKay AP, Berg CJ, Atrash HK. Pregnancy-related mortality from preeclampsia and eclampsia. Obstet Gynecol 2001 Apr;97(4):533-8. PMID: 11275024.11275024
16 Waterstone M, Bewley S, Wolfe C. Incidence and predictors of severe obstetric morbidity: case-control study. BMJ 2001 May 5;322(7294):1089-93. PMID: 11337436.11337436
17 Grobman WA, Bailit J.L., Rice M.M, . Frequency of and factors associated with severe maternal morbidity. Obstet Gynecol 2014;123(4):804-10.24785608
18 Kuklina EV, Ayala C, Callaghan WM. Hypertensive disorders and severe obstetric morbidity in the United States. Obstet Gynecol 2009 Jun;113(6):1299-306. PMID: 19461426.19461426
19 Callaghan WM, Creanga AA, Kuklina EV. Severe maternal morbidity among delivery and postpartum hospitalizations in the United States. Obstet Gynecol 2012 Nov;120(5):1029-36. PMID: 23090519.23090519
20 Harmon QE, Huang L, Umbach DM, . Risk of fetal death with preeclampsia. Obstet Gynecol 2015 Mar;125(3):628-35. PMID: 25730226.25730226
21 Ananth CV, Vintzileos AM. Maternal-fetal conditions necessitating a medical intervention resulting in preterm birth. American Journal of Obstetrics & Gynecology 2006 Dec;195(6):1557-63. PMID: 17014813.17014813
22 Lisonkova S, Joseph KS. Incidence of preeclampsia: risk factors and outcomes associated with early- versus late-onset disease. Am J Obstet Gynecol 2013 Dec;209(6):544. PMID: 23973398.23973398
23 Fisher J, Astbury J, Smith A. Adverse psychological impact of operative obstetric interventions: a prospective longitudinal study. Aust N Z J Psychiatry 1997 Oct;31(5):728-38. PMID: 9400879.9400879
24 Soet JE, Brack GA, DiIorio C. Prevalence and predictors of women's experience of psychological trauma during childbirth. Birth 2003 Mar;30(1):36-46. PMID: 12581038.12581038
25 Hoedjes M, Berks D, Vogel I, . Poor health-related quality of life after severe preeclampsia. Birth 2011 Sep;38(3):246-55. PMID: 21884233.21884233
26 Rep A, Ganzevoort W, Bonsel GJ, . Psychosocial impact of early-onset hypertensive disorders and related complications in pregnancy. Am J Obstet Gynecol 2007 Aug;197(2):158-6. PMID: 17689633.17689633
27 Engelhard IM, van RM, Boullart I, . Posttraumatic stress disorder after pre-eclampsia: an exploratory study. Gen Hosp Psychiatry 2002 Jul;24(4):260-4. PMID: 12100837.12100837
28 Gaugler-Senden IP, Duivenvoorden HJ, Filius A, . Maternal psychosocial outcome after early onset preeclampsia and preterm birth. J Matern Fetal Neonatal Med 2012 Mar;25(3):272-6. PMID: 21557690.21557690
29 Tanaka M, Jaamaa G, Kaiser M, . Racial disparity in hypertensive disorders of pregnancy in New York State: a 10-year longitudinal population-based study. American Journal of Public Health 2007 Jan;97(1):163-70. PMID: 17138931.17138931
30 Levy MT, Jacober SJ, Sowers JR. Hypertensive disorders of pregnancy in southwestern Navajo Indians. Archives of Internal Medicine 1994 Oct 10;154(19):2181-3. PMID: 7944838.7944838
31 Main EK, McCain CL, Morton CH, . Pregnancy-related mortality in California: causes, characteristics, and improvement opportunities. Obstet Gynecol 2015 Apr;125(4):938-47. PMID: 25751214.25751214
32 Berg CJ, Callaghan WM, Syverson C, . Pregnancy-related mortality in the United States, 1998 to 2005. Obstet Gynecol 2010 Dec;116(6):1302-9. PMID: 21099595.21099595
33 Martin JA, Hamilton BE, Ventura SJ, . Births: final data for 2009. Natl Vital Stat Rep 2011 Nov 3;60(1):1-70. PMID: 22670489.22670489
34 Tucker MJ, Berg CJ, Callaghan WM, . The Black-White disparity in pregnancy-related mortality from 5 conditions: differences in prevalence and case-fatality rates. Am J Public Health 2007 Feb;97(2):247-51. PMID: 17194867.17194867
35 Bateman BT, Shaw KM, Kuklina EV, . Hypertension in women of reproductive age in the United States: NHANES 1999-2008. PLoS One 2012;7(4):e36171. PMID: 22558371.22558371
36 Healy AJ, Malone FD, Sullivan LM, . Early access to prenatal care: implications for racial disparity in perinatal mortality. Obstet Gynecol 2006 Mar;107(3):625-31. PMID: 16507934.16507934
37 Mbah AK, Alio AP, Marty PJ, . Recurrent versus isolated pre-eclampsia and risk of feto-infant morbidity outcomes: racial/ethnic disparity. Eur J Obstet Gynecol Reprod Biol 2011 May;156(1):23-8. PMID: 21316142.21316142
38 Egbor M, Ansari T, Morris N, . Morphometric placental villous and vascular abnormalities in early- and late-onset pre-eclampsia with and without fetal growth restriction. BJOG 2006 May;113(5):580-9. PMID: 16579806.16579806
39 McDonald SD, Malinowski A, Zhou Q, . Cardiovascular sequelae of preeclampsia/eclampsia: a systematic review and meta-analyses. Am Heart J 2008 Nov;156(5):918-30. PMID: 19061708.19061708
40 Myatt L, Roberts JM. Preeclampsia: Syndrome or Disease? Curr Hypertens Rep 2015 Nov;17(11):83. PMID: 26362531.26362531
41 Redman C. Pre-eclampsia: A complex and variable disease. Pregnancy Hypertens 2014 Jul;4(3):241-2. PMID: 26104638.26104638
42 Duckitt K, Harrington D. Risk factors for pre-eclampsia at antenatal booking: systematic review of controlled studies. BMJ 2005 Mar 12;330(7491):565. PMID: 15743856.15743856
43 Bushnell C, McCullough LD, Awad IA, . Guidelines for the prevention of stroke in women: a statement for healthcare professionals from the American Heart Association/American Stroke Association. Stroke 2014 May;45(5):1545-88. PMID: 24503673.24503673
44 Bramham K, Parnell B, Nelson-Piercy C, . Chronic hypertension and pregnancy outcomes: systematic review and meta-analysis. BMJ 2014;348:g2301. PMID: 24735917.24735917
45 Sibai BM, Caritis S, Hauth J, . Risks of preeclampsia and adverse neonatal outcomes among women with pregestational diabetes mellitus. National Institute of Child Health and Human Development Network of Maternal-Fetal Medicine Units. Am J Obstet Gynecol 2000 Feb;182(2):364-9. PMID: 10694338.10694338
46 LeFevre ML, U.S.Preventive Services Task Force. Low-dose aspirin use for the prevention of morbidity and mortality from preeclampsia: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med 2014 Dec 2;161(11):819-26. PMID: 25200125.25200125
47 National Institute for Health and Clinical Excellence. Hypertension in pregnancy- the management of hypertensive disorders in pregnancy. Manchester, UK: National Institute for Health and Clinical Excellence; 2010.
48 Arulkumaran N, Lightstone L. Severe pre-eclampsia and hypertensive crises. Best Pract Res Clin Obstet Gynaecol 2013 Dec;27(6):877-84. PMID: 23962474.23962474
49 Altman D, Carroli G, Duley L, . Do women with pre-eclampsia, and their babies, benefit from magnesium sulphate? The Magpie Trial: a randomised placebo-controlled trial. Lancet 2002 Jun 1;359(9321):1877-90. PMID: 12057549.12057549
50 Knight M, UKOSS. Eclampsia in the United Kingdom 2005. BJOG 2007 Sep;114(9):1072-8. PMID: 17617191.17617191
51 World Health Organization. Recommendations for prevention and treatment of preeclampsia. Geneva, Switzerland: World Health Organization; 2011.
52 Chappell LC, Milne F, Shennan A. Is early induction or expectant management more beneficial in women with late preterm pre-eclampsia? BMJ 2015;350:h191. PMID: 25861796.25861796
53 Milne F, Redman C, Walker J, . Assessing the onset of pre-eclampsia in the hospital day unit: summary of the pre-eclampsia guideline (PRECOG II). BMJ 2009;339:b3129. PMID: 19740933.19740933
54 Visintin C, Mugglestone MA, Almerie MQ, . Management of hypertensive disorders during pregnancy: summary of NICE guidance. BMJ 2010;341:c2207. PMID: 20739360.20739360
55 von DP, Payne B, Li J, . Prediction of adverse maternal outcomes in pre-eclampsia: development and validation of the fullPIERS model. Lancet 2011 Jan 15;377(9761):219-27.21185591
56 Chappell LC, Duckworth S, Griffin M, . OS100. Plasma placental growth factor (PLGF) measurement in women presenting with suspected pre-eclampsia: the pelican study. Pregnancy Hypertens 2012 Jul;2(3):233-4. PMID: 26105314.26105314
57 Clark SL, Christmas JT, Frye DR, . Maternal mortality in the United States: predictability and the impact of protocols on fatal postcesarean pulmonary embolism and hypertension-related intracranial hemorrhage. Am J Obstet Gynecol 2014 Mar 14 PMID: 24631705.24631705
58 Geller SE, Rosenberg D, Cox SM, . The continuum of maternal morbidity and mortality: factors associated with severity. Am J Obstet Gynecol 2004 Sep;191(3):939-44. PMID: 15467568.15467568
59 Douglas KA, Redman CW. Eclampsia in the United Kingdom. BMJ 1994 Nov 26;309(6966):1395-400. PMID: 7819845.7819845
60 Henderson JT, Whitlock EP, O'Conner E, . Low-dose aspirin for the prevention of morbidity and mortality from preeclampsia. Rockville, MD: Agency for Healthcare Research and Quality; 2014.
61 Askie LM, Duley L, Henderson-Smart DJ, . Antiplatelet agents for preventing pre-eclampsia and its complications. Lancet 2007 May 26;369(9575):1791-8. PMID: 17512048.17512048
62 Pare E, Parry S, McElrath TF, . Clinical risk factors for preeclampsia in the 21st century. Obstet Gynecol 2014 Oct;124(4):763-70. PMID: 25198274.25198274
63 Grill S, Rusterholz C, Zanetti-Dallenbach R, . Potential markers of preeclampsia--a review. Reprod Biol Endocrinol 2009;7:70. PMID: 19602262.19602262
64 Thangaratinam S, Langenveld J, Mol BW, . Prediction and primary prevention of pre-eclampsia. [Review]. Best Practice & Research in Clinical Obstetrics & Gynaecology 2011 Aug;25(4):419-33. PMID: 21454131.21454131
65 Poon LC, Kametas NA, Chelemen T, . Maternal risk factors for hypertensive disorders in pregnancy: a multivariate approach. J Hum Hypertens 2010 Feb;24(2):104-10. PMID: 19516271.19516271
66 Audibert F, Boucoiran I, An N, . Screening for preeclampsia using first-trimester serum markers and uterine artery Doppler in nulliparous women. Am J Obstet Gynecol 2010 Oct;203(4):383-8. PMID: 20691410.20691410
67 Kirkham C, Harris S, Grzybowski S. Evidence-based prenatal care: Part I. General prenatal care and counseling issues. Am Fam Physician 2005 Apr 1;71(7):1307-16. PMID: 15832534.15832534
68 Schuster MA, McGlynn EA, Brook RH. How good is the quality of health care in the United States? 1998. Milbank Q 2005;83(4):843-95. PMID: 16279970.16279970
69 Siddique J, Lantos JD, VanderWeele TJ, . Screening tests during prenatal care: does practice follow the evidence? Matern Child Health J 2012 Jan;16(1):51-9. PMID: 21113814.21113814
70 Alto WA, Yetman CA. Routine prenatal urine dipstick testing. Journal of Reproductive Medicine 2007 Oct;52(10):984. PMID: 17977184.17977184
71 National Institute of Child Health and Human Development. What happens during prenatal visits? Bethesda, MD: National Institutes of Health; 2013. http://www.nichd.nih.gov/health/topics/preconceptioncare/conditioninfo/pages/prenatal-visits.aspx. Accessed October 22, 2015.
72 Office on Women's Health. Prenatal care and tests. Washington, DC: U.S. Department of Health and Human Services; 2010. http://www.womenshealth.gov/pregnancy/you-are-pregnant/prenatal-care-tests.html. Accessed October 22, 2015.
73 Meads CA, Cnossen JS, Meher S, . Methods of prediction and prevention of pre-eclampsia: systematic reviews of accuracy and effectiveness literature with economic modelling. Health Technology Assessment (Winchester, England) 2001;12(6):iii-iiv. PMID: 18331705.18331705
74 US Preventive Services Task Force. Screening for Preeclampsia. In: DiGiuseppi C, Atkins D, Woolf S, . (eds). Guide to Clinical Preventive Services. 2nd ed. Baltimore, MD: Williams and Wilkins; 1996. p. 419-24.
75 Cote AM, Brown MA, Lam E, . Diagnostic accuracy of urinary spot protein:creatinine ratio for proteinuria in hypertensive pregnant women: systematic review. BMJ 2008 May 3;336(7651):1003-6. PMID: 18403498.18403498
76 U.S.Preventive Services Task Force. Procedure manual. Rockville, MD: Agency of Healthcare Research and Quality; 2014.
77 Wallace BC, Small K, Brodley CE, . Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proceedings of the 2nd ACM SIGHIT International Health Informatics Symposium. 2012. p. 819-24.
78 Gillon TE, Pels A, von DP, . Hypertensive disorders of pregnancy: a systematic review of international clinical practice guidelines. PLoS One 2014;9(12):e113715. PMID: 25436639.25436639
79 American College of Obstetricians and Gynecologists. ACOG practice bulletin. Diagnosis and management of preeclampsia and eclampsia. Number 33, January 2002. Obstet Gynecol 2002 Jan;99(1):159-67. PMID: 16175681.16175681
80 Bujold E, Roberge S, Lacasse Y, . Prevention of preeclampsia and intrauterine growth restriction with aspirin started in early pregnancy: a meta-analysis. Obstet Gynecol 2010 Aug;116(2:Pt 1):402-14. PMID: 20664402.20664402
81 Moore GS, Allshouse AA, Post AL, . Early initiation of low-dose aspirin for reduction in preeclampsia risk in high-risk women: a secondary analysis of the MFMU High-Risk Aspirin Study. J Perinatol 2014 Dec 4 PMID: 25474553.25474553
82 Palomaki GE, Knight GJ, Ashwood ER, . Screening for down syndrome in the United States: results of surveys in 2011 and 2012. Arch Pathol Lab Med 2013 Jul;137(7):921-6. PMID: 23808464.23808464
83 Moons KG, de Groot JA, Bouwmeester W, . Critical appraisal and data extraction for systematic reviews of prediction modelling studies: the CHARMS checklist. PLoS Med 2014 Oct;11(10):e1001744. PMID: 25314315.25314315
84 Debray TP, Vergouwe Y, Koffijberg H, . A new framework to enhance the interpretation of external validation studies of clinical prediction models. J Clin Epidemiol 2015 Mar;68(3):279-89. PMID: 25179855.25179855
85 Moons KG, Altman DG, Reitsma JB, . Transparent Reporting of a multivariable prediction model for Individual Prognosis or Diagnosis (TRIPOD): explanation and elaboration. Ann Intern Med 2015 Jan 6;162(1):W1-73. PMID: 25560730.25560730
86 United Nations Development Programme. Human Development Report 2014. Washington DC, USA: United Nations Development Programme; 2014.
87 Harris RP, Helfand M, Woolf SH, . Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med 2001 Apr;20(3 Suppl):21-35. PMID: 11306229.11306229
88 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med 2011 Oct 18;155(8):529-36. PMID: 22007046.22007046
89 Wells GA, Shea B, O'Connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analysis. Ottawa: Ottawa Hospital Research Institute; 2014. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed October 26, 2015.
90 Kleinrouweler CE, Cheong-See Mrcog FM, Collins GS, . Prognostic models in obstetrics: available, but far from applicable. Am J Obstet Gynecol 2015 Jun 9 PMID: 26070707.26070707
91 Steyerberg EW, Vickers AJ, Cook NR, . Assessing the performance of prediction models: a framework for traditional and novel measures. Epidemiology 2010 Jan;21(1):128-38. PMID: 20010215.20010215
92 Deeks JJ, Altman DG. Diagnostic tests 4: likelihood ratios. BMJ 2004 Jul 17;329(7458):168-9. PMID: 15258077.15258077
93 Saudan PJ, Brown MA, Farrell T, . Improved methods of assessing proteinuria in hypertensive pregnancy. Br J Obstet Gynaecol 1997 Oct;104(10):1159-64. PMID: 9332994.9332994
94 Waugh JJ, Bell SC, Kilby MD, . Optimal bedside urinalysis for the detection of proteinuria in hypertensive pregnancy: a study of diagnostic accuracy. BJOG 2005 Apr;112(4):412-7. PMID: 15777437.15777437
95 Thompson SG, Higgins JP. How should meta-regression analyses be undertaken and interpreted? Stat Med 2002 Jun 15;21(11):1559-73. PMID: 12111920.12111920
96 Naaktgeboren CA, van Enst WA, Ochodo EA, . Systematic overview finds variation in approaches to investigating and reporting on sources of heterogeneity in systematic reviews of diagnostic studies. J Clin Epidemiol 2014 Nov;67(11):1200-9. PMID: 25063558.25063558
97 McDuffie RS, Jr., Beck A, Bischoff K, . Effect of frequency of prenatal care visits on perinatal outcome among low-risk women. A randomized controlled trial. JAMA 1996 Mar 20;275(11):847-51. PMID: 8596222.8596222
98 Farina A, Rapacchia G, Freni SA, . Prospective evaluation of ultrasound and biochemical-based multivariable models for the prediction of late pre-eclampsia. Prenat Diagn 2011 Dec;31(12):1147-52. PMID: 22009522.22009522
99 Oliveira N, Magder LS, Blitzer MG, . First Trimester Prediction of Preeclampsia: External validity of algorithms in a prospectively enrolled cohort. Ultrasound Obstet Gynecol 2014 Jun 10;44(3):279-85. PMID: 24913190.24913190
100 Park FJ, Leung CH, Poon LC, . Clinical evaluation of a first trimester algorithm predicting the risk of hypertensive disease of pregnancy. Aust N Z J Obstet Gynaecol 2013 Dec;53(6):532-9. PMID: 23919594.23919594
101 Skrastad R, Hov G, Blaas HG, . Risk assessment for preeclampsia in nulliparous women at 11-13 weeks gestational age: prospective evaluation of two algorithms. BJOG 2014 Dec 4 PMID: 25471057.25471057
102 Simeone S, Lojo C, Garcia-Esteve L, . Psychological impact of first-trimester prevention for preeclampsia on anxiety. Prenat Diagn 2015 Jan;35(1):60-4. PMID: 25156501.25156501
103 Bhide A, Rana R, Dhavilkar M, . The value of the urinary protein:creatinine ratio for the detection of significant proteinuria in women with suspected preeclampsia. Acta Obstet Gynecol Scand 2015 Mar 3;94(5):542-6. PMID: 25737188.25737188
104 Durnwald C, Mercer B. A prospective comparison of total protein/creatinine ratio versus 24-hour urine protein in women with suspected preeclampsia. Am J Obstet Gynecol 2003 Sep;189(3):848-52. PMID: 14526328.14526328
105 Dwyer BK, Gorman M, Carroll IR, . Urinalysis vs urine protein-creatinine ratio to predict significant proteinuria in pregnancy. J Perinatol 2008 Jul;28(7):461-7. PMID: 18288120.18288120
106 Kyle PM, Fielder JN, Pullar B, . Comparison of methods to identify significant proteinuria in pregnancy in the outpatient setting. BJOG 2008 Mar;115(4):523-7. PMID: 18201282.18201282
107 Lamontagne A, Cote AM, Rey E. The urinary protein-to-creatinine ratio in Canadian women at risk of preeclampsia: does the time of day of testing matter? J Obstet Gynaecol Can 2014 Apr;36(4):303-8. PMID: 24798667.24798667
108 Sethuram R, Kiran TS, Weerakkody AN. Is the urine spot protein/creatinine ratio a valid diagnostic test for pre-eclampsia? J Obstet Gynaecol 2011;31(2):128-30. PMID: 21281026.21281026
109 Stout MJ, Scifres CM, Stamilio DM. Diagnostic utility of urine protein-to-creatinine ratio for identifying proteinuria in pregnancy. J Matern Fetal Neonatal Med 2013 Jan;26(1):66-70. PMID: 23020712.23020712
110 Tun C, Quinones JN, Kurt A, . Comparison of 12-hour urine protein and protein:creatinine ratio with 24-hour urine protein for the diagnosis of preeclampsia. Am J Obstet Gynecol 2012 Sep;207(3):233-8. PMID: 22939731.22939731
111 Verdonk K, Niemeijer I, Hop W, . Variation of urinary protein to creatinine ratio during the day in women with suspected pre-eclampsia. BJOG 2014 Apr 25;121(13):1660-5. PMID: 24762212.24762212
112 Waugh J, Bell SC, Kilby M, . Effect of concentration and biochemical assay on the accuracy of urine dipsticks in hypertensive pregnancies. Hypertens Pregnancy 2001;20(2):205-17. PMID: 12044331.12044331
113 Wheeler TL, Blackhurst DW, Dellinger EH, . Usage of spot urine protein to creatinine ratios in the evaluation of preeclampsia. Am J Obstet Gynecol 2007 May;196(5):465-4. PMID: 17466704.17466704
114 Young RA, Buchanan RJ, Kinch RA. Use of the protein/creatinine ratio of a single voided urine specimen in the evaluation of suspected pregnancy-induced hypertension. J Fam Pract 1996 Apr;42(4):385-9. PMID: 8627207.8627207
115 Rhode MA, Shapiro H, Jones OW, III. Indicated vs. routine prenatal urine chemical reagent strip testing. J Reprod Med 2007 Mar;52(3):214-9. PMID: 17465289.17465289
116 Moura SB EH Park F, Murthi P, . TNF-R1 as a first trimester marker for prediction of pre-eclampsia. J Matern Fetal Neonatal Med 2015 Mar 17:1-7. PMID: 25758630.25758630
117 Oliveira N, Doyle LE, Atlas RO, . External validity of first trimester algorithms in the prediction of pre-eclampsia disease severity. Ultrasound Obstet Gynecol 2014 Jun 10;44(3):286-92. PMID: 24912952.24912952
118 Park F, Russo K, Williams P, . Prediction and prevention of early onset pre-eclampsia: The impact of aspirin after first trimester screening. Ultrasound Obstet Gynecol 2015 Feb 11 PMID: 25678383.25678383
119 Valdes E, Sepulveda-Martinez A, Tong A, . Assessment of protein:creatinine ratio versus 24-hour urine protein in the diagnosis of preeclampsia. Gynecol Obstet Invest 2015 Jun 3 PMID: 26045043.26045043
120 Akolekar R, Syngelaki A, Poon L, . Competing risks model in early screening for preeclampsia by biophysical and biochemical markers. Fetal Diagn Ther 2013;33(1):8-15. PMID: 22906914.22906914
121 Caradeux J, Serra R, Nien JK, . First trimester prediction of early onset preeclampsia using demographic, clinical, and sonographic data: a cohort study. Prenat Diagn 2013 Aug;33(8):732-6. PMID: 23584890.23584890
122 Odibo AO, Zhong Y, Goetzinger KR, . First-trimester placental protein 13, PAPP-A, uterine artery Doppler and maternal characteristics in the prediction of pre-eclampsia. Placenta 2011 Aug;32(8):598-602. PMID: 21652068.21652068
123 Onwudiwe N, Yu CK, Poon LC, . Prediction of pre-eclampsia by a combination of maternal history, uterine artery Doppler and mean arterial pressure. Ultrasound Obstet Gynecol 2008 Dec;32(7):877-83. PMID: 18991324.18991324
124 Parra-Cordero M, Rodrigo R, Barja P, . Prediction of early and late pre-eclampsia from maternal characteristics, uterine artery Doppler and markers of vasculogenesis during first trimester of pregnancy. Ultrasound Obstet Gynecol 2013 May;41(5):538-44. PMID: 22807133.22807133
125 Plasencia W, Maiz N, Poon L, . Uterine artery Doppler at 11 + 0 to 13 + 6 weeks and 21 + 0 to 24 + 6 weeks in the prediction of pre-eclampsia. Ultrasound Obstet Gynecol 2008 Aug;32(2):138-46. PMID: 18634131.18634131
126 Plasencia W, Maiz N, Bonino S, . Uterine artery Doppler at 11 + 0 to 13 + 6 weeks in the prediction of pre-eclampsia. Ultrasound Obstet Gynecol 2007 Oct;30(5):742-9. PMID: 17899573.17899573
127 Poon LC, Stratieva V, Piras S, . Hypertensive disorders in pregnancy: combined screening by uterine artery Doppler, blood pressure and serum PAPP-A at 11-13 weeks. Prenat Diagn 2010 Mar;30(3):216-23. PMID: 20108221.20108221
128 Poon LC, Karagiannis G, Leal A, . Hypertensive disorders in pregnancy: screening by uterine artery Doppler imaging and blood pressure at 11-13 weeks. Ultrasound Obstet Gynecol 2009 Nov;34(5):497-502. PMID: 19827052.19827052
129 Poon LCY, Maiz N, Valencia C, . First-trimester maternal serum pregnancy-associated plasma protein-A and pre-eclampsia. Ultrasound Obstet Gynecol 2009;33(1):23-33. PMID: 19090499.19090499
130 Scazzocchio E, Figueras F, Crispi F, . Performance of a first-trimester screening of preeclampsia in a routine care low-risk setting. Am J Obstet Gynecol 2013 Mar;208(3):203. PMID: 23246313.23246313
131 Iwata J, Nishikaze O. New micro-turbidimetric method for determination of protein in cerebrospinal fluid and urine. Clin Chem 1979 Jul;25(7):1317-9. PMID: 88281.88281
132 Bradford MM. A rapid and sensitive method for the quantitation of microgram quantities of protein utilizing the principle of protein-dye binding. Anal Biochem 1976 May 7;72:248-54. PMID: 942051.942051
133 Reilly BM, Evans AT. Translating clinical research into clinical practice: impact of using prediction rules to make decisions. Ann Intern Med 2006 Feb 7;144(3):201-9. PMID: 16461965.16461965
134 American College of Obstetricians and Gynecologists. Committee Opinion No. 638: First-Trimester Risk Assessment for Early-Onset Preeclampsia. Obstet Gynecol 2015 Sep;126(3):e25-e27. PMID: 26287789.26287789
135 Grady D, Berkowitz SA. Why is a good clinical prediction rule so hard to find? Arch Intern Med 2011 Oct 24;171(19):1701-2. PMID: 22025427.22025427
136 North RA, McCowan LM, Dekker GA, . Clinical risk prediction for pre-eclampsia in nulliparous women: development of model in international prospective cohort. BMJ 2011;342:d1875. PMID: 21474517.21474517
137 Haas DM, Parker CB, Wing DA, . A description of the methods of the Nulliparous Pregnancy Outcomes Study: monitoring mothers-to-be (nuMoM2b). Am J Obstet Gynecol 2015 Apr;212(4):539. PMID: 25648779.25648779
138 Lynch CD, Tumin R, Prasad MR. Association between body mass index and the timing of pregnancy recognition and entry into prenatal care. Obstet Gynecol 2014 Nov;124(5):911-8. PMID: 25437718.25437718
139 Cheng D, Schwarz EB, Douglas E, . Unintended pregnancy and associated maternal preconception, prenatal and postpartum behaviors. Contraception 2009 Mar;79(3):194-8. PMID: 19185672.19185672
140 Higgins JR, de Swiet M. Blood-pressure measurement and classification in pregnancy. Lancet 2001 Jan 13;357(9250):131-5. PMID: 11197413.11197413
141 Pickering TG, Hall JE, Appel LJ, . Recommendations for blood pressure measurement in humans and experimental animals: part 1: blood pressure measurement in humans: a statement for professionals from the Subcommittee of Professional and Public Education of the American Heart Association Council on High Blood Pressure Research. Circulation 2005 Feb 8;111(5):697-716. PMID: 15699287.15699287
142 Morris RK, Riley RD, Doug M, . Diagnostic accuracy of spot urinary protein and albumin to creatinine ratios for detection of significant proteinuria or adverse pregnancy outcome in patients with suspected pre-eclampsia: systematic review and meta-analysis. BMJ 2012;345:e4342. PMID: 22777026.22777026
143 Magee LA, Pels A, Helewa M, . Diagnosis, evaluation, and management of the hypertensive disorders of pregnancy. Pregnancy Hypertens 2014 Apr;4(2):105-45. PMID: 26104418.26104418
144 Cote AM, Firoz T, Mattman A, . The 24-hour urine collection: gold standard or historical practice? Am J Obstet Gynecol 2008 Dec;199(6):625-6. PMID: 18718568.18718568
145 Lindheimer MD, Kanter D. Interpreting abnormal proteinuria in pregnancy: the need for a more pathophysiological approach. Obstet Gynecol 2010 Feb;115(2 Pt 1):365-75. PMID: 20093912.20093912
146 Brunelli VB, Prefumo F. Quality of first trimester risk prediction models for pre-eclampsia: a systematic review. BJOG 2015 Mar 11 PMID: 25761437.25761437
147 Al-Rubaie Z, Askie LM, Ray JG, . The performance of risk prediction models for pre-eclampsia using routinely collected maternal characteristics and comparison with models that include specialised tests and with clinical guideline decision rules: a systematic review. BJOG 2016 Aug;123(9):1441-52. PMID: 10.1111/1471-0528.14029 [doi].27225348
148 Bouwmeester W, Zuithoff NP, Mallett S, . Reporting and methods in clinical prediction research: a systematic review. PLoS Med 2012;9(5):1-12. PMID: 22629234.22629234
149 Cnossen JS, ter RG, Mol BW, . Are tests for predicting pre-eclampsia good enough to make screening viable? A review of reviews and critical appraisal. Acta Obstetricia et Gynecologica Scandinavica 2009;88(7):758-65. PMID: 19488883.19488883
150 Chappell LC, Sandall J, Barnard AM, . Predicting pre-eclampsia. BMJ 2015;351:h6349. PMID: 26607975.26607975
151 Poon LC, Kametas NA, Maiz N, . First-trimester prediction of hypertensive disorders in pregnancy. Hypertension 2009 May;53(5):812-8. PMID: 19273739.19273739
152 Harris JM, Franck L, Green B, . The psychological impact of providing women with risk information for pre-eclampsia: A qualitative study. Midwifery 2014 Apr 30;30(12):1187-95. PMID: 24917032.24917032
153 Bartsch E, Park AL, Kingdom JC, . Risk threshold for starting low dose aspirin in pregnancy to prevent preeclampsia: an opportunity at a low cost. PLoS One 2015;10(3):e0116296. PMID: 25789633.25789633
154 Ioannidis JP, Tzoulaki I. What makes a good predictor?: the evidence applied to coronary artery calcium score. JAMA 2010 Apr 28;303(16):1646-7. PMID: 20424257.20424257
155 Henderson JT, Whitlock EP, O'Connor E, . Low-dose aspirin for prevention of morbidity and mortality from preeclampsia: a systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med 2014 May 20;160(10):695-703. PMID: 24711050.24711050
156 Wright D, Syngelaki A, Akolekar R, . Competing risks model in screening for preeclampsia by maternal characteristics and medical history. Am J Obstet Gynecol 2015 Feb 25;213(1):62. PMID: 25724400.25724400
157 Verghese L, Alam S, Beski S, . Antenatal screening for pre-eclampsia: evaluation of the NICE and pre-eclampsia community guidelines. J Obstet Gynaecol 2012 Feb;32(2):128-31. PMID: 22296420.22296420
158 Myers JE, Kenny LC, McCowan LM, . Angiogenic factors combined with clinical risk factors to predict preterm pre-eclampsia in nulliparous women: a predictive test accuracy study. BJOG 2013 Sep;120(10):1215-23. PMID: 23906160.23906160
159 Macdonald-Wallis C, Silverwood RJ, de Stavola BL, . Antenatal blood pressure for prediction of pre-eclampsia, preterm birth, and small for gestational age babies: development and validation in two general population cohorts. BMJ 2015;351:h5948. PMID: 26578347.26578347
160 Woelkers D, Barton J, Dadelszen P, . [71-OR]: The revised 2013 ACOG definitions of hypertensive disorders of pregnancy significantly increase the diagnostic prevalence of preeclampsia. Pregnancy Hypertens 2015 Jan;5(1):38. PMID: 25787421.
161 Buhimschi IA, Nayeri UA, Zhao G, . Protein misfolding, congophilia, oligomerization, and defective amyloid processing in preeclampsia. Sci Transl Med 2014 Jul 16;6(245):245ra92. PMID: 25031267.25031267
162 Klein J, Buffin-Meyer B, Mullen W, . Clinical proteomics in obstetrics and neonatology. [Review]. Expert Review of Proteomics 2014 Feb;11(1):75-89.24404900
163 Smith CJ, Saftlas AF, Spracklen CN, . Genetic Risk Score for Essential Hypertension and Risk of Preeclampsia. Am J Hypertens 2015 May 23 PMID: 26002928.26002928
164 Navaratnam K, Alfirevic Z, Baker PN, . A multi-centre phase IIa clinical study of predictive testing for preeclampsia: improved pregnancy outcomes via early detection (IMPROvED). BMC Pregnancy & Childbirth 2013;13:226. PMID: 24314209.24314209
165 Cook NR. Use and misuse of the receiver operating characteristic curve in risk prediction. Circulation 2007 Feb 20;115(7):928-35. PMID: 17309939.17309939
166 Roberts JM, Bell MJ. If we know so much about preeclampsia, why haven't we cured the disease? J Reprod Immunol 2013 Sep;99(1-2):1-9. PMID: 23890710.23890710
167 Wright D, Akolekar R, Syngelaki A, . A competing risks model in early screening for preeclampsia. Fetal Diagn Ther 2012;32(3):171-8. PMID: 22846473.22846473
168 Cnossen JS, Morris RK, ter RG, . Use of uterine artery Doppler ultrasonography to predict pre-eclampsia and intrauterine growth restriction: a systematic review and bivariable meta-analysis. CMAJ 2008 Mar 11;178(6):701-11. PMID: 18332385.18332385
169 Nicolaides KH, Bindra R, Turan OM, . A novel approach to first-trimester screening for early pre-eclampsia combining serum PP-13 and Doppler ultrasound. Ultrasound Obstet Gynecol 2006 Jan;27(1):13-7. PMID: 16374755.16374755
170 Schmella MJ, Clifton RG, Althouse AD, . Uric Acid Determination in Gestational Hypertension: Is it as Effective a Delineator of Risk as Proteinuria in High-Risk Women? Reprod Sci 2015 Feb 24 PMID: 25717062.25717062
171 Meyer NL, Mercer BM, Friedman SA, . Urinary dipstick protein: a poor predictor of absent or severe proteinuria. Am J Obstet Gynecol 1994 Jan;170(1:Pt 1):t-41. PMID: 8296815.8296815
172 Waugh J, Maybury H, Shennan A. A prospective comparison of total protein/creatinine ratio versus 24-hour urine protein in women with suspected preeclampsia. Am J Obstet Gynecol 2004;191(3):1049-50. PMID: 15467588.15467588
173 Royal College of Obstetricians and Gynaecologists. Pre-eclampsia - Study group consensus statement. Royal College of Obstetricians and Gynecologists; 2003. http://www.rcog.org.uk/womens-health/clinical-guidance/pre-eclampsia-study-group-consensus-statement.
174 Lain KY, Roberts JM. Contemporary concepts of the pathogenesis and management of preeclampsia. JAMA 2002 Jun 26;287(24):3183-6. PMID: 12076198.12076198
175 Teune MJ, Bakhuizen S, Gyamfi BC, . A systematic review of severe morbidity in infants born late preterm. Am J Obstet Gynecol 2011 Oct;205(4):374-9. PMID: 21864824.21864824
176 Mishanina E, Rogozinska E, Thatthi T, . Use of labour induction and risk of cesarean delivery: a systematic review and meta-analysis. CMAJ 2014 Jun 10;186(9):665-73. PMID: 24778358.24778358
177 Broekhuijsen K, van Baaren GJ, van Pampus MG, . Immediate delivery versus expectant monitoring for hypertensive disorders of pregnancy between 34 and 37 weeks of gestation (HYPITAT-II): an open-label, randomised controlled trial. Lancet 2015 Mar 24 PMID: 25817374.25817374
178 Odendaal HJ, Pattinson RC, Bam R, . Aggressive or expectant management for patients with severe preeclampsia between 28-34 weeks' gestation: a randomized controlled trial. Obstet Gynecol 1990 Dec;76(6):1070-5. PMID: 2234715.2234715
179 Sibai BM, Mercer BM, Schiff E, . Aggressive versus expectant management of severe preeclampsia at 28 to 32 weeks' gestation: a randomized controlled trial. Am J Obstet Gynecol 1994 Sep;171(3):818-22. PMID: 8092235.8092235
180 Vigil-De GP, Reyes TO, Calle MA, . Expectant management of severe preeclampsia remote from term: the MEXPRE Latin Study, a randomized, multicenter clinical trial. Am J Obstet Gynecol 2013 Nov;209(5):425-8. PMID: 23954534.23954534
181 Ganzevoort W, Sibai BM. Temporising versus interventionist management (preterm and at term). Best Pract Res Clin Obstet Gynaecol 2011 Aug;25(4):463-76. PMID: 21376672.21376672
182 Duley L, Gülmezoglu AM, Henderson-Smart DJ, . Magnesium sulphate and other anticonvulsants for women with pre-eclampsia. Cochrane Database of Syst Rev 2010 Nov 10(11):CD000025. PMID: 21069663.21069663
183 Koopmans CM, Bijlenga D, Groen H, . Induction of labour versus expectant monitoring for gestational hypertension or mild pre-eclampsia after 36 weeks' gestation (HYPITAT): a multicentre, open-label randomised controlled trial. Lancet 2009 Sep 19;374(9694):979-88. PMID: 19656558.19656558
184 Pauli JM, Lauring JR, Stetter CM, . Management of gestational hypertension - the impact of HYPITATa. J Perinat Med 2013 Jul;41(4):415-20. PMID: 23399585.23399585
185 Spong CY, Mercer BM, D'Alton M, . Timing of indicated late-preterm and early-term birth. Obstet Gynecol 2011 Aug;118(2 Pt 1):323-33. PMID: 21775849.21775849
186 Churchill D, Duley L, Thornton JG, . Interventionist versus expectant care for severe pre-eclampsia between 24 and 34 weeks' gestation. Cochrane Database Syst Rev 2013 Jul 26(7):CD003106. PMID: 23888485.23888485
187 Pritchard JA. The use of the magnesium ion in the management of eclamptogenic toxemias. Surg Gynecol Obstet 1955 Feb;100(2):131-40. PMID: 13238166.13238166
188 Magpie Trial Follow-Up Study Collaborative Group. The Magpie Trial: a randomised trial comparing magnesium sulphate with placebo for pre-eclampsia. Outcome for women at 2 years. BJOG 2007 Mar;114(3):300-9. PMID: 17166220.17166220
189 Magpie Trial Follow-Up Study Collaborative Group. The Magpie Trial: a randomised trial comparing magnesium sulphate with placebo for pre-eclampsia. Outcome for children at 18 months. BJOG 2007 Mar;114(3):289-99. PMID: 17166221.17166221
190 Duley L, Meher S, Jones L. Drugs for treatment of very high blood pressure during pregnancy. Cochrane Database Syst Rev 2013 Jul 31;7:CD001449. PMID: 23900968.23900968
191 Too GT, Hill JB. Hypertensive crisis during pregnancy and postpartum period. Semin Perinatol 2013 Aug;37(4):280-7. PMID: 23916027.23916027
192 Abalos E, Duley L, Steyn DW. Antihypertensive drug therapy for mild to moderate hypertension during pregnancy. Cochrane Database Syst Rev 2014 Feb 6(2):CD002252. PMID: 24504933.24504933
193 National High Blood Pressure Education Program Working Group on High Blood Pressure in Pregnancy. Report of the National High Blood Pressure Education Program Working Group on High Blood Pressure in Pregnancy. Am J Obstet Gynecol 2000 Jul;183(1):S1-S22. PMID: 10920346.10920346
194 National High Blood Pressure Education Program Working Group. Report on high blood pressure in pregnancy. American Journal of Obstetrics and Gynecology 1990;163:1689-712.
195 Grzybowski M, Younger JG. Statistical methodology: III. Receiver operating characteristic (ROC) curves. Acad Emerg Med 1997 Aug;4(8):818-26. PMID: 9262704.9262704
196 Magee LA, von DP. Clinical risk prediction of pre-eclampsia. BMJ 2011 Apr 7;342:d1863. PMID: 21474516.21474516