# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this report: Iris Mabry-Hernandez, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Aaron B. Caughey, MD, PhD, Liona Poon, MBBS, MRCOG, MD(Res), and James M. Roberts, MD, who provided expert review; the National Institute of Child Health and Human Development, the U.S. Department of Veterans Affairs, and the Indian Health Service, who provided federal partner review; and Smyth Lai, MLS, Elizabeth Hess, ELS(D), Elizabeth O'Connor, PhD, Ning Smith, PhD, and Maya G. Rowland, MPH, at the Kaiser Permanente Center for Health Research.