# Chapter 4 Discussion

## Summary of Evidence

We reviewed externally validated multivariable models for predicting preeclampsia, most focusing on the prediction of early-onset disease, but did not identify a model with supporting evidence indicating readiness for clinical use. A few models had good discrimination (c-statistic ≥0.80), but CIs on estimates were wide, PPVs were low, and calibration statistics or plots were not provided, so it is not possible to determine likely performance in clinical use. As others have emphasized,^85,133^ at minimum predictive models must be externally validated and shown to have acceptable discrimination and calibration before they might be ready for clinical practice. Beyond that, it is desirable to determine the likely performance or clinical impact of these models.^134,135^ These evidence standards were not achieved by the currently available studies of predictive models in preeclampsia. Further, the serum markers and Doppler ultrasound tests used in the models require resource-intensive collection and evaluation using complex algorithms. Efforts are under way to externally validate models using more easily collected clinical history information.^136,137^

Although we found considerable evidence on the accuracy of protein urine screening at a single time point in pregnancy, the studies were conducted in only women with suspected preeclampsia and thus are not representative of women presenting for routine prenatal visits. Of the different protein urine tests that can be conducted with point-of-care urine samples, protein dipstick tests are easy and low cost, but we identified only four eligible studies, which had highly variable results. The accuracy of albumin:creatinine tests was high, but only two studies contributed evidence. The majority of the evidence on accuracy was for protein:creatinine ratio tests, which can be conducted using a variety of tools (e.g., automated dipstick or aliquot readers, laboratory assays), but high heterogeneity precluded summary generalizations about performance. While these tests are often evaluated as a potential alternative to 24-hour urine collection for diagnostic confirmation, they have also been proposed for use in routine screening, particularly to rule out proteinuria.^75^ The available evidence, however, does not facilitate conclusions about which point-of-care proteinuria test would be optimal for this purpose. There was considerable variation among tests, and the variation is difficult to explain given limitations in the evidence. Based on our findings and likely spectrum bias, we would expect quite variable and generally lower test accuracy performance in routine care of general prenatal care populations. Finally, no studies evaluated the performance of urine protein screening in the context of repeated testing, where false-negative results might be corrected over time.

### Preeclampsia Screening for Reducing Morbidity and Mortality

We found no evidence that directly compared health outcomes in a screened population compared with an unscreened population (Table 7). One large trial, conducted in 1996 in a large health maintenance organization, suggested a schedule of somewhat fewer prenatal risk assessment and screening visits (and thus blood pressure and urine screening tests), which resulted in similar maternal and infant health outcomes and patient satisfaction among selected women determined to be low risk for adverse birth outcomes. The extensive inclusion and exclusion criteria, including required initiation of prenatal care in the first trimester of pregnancy, limited the potential relevance of this large trial. Generally, women presenting for prenatal care in the first trimester of pregnancy differ from those presenting at later times, tending to have higher socioeconomic status, more planned pregnancies, and higher rates of health insurance.^138,139^ Even in this study conducted among insured women, 17 percent of women presenting for care were excluded because they made their first prenatal care visit after 13 weeks. The applicability of the study, conducted more than 20 years ago, in the context of updated diagnostic criteria and treatment algorithms may be limited for current clinical practice settings and populations. The study does, however, represent an important attempt to provide evidence for a specific screening approach relative to standard care.

Table 7 Overall Summary of Evidence by Key Question

Key Question | No. of Studies (k), No. of Observations (n), Design | Quality | Limitations^*^ | Consistency | U.S. Primary Care Applicability | Summary of Findings^†^
KQ1 | 0 | NA | NA | NA | NA | NA
KQ1a Preeclampsia screening effects on health outcomes | k=1 n=2,764 RCT | Fair | Differences in the number of visits between the control and intervention groups were not as pronounced as intended by the design (12.0 vs. 14.7 visits). Insufficient power to detect differences in rare adverse outcomes such as very low birth weight, eclampsia, and stillbirth. | NA | Low Low-risk women seeking prenatal care in the first trimester in a large U.S. health maintenance organization. Study published nearly 20 years ago; there have been changes to clinical practice; insured women presenting for prenatal care in the first trimester of pregnancy may differ from those presenting at later gestations. | Fewer prenatal care visits did not have a beneficial or harmful effect on rates of health outcomes or diagnoses of preeclampsia, but evidence has limited relevance to current clinical practice or population.
KQ2 Preeclampsia multivariable risk assessment | k=4 external validation studies 16 externally validated risk assessment models 5 externally validated models with good to excellent discrimination (c-statistic ≥0.80) n=541–3,066 Prospective cohort | External validation in prospective cohort studies addresses common sources of bias in model development, we therefore included all externally validated risk prediction models in our review^‡^ | Calibration was not reported for any of the models, and risk cutpoints were not established a priori Many prediction models were developed by the same team of investigators, and the Australian cohort external validation studies were not independent from that group | Moderate/low Only one of the models was validated in more than one population, with similarly low positive predictive value, but inconsistently reported discrimination and detection. | Moderate The validation of some of the models in a diverse cohort of U.S. women with singleton pregnancies seeking routine prenatal care would be potentially applicable, but the impact of the model in other settings and in clinical use has not been evaluated. | No externally validated model was supported by evidence of good performance or clinical benefits Important model performance statistics were not available. Positive predictive values were low.
KQ3 Harms of preeclampsia multivariable risk assessment | k=1 n=255 Prospective cohort study | Fair | The risk assessment tool used was not clearly described, risk assessment occurred alongside intensive counseling and changes to clinical care and was not clearly described—cannot disentangle effects of risk assessment and clinical care Insufficient power to assess differences in effects of risk assessment for false- negative results compared with others. | NA | Low Study was conducted in Spain and Italy among women undergoing aneuploidy screening The risk assessment tool is unlikely to be used in practice based on external validation in U.S. cohort.^99^ Specially trained midwives conducted the risk assessment counseling visit. | Anxiety was not different between women screened as low and high risk for preeclampsia, but study groups were not equivalent. Comparisons in anxiety levels for women screened false negative could not be ascertained due to the timing of outcome measurement and insufficient power.
KQ4 Effectiveness of screening tests in identifying women with preeclampsia | 0 | NA | NA | NA | NA | NA
KQ4a Diagnostic accuracy of urine tests for proteinuria | k=14 n=1,888 Diagnostic accuracy studies | Fair | Spectrum bias was high as studies were limited to those with suspected preeclampsia (e.g., de novo hypertension, ≥1+ dipstick) and not a broad range of pregnant women in primary care. High heterogeneity across studies; limited descriptions of tests and collection methods. Too few studies evaluating the diagnostic accuracy of dipsticks and albumin:creatinine spot urine tests to combine. | Moderate/Low Studies of protein:creatinine and albumin:creatinine spot urine tests had similar sensitivity and specificity, dipstick did not. | Moderate Six studies conducted in the United States; the remaining were conducted in European or South American countries with representative samples of pregnant women. All were conducted in women with suspected preeclampsia. | Protein:creatinine tests (k=12) had most evidence on test accuracy; sensitivity ranged from 0.65 to 0.96 and specificity from 0.49 to 1.00. Evidence of spectrum bias and high heterogeneity limit conclusions that can be drawn about test performance in routine clinical care. Dipstick urine tests least accurate (k=4). Sensitivity ranged from 0.22 to 1.00 and specificity from 0.36 to 1.00. Albumin:creatinine spot urine tests (k=2); sensitivity (0.94 and 1.00) and specificity (0.94 and 0.68).
KQ4b Effectiveness of different screening tests in identifying women with preeclampsia | 0 | NA | NA | NA | NA | No studies comparing the performance of different approaches to routine preeclampsia screening were identified. Within study comparisons from individual studies included for KQ4a provided limited evidence that: automated readings may be more accurate than visual; urine samples taken at different times of day have similar performance for the Albustix protein:creatinine test; and different assays used for evaluating 24-hour protein gold-standard give different results for test sensitivity.
KQ4c Effectiveness of different screening tests in identifying women at high or low risk for preeclampsia | 0 | NA | NA | NA | NA | NA
KQ5 Harms of preeclampsia screening | k=2 1 RCT n=2,764 1 before-after study n=1,952 | Fair | Insufficient power to detect differences in rare adverse outcomes, such as very low birth weight and stillbirth RCT powered to detect differences of 2% or more between groups, but 1% differences for some outcomes could be clinically important Before-after study found a statistical difference in the source of payment for care over the study period, suggesting secular changes over time | NA Only 2 studies, similar finding that reductions in routine preeclampsia screening did not increase adverse maternal and infant health outcomes. | Moderate The RCT was published nearly 20 years ago, and there have been changes to clinical practices in the U.S., where the original study was conducted. The before-after study was among primarily underserved and race/ethnic minority patients obtaining care in a hospital-based midwifery practice in the U.S. | No differences in maternal, delivery or perinatal/neonatal health outcomes when fewer preeclampsia screening visits during pregnancy^97^ or when urine testing conducted only when indicated (vs. routine urine screening).^115^ Limitations in the timeliness of the research^97^ and weakness in study design^115^ do not allow for strong conclusions about potential harms of different screening approaches to be made.

* Includes reporting bias.

† Includes precision.

‡ See methods for full explanation of the prediction model appraisal approach.

Abbreviations: KQ=key question; NA=not available; RCT=randomized, controlled trial.

Two fair-quality studies reporting on rates of adverse events with different screening protocols did not identify any harms of preeclampsia screening (Table 7). The 1996 trial of reduced prenatal visits found that preeclampsia diagnoses and related adverse outcomes did not differ with fewer screening visits. The difference in the number of visits between the two groups ultimately was not as large as the study had aimed to generate, however, and the study's age limits its value for current populations and practices. The study was also underpowered to detect rare but serious health outcomes related to preeclampsia. The other study^115^ provided some reassurance that there is no harm associated with a change in protocol when point-of-care urine tests are conducted for specific indications rather than on a routine basis, resulting in fewer tests on average. The before-after study design was subject to more potential threats to bias, including secular trends across the study period, than a randomized study. Reported differences in the study groups would tend to bias results in a conservative direction—toward worse preeclampsia-related outcomes in the indicated testing group—but this was not observed.

### Effectiveness of Routine Screening for Preeclampsia Detection

No studies directly evaluated the test accuracy of blood pressure or urine protein screening for detecting preeclampsia. In a screening test performance paradigm, evidence to answer KQ 4 would compare results from screening blood pressure measurements and protein urine tests with confirmatory gold standard diagnostic tests. These data would populate a test accuracy table for assessing sensitivity and specificity of the individual or combined use of these screening tests for detection of preeclampsia. Since screening for preeclampsia is ongoing throughout pregnancy and provided at multiple time points, screening test accuracy must consider the timing of the test, cumulative clinical results, or both. A single positive proteinuria screening test is followed up with other diagnostic tests and, if the result is not confirmed, routine screening continues. Estimating how often false-positive and false-negative readings occur for elevated blood pressure and proteinuria has not been a research priority, likely owing to the low-resource nature of the screening tests and the low risk to patients of the confirmatory tests (e.g., additional blood pressure measurements, repeat point-of-care urine tests, diagnostic urine tests).

Although multiple studies have tested the associations of continuous elevated levels of blood pressure and proteinuria with the likelihood of developing preeclampsia at future time points in pregnancy, these do not directly address questions about screening test effectiveness in detecting preeclampsia. High blood pressure is an important sign of preeclampsia,^44^ hence the importance of the current clinical practice of repeat measurement at clinical visits. The accuracy of individual blood pressure readings is optimized if conducted in accordance with guidance on clinical blood pressure measurement in general and during pregnancy.^140,141^

There is less evidence to support the relationship between proteinuria levels and adverse preeclampsia outcomes.^5,142^ Recent changes to the ACOG guidelines regarding the role of protein urine screening in the definition and management of preeclampsia highlight the importance of other signs and symptoms that might be used to diagnose preeclampsia in the absence of proteinuria.^1^ Because the disease is not well understood and unexpected cases of preeclampsia that are not preceded by high blood pressure do occur, in the absence of an alternative evidence-based screening strategy, this historically important and relatively inexpensive aspect of prenatal health care will likely continue. We found no evidence of harms and no evidence to evaluate whether the use of one type of urine protein screening test versus another contributes to improved pregnancy outcomes.

### Accuracy of Urine Screening Tests for Proteinuria

Most of the available evidence assessed how well point-of-care urine protein screening tests detect proteinuria, a diagnostic criterion for preeclampsia diagnosis, compared with the 24-hour collection gold standard. The most commonly studied test was the protein:creatinine test, which has been cited in recent diagnostic criteria as a reasonable alternative to 24-hour urine collection.^1,143^ The range of sensitivity and specificity was wide, and heterogeneity was high; sensitivity and specificity near 80 percent for studies using thresholds at or near 30 mg/mmol likely represents a best case scenario, but the high and largely unexplained heterogeneity limits conclusions. In routine prenatal care for women presenting outside of monitored study conditions, performance could be considerably lower and is likely to be more variable across clinical settings given the diversity in the tests available and 24-hour test assays. Our findings on the protein:creatinine test are consistent with those conducted by others in recent years.^75,142^ A review by Côté et al concluded that although this test was not sufficiently accurate to replace the 24-hour test for diagnostic confirmation, it does perform well enough to serve as a screening test to rule out significant proteinuria (excretion threshold of 0.3 g/day).^75^

Based on relatively limited evidence available on other point-of-care tests, quantitative rather than qualitative readings of various urine dipstick tests appear more accurate.^94^ In two studies, quantitative albumin:creatinine urine testing could obtain sensitivity and specificity in ranges similar to those of protein:creatinine tests. These two studies' populations exhibited a very different prevalence of proteinuria; one had less than 10 percent^106^ and the other had nearly 50 percent of participants with significant proteinuria, according to the 24-hour test.^94^ In both studies, however, albumin:creatinine testing had higher sensitivity and specificity values than those reported in studies of the protein:creatinine test. As in our own review, another recent review noted the limited evidence but also the potential promise of the albumin:creatinine test, deeming the test deserving of further investigation.^142^

Evidence on test performance of point-of-care urine screening tests is both statistically and clinically heterogeneous. Different assays for the 24-hour reference test, manufacturers of test kits and readers, laboratory procedures, and protocols for collection and reading of the index and gold standard tests could all contribute to the range of sensitivity and specificity observed. We sought to identify potential patterns in test performance based on these methodological characteristics but found few clear signals. The degree of spectrum bias, which is based on the extent to which preeclampsia was suspected, may have contributed to the heterogeneity in sensitivity, but the heterogeneity in specificity could not be explained. Limited information on the types of index tests and 24-hour assays used did not permit us to examine the role of different tests and procedures in performance.

None of the proteinuria test accuracy studies were conducted in a general primary care screening population of pregnant women. Instead, all of the available evidence was from pregnant women in the later part of the third trimester already identified with suspected preeclampsia and undergoing evaluation or diagnostic confirmation (Table 7). Tested populations were also predominantly white, further limiting the applicability of this review to women who bear a disproportionate burden of preeclampsia-related morbidity and mortality. Thus, the test accuracy estimates are subject to spectrum bias, wherein the higher pretest probability for the condition results in higher test performance.^96^ Furthermore, nine of the studies included were conducted among inpatients, where the fidelity to collection protocols is higher than that in routine outpatient care, where problems with 24-hour gold standard tests have been well articulated.^144, 145^ Incomplete collection and erratic patterns of protein excretion can influence test accuracy results, making the clinical feasibility and reliability of the standard not entirely “golden.” It is likely that the test performance results we obtained are an upper boundary for performance and that studies in general or high-risk populations that do not already have a positive screen result would be more informative.

Considered broadly, protein urine screening occurs throughout pregnancy and false-positive results may lead to greater surveillance or further confirmatory testing. As noted in the review by Morris et al,^142^ the implications of the sensitivity and specificity of tests depend on the clinical actions taken with positive and negative results. Additionally, test performance for both would likely improve when cumulative rather than single test performance is considered, as false- negative readings can later be identified as positive and false-positive findings become subject to disconfirmation with followup testing. Thus, maximizing single-test performance for a relatively inexpensive and noninvasive test has limited value.

### Effectiveness of Risk-Based Screening

We did not identify any studies that assessed the performance of different preeclampsia screening strategies with high- or low-risk women or compared screening effectiveness between women considered to be at high or low risk. We reviewed multivariable risk prediction models that could be useful for risk-based screening approaches or for targeting other clinical preventive services, such as aspirin prophylaxis for preeclampsia prevention. We identified 16 models externally validated in four studies that assessed the performance of multivariable risk assessment tools for use in pregnancy before 20 weeks' gestation (Table 7). Of the five models found to have good or better discrimination based on the c-statistic, two had high detection (10% false-positive rate), but all models had low PPVs. Importantly, information on model calibration was not provided for any of the risk prediction models, and we could not determine the likely performance or impact of the available validated risk prediction models that would be expected in routine clinical use. Two recent systematic reviews,^146,147^ several methodological critiques,^90, 148-150^ and recent guidance from ACOG^134^ support our assessment of the current state of the evidence aimed at developing a model for preeclampsia risk prediction.

Our review identified one small, fair-quality prospective cohort study that evaluated potential psychological harms of preeclampsia risk assessment using a multivariable risk assessment model (Table 7) and found no difference in anxiety before and after clinical risk assessment.^102^ A recent qualitative study, which analyzed in-depth interviews with women who had been identified as low or high risk using a published risk assessment tool,^151^ found that some women had strong negative perceptions of being labeled at high risk.^152^ We did not find any evidence on harms related to risk assessment for health or pregnancy outcomes.

Owing partly to the rarity and complexity of preeclampsia and partly to limitations in methodological rigor, the current evidence for preeclampsia risk prediction does not support conclusions regarding likely performance, benefits, or harms. Recent efforts to establish reporting guidelines for prediction models and the growing maturity of risk assessment in other clinical areas will likely improve efforts to develop and validate risk prediction tools for preeclampsia.^85^ All of the models we identified included clinical tests that are not routinely collected for all pregnant women in early pregnancy. While the collection of serum marker data might be feasible in the context of aneuploidy screening, first-trimester ultrasound scans to calculate the uterine artery pulsatility index for those who seek it are not currently recommended in routine prenatal care. The additional resources needed to conduct clinical tests and calculate risk might be worthwhile if there was a clear net benefit of a risk assessment tool relative to usual practice, where current risk assessment recommendations are based on established risk factors and the clinician's judgment.

### Evaluating Clinical Performance of Preeclampsia Risk Prediction

To inform clinical practice, determining the net effect of risk assessment and the clinical actions that follow is necessary.^133^ High sensitivity may be more important for preeclampsia risk assessment because false-negative results could be more detrimental than false-positive results;^149^ a lower risk threshold, lower PPV, and possibly low-dose aspirin prophylaxis may be reasonable to consider for heightened surveillance.^153^ Harms could occur among women misclassified as low risk, not offered aspirin prophylaxis, or assigned to lower-intensity prenatal care schedules. Heightened surveillance and allocation of aspirin to women at low risk for the disease could also lead to harms.

In the absence of studies comparing model-based risk assessment with usual care risk assessment, it is not clear whether a formal risk assessment algorithm would improve performance or health outcomes beyond currently recommended risk assessment practice.^133,135, 154^ The USPSTF has issued an evidence-based recommendation (grade B) for the use of low-dose aspirin (81 mg/day) to prevent preeclampsia and its associated morbidity and mortality.^46,155^ The recommendation specifies that benefits relative to potential harms are observed for women at increased risk of preeclampsia. The USPSTF, like NICE, provides a list of risk factors to assist clinicians in determining which patients are at elevated risk for preeclampsia (Table 2). These risk factors are based on the strongest epidemiologic associations and the most common risk factors used to select high-risk participants in trials of aspirin for the prevention of preeclampsia. These approaches to risk stratification might be improved on with further development of validated tools for combining individual risk factors into an algorithm to provide more personalized risk assessment, but as we noted above, no externally validated models we evaluated provided evidence of performance that supports their clinical use.

Comparing risk prediction model effectiveness with NICE and USPSTF clinical risk assessment criteria would help provide a means of evaluating relative performance and whether incremental gains are worth implementation costs.^135,154^ We identified a few risk prediction models that compared detection in the proposed model with detection that would be achieved for the same population using the NICE criteria^65,156-158^ based on maternal characteristics and maternal history (Table 2). A recent study by Wright et al reported better detection using a new (but not yet externally validated model) compared with the NICE guidelines for risk stratification.^156^ Although detection was higher with the model than with the NICE criteria (67% vs. 58%), models derived and tested in the same dataset tend to overestimate discrimination, and the observed difference may not be reproduced in external validation. We did not identify any studies comparing model performance with the risk factors in the USPSTF clinical considerations for assessing risk for purposes of low-dose aspirin prophylaxis.^46^

Another risk prediction model recently reported by Macdonald-Wallis et al employed two different general population cohorts to establish a model for predicting preeclampsia, preterm birth, and SGA neonates.^159^ The study more closely adhered to TRIPOD guidance for development and reporting of prediction modeling results, including provision of calibration plots for their best performing model. Because our review was scoped to identify models for use in the first half of pregnancy, this study was not included because the optimal model in external validation, for which calibration, recalibration, and classification were reported, included measures added to the model at 28 weeks' gestation and beyond. While not included in this review, our conclusions would not differ substantially with its findings. It does, however, represent an informative effort. First, the model proposed does not rely on serum markers or Doppler ultrasound measures, but instead uses common clinical history measures and an estimate of mean arterial pressure based on blood pressure measurements (i.e., SBP×2/DBP), which would be easily collected in primary care. Secondly, it is conceptually worthwhile to consider whether preeclampsia risk prediction might be beneficial on an ongoing basis across pregnancy, alongside screening. Clinicians may informally assess risk at each prenatal care visit based on the signs and symptoms they observe—with more or less concern that the patient is likely to develop preeclampsia, and decisions regarding additional visits or screening tests informed by these evaluations. The results of this model validation study do not provide evidence on how the proposed model would improve on current approaches.

The levels of discrimination and classification achieved with the proposed models are modest until adding the measurement of mean arterial pressure at 28 weeks' gestation, at which point the AUC is greater than 0.80 (c-statistic, 0.84 [95% CI, 0.79 to 0.88]).^159^ The AUC is highest when mean arterial pressure at 36 weeks is added to the model (0.88 [95% CI, 0.84 to 0.93]). Model calibration and recalibration plots and classification tables are reported for the model that includes the 28 weeks mean arterial pressure measurement. Similar to the included models in our review, the PPV was very low. Although models using the same approach were developed to predict preeclampsia-related health outcomes (i.e., preterm birth and SGA neonates), they had lower performance than for prediction of preeclampsia.

Despite better adherence to rigorous conduct and reporting of model development and validation, including a recalibrated model based on calibration plot observations, the clinical implications of the model remain unclear. The study authors conclude that the model could be used to risk stratify the clinical care of women who need more intensive monitoring from those likely to have a normal pregnancy. Whether the model would improve on current practices for adjusting the intensity of prenatal monitoring is unknown, however, since blood pressure readings at prenatal visits already serve as a key indicator of the need for closer monitoring. An accompanying editorial questioned what would be gained or lost with reduced monitoring that might be proposed for women with a low risk score using the model, particularly given other activities that occur in prenatal visits.^150^ Conversely, there is an absence of information on the harms of risk prediction that could occur for the many women unnecessarily assigned to heightened surveillance given the high false-positive rates of the prediction model. Without comparisons of proposed models with current clinical practices, the potential benefits and harms of risk prediction cannot be determined, even with clear reporting of validated models. Testing different prenatal care algorithms against usual care, possibly incorporating use of the best performing and most feasible models, would be valuable to the field.

An example is a nonrandomized impact study conducted by Park et al^118^ that tested whether risk prediction Model A would improve the clinical process for assigning women at high risk for preeclampsia to low-dose aspirin prophylaxis to improve health outcomes. The simulation resulted in a statistically significant reduction in early-onset preeclampsia cases (12 vs. 1 case; p=0.01). The findings are encouraging but are limited by substantial, unexplained differences in the demographic characteristics of the two cohorts that could introduce confounding. Secular changes over the study time period (April 2010 to June 2013) might also have influenced the results, as would the approaches to risk assessment and aspirin prophylaxis in the original comparison cohort. Similar work to assess the clinical impact of risk prediction tools using randomized study designs should be pursued, ideally, with comparisons with current usual care.

## Applicability

The only study we identified that compared different screening strategies in a randomized study was conducted more than 20 years ago in a large health maintenance organization. In the context of updated diagnostic criteria and management protocols for preeclampsia, application of this study to current clinical practice settings and populations is limited.

We did not identify any studies assessing the accuracy of urine protein tests in general prenatal care populations nor for the common practice of repeated testing over the course of pregnancy. The role of urine protein in the detection and diagnosis of preeclampsia is undergoing reevaluation as new guidelines and understanding of the disease process emerge. This may warrant consideration of different approaches to screening for women with hypertension in the absence of proteinuria in future reviews, as evidence accrues on the use of newer diagnostic criteria.

## Limitations of the Review

The absence of rigorous studies on different approaches to preeclampsia screening, including risk-based approaches to care, is the most notable limitation. Newer studies are needed, in the current population of prenatal care patients with higher prevalence of obesity and other preeclampsia risk factors, to improve the evidence base for conducting screening. Moreover, with recent changes to diagnostic criteria, additional screening tests for women with hypertension but not proteinuria require study to estimate potential clinical benefits, harms, and performance and to develop evidence-based approaches to screening.^160^

One reason for the absence of data on the test performance of screening with blood pressure and urine protein tests is the fact that these have until very recently also been the primary diagnostic criteria for the condition; thus, repeat tests to confirm initial readings are commonly conducted. The need to evaluate the proportion of women misclassified as having or not having preeclampsia at a single point in time, or even over the course of pregnancy, may be less important when the result of a false-negative is to continue screening, and the result of a false- positive is enhanced surveillance, also resulting in continued screening. The complexity of the condition and the limited tools currently available for screening may have necessarily focused scientific resources on efforts to better understand the pathogenesis and potential new disease markers. Advances in proteomics and genomics may yield better precursors and markers, as well as new treatments for preeclampsia.^161-164^

Multivariable risk prediction tools that have been developed have aimed to combine serum tests and ultrasonography measures with known clinical history risk factors. Only recently have efforts been undertaken to combine a more robust set of known maternal history risk factors into a prediction model,^136^ and this work has not yet been externally validated. Very large cohorts are needed to develop and test models for early-onset preeclampsia, when the risk of poor outcomes is greatest. Many of the studies we identified had very few cases to classify, so the CIs for performance estimates were wide. There are shortcomings in the literature on preeclampsia prediction modeling in transparency and completeness of reporting, as noted by others.^90,146^ In particular, the absence of calibration statistics limited our ability to comprehensively evaluate and compare model performance.^148^ AUC values do not provide a solid basis for determining how well, and at what level of risk, a risk prediction model would perform.^165^

Eleven included studies were pooled for meta-analysis of the accuracy of urine tests for protein:creatinine, with results indicating high, mostly unexplainable heterogeneity, which limited our ability to generalize the accuracy of test performance. Heterogeneity was due in part to the degree to which preeclampsia was suspected. A recent methodological review for diagnostic studies noted limitations in the methods for determining the overall degree of heterogeneity in test accuracy studies, in part because of the interrelatedness of sensitivity and specificity.^96^ The bivariate random-effects model can take these correlations into account, but interpretation is challenging and better approaches are needed.

## Future Research Needs

The complexity of preeclampsia and the variety of ways it can present with regard to timing, signs, and symptoms make it difficult to identify a highly effective and broadly applicable risk assessment and screening strategy.^10^ Studies aimed at testing risk assessment and screening algorithms are needed to provide a more robust evidence base with which to inform prenatal care screening practices. Large study populations are required to compare different approaches to screening and effects on maternal and perinatal health outcomes, as well as longer-term sequelae. Basic descriptive studies characterizing variations in current preeclampsia screening practices in different types of health care settings would be helpful for identifying alternative screening approaches to evaluate in clinical studies. Basic research into the pathophysiology of preeclampsia will also help identify better tools for risk assessment and screening. If preeclampsia is comprised of several distinct syndromes,^166^ new screening approaches will need to be developed to distinguish subtypes, especially those most likely to result in serious morbidity or mortality without intervention. If, as others have proposed,^156,167^ preeclampsia is a single condition with a spectrum of severity and speed of progression, it will remain important to identify the best tools and clinical protocols for capturing all cases as soon as they arise for enhanced monitoring and evidence-based treatment protocols. Additional risk assessment measures in the second half of pregnancy may further predict the likelihood of developing disease. For example, uterine artery Doppler measurement in later pregnancy^168,169^ and serum uric acid levels^170^ are potentially useful for identifying women at risk for adverse outcomes resulting from preeclampsia. Future validation of these techniques may help guide more individualized surveillance of women at highest risk.

Protein dipstick tests are an initial screening for preeclampsia in many health care settings and are used for diagnosis when other tests are not available. Urine dipstick tests for proteinuria have poor test performance,^171^ particularly with visual rather than automated readings.^94,172^ Further research on the extent to which these tests are used to guide clinical decisionmaking and whether variations in practice explain differences in health outcomes could inform investigations into best practices. Assessing the protein:creatinine ratio in point-of-care urine samples appears to have more evidence suggestive of better performance, but further evaluation of accuracy in general populations, and with repeat testing, could better estimate its optimal role for proteinuria detection for routine preeclampsia screening.

Recently published models based on maternal characteristics and clinical history may hold promise if external validation supports their reproducibility.^136,156^ These studies have focused on a larger set of health behaviors, clinical measurements, health history, and maternal characteristics. A model developed by North et al^136^ in the international cohort study Screening for Pregnancy Endpoints (SCOPE) sought a clinical tool for risk prediction for use at around 15 weeks' gestation in nulliparous women, based on clinical risk factors that could be easily collected in routine care. Based on an international cohort of healthy nulliparous women from New Zealand, Australia, the United Kingdom, and Ireland (n=3,529), the study methods more closely aligned with TRIPOD guidance. Overall, 5 percent of the cohort developed preeclampsia. The performance of the model was modest (c-statistic, 0.71) but was adjusted statistically with a 10-fold cross-validation technique to adjust for optimism/overfitting bias. Unlike the existing models we identified, the SCOPE model considered a larger set of potential predictors and found some predictive factors that were not included in previous algorithms, such as family history of coronary heart disease, vaginal bleeding during pregnancy for at least 5 days, and protective factors that decreased risk (e.g., high fruit intake, prior miscarriage with the same partner).

Given the heterogeneity of the disease, screening tools aimed at different subtypes of preeclampsia, once they are more clearly defined, and for different study populations, may be necessary. The SCOPE model would not be applicable to parous women entering prenatal care, but the majority of cases of preeclampsia occur among nulliparous women. Efforts to test and recalibrate a clinically feasible tool for other targeted or broader populations could be undertaken. Well-designed impact studies are needed to determine what level of performance improves on current clinical risk assessment practices using to compare usual care with more complex risk prediction model–based tools. Without these impact studies, the value of new instruments for improving processes of care and health outcomes cannot be quantified.

## Conclusion

There is limited evidence available to determine the health benefits and harms of preeclampsia screening or the test performance of different screening and risk assessment strategies over the course of pregnancy. Despite the lack of empiric evidence, routine preeclampsia screening as currently conducted in prenatal care (i.e., blood pressure measurement and urine protein testing as part of routine pregnancy monitoring) is an established and feasible practice that is unlikely to be harmful or expensive. This is particularly true since the result of a positive screening measurement is repeat or similar testing for diagnostic confirmation and determination of severity to inform management. For most cases that will not develop into severe preeclampsia, enhanced monitoring is the most common initial clinical management. Given the rarity of preeclampsia and the potentially devastating consequences, especially in early-onset disease requiring preterm delivery, the focus of scientific inquiry has emphasized understanding the complex condition to more accurately identify those who will develop severe disease.

The complex pathophysiology of preeclampsia and its diverse outcomes present challenges for research aimed at improving health outcomes through evidence-based risk assessment and screening strategies. Research on the effectiveness of longstanding screening practices may be a lower research priority relative to efforts to better define the condition; to understand its physiological and causal underpinnings; and to develop new markers, tools, or tests for early identification and disease treatment. Broadly considered, screening recommendations for preeclampsia, including prior USPSTF guidance, highlight the low resource requirements of screening for high blood pressure and proteinuria. Efforts to identify the patients most likely to have severe or early-onset preeclampsia hold promise for better targeting of enhanced screening and preventive interventions. None of the existing validated models to estimate preeclampsia risk are sufficiently supported by evidence of performance that would warrant clinical application to general populations of pregnant women. Additional development, validation, and implementation research is needed to derive a tool ready for preeclampsia risk assessment in routine prenatal care and define its uses for improving health outcomes.

Periodic blood pressure and proteinuria measurements are routinely collected in primary obstetric care. Because of the long history of use of blood pressure and urine protein screening for preeclampsia screening, few studies have assessed their benefits and harms. Changes to diagnostic criteria in conjunction with evolving evidence on preeclampsia pathophysiology may foster new opportunities for improving clinical practice.