# 3 Results

## Literature Search Results

We screened 10,082 abstracts and 378 full-text articles to identify 21 included studies reported in 35 publications (Appendix B Figure 1).^94,97-130^ We did not identify any studies that directly compared the effectiveness of preeclampsia screening in a screened population versus an unscreened population (KQ 1). We included one RCT^97^ on the benefits and harms of differing visit schedules for preeclampsia screening for both KQs 1a and 5 and one observational before-after study that assessed potential harms of different screening strategies (KQ 5).^115^ We identified four studies reporting on the external validation of preeclampsia risk prediction models (KQ 2)^98-101^ and a single observational study evaluating the harms of risk assessment (KQ 3).^102^ We did not identify any studies evaluating the effectiveness of screening tests for identifying women with preeclampsia (KQ 4). We included 14 studies examining the diagnostic accuracy of urine tests for proteinuria (KQ 4a), which included comparisons of the test accuracy of different approaches to urine protein screening (KQ 4b).^94,103-114,119^

## Results of Included Studies

### KQ 1 How Effectively Does Screening for Preeclampsia Reduce Maternal and Perinatal Morbidity and Mortality?

No studies directly compared the effectiveness of preeclampsia screening in a screened population versus an unscreened population.

### KQ 1a Does Effectiveness Differ by Screening Protocol or Preeclampsia Risk Status?

#### Summary

One RCT conducted among 2,764 “low-risk” insured women seeking prenatal care in the first trimester in the early 1990s found that five fewer scheduled prenatal care visits (and thus fewer preeclampsia screenings) did not result in worse birth outcomes. However, the difference in the number of visits between groups was smaller than intended and the power to detect differences was insufficient for some important health outcomes.

#### Evidence

One fair-quality RCT randomized 2,764 pregnant women, enrolled from 1992 to 1994, ages 18 to 39 years presenting for their intake visit in the first trimester to a routine number of prenatal care visits (14 visits) or a schedule of fewer visits (nine visits) (Appendix F Tables 1–3).^97^ A total of 2,328 women completed the study: 1,163 in the control group and 1,165 in the intervention group. The study sought to enroll “low-risk” women; the most common reasons for exclusion were: presenting too late for the first prenatal care visit (17% of women making their first visit arrived after 13 weeks' gestation), being outside the included age range, and having a previous high-risk obstetric condition or a medical condition. Past high-risk conditions included preterm delivery, preterm labor, abruption, severe preeclampsia, cesarean delivery (vertical incision), gestational diabetes, incompetent cervix, uterine anomaly, diethylstilbestrol exposure, isoimmunization, more than one second-trimester abortion, fetal anomaly, or SGA neonate. Current high-risk medical conditions included diabetes, chronic hypertension, drug or alcohol abuse, multiple gestation, conception through assisted reproductive technology, and large (≥4 cm) leiomyomata.

Routine prenatal care consisted of visits every 4 weeks between 8 and 28 weeks' gestation, then every 2 weeks until 36 weeks' gestation, then weekly until delivery, for a total of 14 prenatal care visits. For the intervention, the number of visits was reduced to nine; they occurred at 8, 12, 16, 24, 28, 32, 36, 38, and 40 weeks' gestation. In both groups, the initial visit consisted of routine blood analysis, Papanicolaou test, and gonorrhea and chlamydia screening; later tests included serum alpha-fetoprotein screening (15 to 18 weeks' gestation), gestational diabetes screening with the 1-hour glucose tolerance test and hematocrit (24 to 28 weeks' gestation), and antibody screening (28 weeks' gestation). Ongoing risk assessment occurred at each visit, which included blood pressure screening and urine testing for glucose and protein.

At baseline, there were no statistically significant differences between groups in maternal characteristics. During pregnancy, women in the control group had more health care visits in total (p<0.001), with a provider (p<0.001), and with a nurse (p=0.04) than did women in the intervention group, although the mean difference in the number of visits between the two study groups was smaller than intended (12.0 ± 4.2 vs. 14.7 ± 4.2; p<0.001). At the time of delivery, there were no statistically significant differences between groups in maternal outcomes (e.g., gestational diabetes, preeclampsia), delivery complications (e.g., preterm delivery, cesarean delivery, postpartum hemorrhage), or neonatal outcomes (e.g., birth weight, gestational age, stillbirth) (Table 3). At 6 weeks postpartum, there were also no statistically significant differences between groups in satisfaction with prenatal care. More women in the intervention group than the control group felt the number of prenatal care visits was “just right” (p=0.002). Overall, reducing the number of prenatal care visits did not clearly affect health outcomes.

Table 3 Differences in Health Outcomes During Pregnancy, at Time of Delivery, or 6 Weeks Postpartum (Key Questions 1a and 5)

Study, Quality | Category | Outcomes | Group | Results | Between-Group Difference
McDuffie, 1996^97^ Fair | Preeclampsia | Mild PE, n (%) | IG | 59 (5.1) | RR, 0.94 (95% CI, 0.78 to 1.14); p=0.74
McDuffie, 1996^97^ Fair | Preeclampsia | Mild PE, n (%) | CG | 66 (5.7) | RR, 0.94 (95% CI, 0.78 to 1.14); p=0.74
McDuffie, 1996^97^ Fair | Preeclampsia | Severe PE, n (%) | IG | 10 (0.9) | RR, 1.05 (95% CI, 0.68 to 1.62); p=0.41
McDuffie, 1996^97^ Fair | Preeclampsia | Severe PE, n (%) | CG | 9 (0.8) | RR, 1.05 (95% CI, 0.68 to 1.62); p=0.41
McDuffie, 1996^97^ Fair | Preterm birth | Preterm delivery <32 weeks, n (%) | IG | 10 (0.9) | RR, 1.11 (95% CI, 0.73 to 1.68); p=0.32
McDuffie, 1996^97^ Fair | Preterm birth | Preterm delivery <32 weeks, n (%) | CG | 8 (0.7) | RR, 1.11 (95% CI, 0.73 to 1.68); p=0.32
McDuffie, 1996^97^ Fair | Preterm birth | Preterm delivery <37 weeks, n (%) | IG | 73 (6.3) | RR, 1.08 (95% CI, 0.92 to 1.27); p=0.19
McDuffie, 1996^97^ Fair | Preterm birth | Preterm delivery <37 weeks, n (%) | CG | 63 (5.4) | RR, 1.08 (95% CI, 0.92 to 1.27); p=0.19
McDuffie, 1996^97^ Fair | Delivery complications | Abruptio placentae, n (%) | IG | 17 (1.5) | RR, 1.21 (95% CI, 0.90 to 1.64); p=0.13
McDuffie, 1996^97^ Fair | Delivery complications | Abruptio placentae, n (%) | CG | 11 (0.9) | RR, 1.21 (95% CI, 0.90 to 1.64); p=0.13
McDuffie, 1996^97^ Fair | Delivery complications | Apgar score at 5 minutes <7, n (%) | IG | 18 (1.6) | RR, 0.77 (95% CI, 0.53 to 1.10); p=0.95
McDuffie, 1996^97^ Fair | Delivery complications | Apgar score at 5 minutes <7, n (%) | CG | 29 (2.5) | RR, 0.77 (95% CI, 0.53 to 1.10); p=0.95
McDuffie, 1996^97^ Fair | Delivery complications | Chorioamnionitis, n (%) | IG | 9 (0.8) | RR, 0.90 (95% CI, 0.55 to 1.46); p=0.68
McDuffie, 1996^97^ Fair | Delivery complications | Chorioamnionitis, n (%) | CG | 11 (0.9) | RR, 0.90 (95% CI, 0.55 to 1.46); p=0.68
McDuffie, 1996^97^ Fair | Delivery complications | Placenta previa, n (%) | IG | 7 (0.6) | RR, 0.87 (95% CI, 0.50 to 1.52); p=0.70
McDuffie, 1996^97^ Fair | Delivery complications | Placenta previa, n (%) | CG | 9 (0.8) | RR, 0.87 (95% CI, 0.50 to 1.52); p=0.70
McDuffie, 1996^97^ Fair | Delivery complications | Postpartum hemorrhage with cesarean delivery, n (%) | IG | 2 (1.3) | RR, 0.77 (95% CI, 0.26 to 2.27); p=0.77
McDuffie, 1996^97^ Fair | Delivery complications | Postpartum hemorrhage with cesarean delivery, n (%) | CG | 3 (2.2) | RR, 0.77 (95% CI, 0.26 to 2.27); p=0.77
McDuffie, 1996^97^ Fair | Delivery complications | Postpartum hemorrhage with vaginal delivery, n (%) | IG | 32 (3.2) | RR, 0.98 (95% CI, 0.77 to 1.27); p=0.47
McDuffie, 1996^97^ Fair | Delivery complications | Postpartum hemorrhage with vaginal delivery, n (%) | CG | 33 (3.2) | RR, 0.98 (95% CI, 0.77 to 1.27); p=0.47
McDuffie, 1996^97^ Fair | Delivery complications | Preterm labor, n (%) | IG | 79 (6.8) | RR, 1.01 (95% CI, 0.86 to 1.18); p=0.44
McDuffie, 1996^97^ Fair | Delivery complications | Preterm labor, n (%) | CG | 77 (6.6) | RR, 1.01 (95% CI, 0.86 to 1.18); p=0.44
McDuffie, 1996^97^ Fair | Delivery complications | Preterm premature rupture of membranes, n (%) | IG | 38 (3.3) | RR, 1.00 (95% CI, 0.80 to 1.25); p=0.50
McDuffie, 1996^97^ Fair | Delivery complications | Preterm premature rupture of membranes, n (%) | CG | 38 (3.3) | RR, 1.00 (95% CI, 0.80 to 1.25); p=0.50
McDuffie, 1996^97^ Fair | Cesarean delivery | Cesarean delivery, overall, n (%) | IG | 151 (13.0) | RR, 1.04 (95% CI, 0.93 to 1.17); p=0.25
McDuffie, 1996^97^ Fair | Cesarean delivery | Cesarean delivery, overall, n (%) | CG | 140 (12.0) | RR, 1.04 (95% CI, 0.93 to 1.17); p=0.25
McDuffie, 1996^97^ Fair | Perinatal/neonatal mortality | Stillbirth, n (%) | IG | 5 (0.4) | RR, 1.00 (95% CI, 0.54 to 1.86); p=0.50
McDuffie, 1996^97^ Fair | Perinatal/neonatal mortality | Stillbirth, n (%) | CG | 5 (0.4) | RR, 1.00 (95% CI, 0.54 to 1.86); p=0.50
McDuffie, 1996^97^ Fair | Birth weight | Birth weight (g), mean (SD) | IG | 3,286 (520) | NR; p=0.66
McDuffie, 1996^97^ Fair | Birth weight | Birth weight (g), mean (SD) | CG | 3,295 (536) | NR; p=0.66
McDuffie, 1996^97^ Fair | Birth weight | Very low birth weight (<1,500 g), n (%) | IG | 7 (0.3) | RR, 1.08 (95% CI, 0.65 to 1.79); p=0.39
McDuffie, 1996^97^ Fair | Birth weight | Very low birth weight (<1,500 g), n (%) | CG | 6 (0.3) | RR, 1.08 (95% CI, 0.65 to 1.79); p=0.39
McDuffie, 1996^97^ Fair | Birth weight | Low birth weight (<2,500 g), n (%) | IG | 64 (5.4) | RR, 0.94 (95% CI, 0.78 to 1.12); p=0.76
McDuffie, 1996^97^ Fair | Birth weight | Low birth weight (<2,500 g), n (%) | CG | 72 (6.1) | RR, 0.94 (95% CI, 0.78 to 1.12); p=0.76
McDuffie, 1996^97^ Fair | Birth weight | SGA, n (%) | IG | 36 (3.1) | RR, 1.13 (95% CI, 0.91 to 1.41); p=0.16
McDuffie, 1996^97^ Fair | Birth weight | SGA, n (%) | CG | 28 (2.4) | RR, 1.13 (95% CI, 0.91 to 1.41); p=0.16
McDuffie, 1996^97^ Fair | Health care use during pregnancy | Total number of visits, mean (SD) | IG | 12.0 (4.2) | NR; p<0.001
McDuffie, 1996^97^ Fair | Health care use during pregnancy | Total number of visits, mean (SD) | CG | 14.7 (4.2) | NR; p<0.001
McDuffie, 1996^97^ Fair | Satisfaction with prenatal care at 6 weeks postpartum | Number of prenatal visits, just right | IG | 494 (89.2) | NR; p=0.002
McDuffie, 1996^97^ Fair | Satisfaction with prenatal care at 6 weeks postpartum | Number of prenatal visits, just right | CG | 473 (82.8) | NR; p=0.002
McDuffie, 1996^97^ Fair | Satisfaction with prenatal care at 6 weeks postpartum | Number of prenatal visits, too few | IG | 49 (8.8) | NR
McDuffie, 1996^97^ Fair | Satisfaction with prenatal care at 6 weeks postpartum | Number of prenatal visits, too few | CG | 6 (1.1) | NR
McDuffie, 1996^97^ Fair | Satisfaction with prenatal care at 6 weeks postpartum | Number of prenatal visits, too many | IG | 11 (2.0) | NR
McDuffie, 1996^97^ Fair | Satisfaction with prenatal care at 6 weeks postpartum | Number of prenatal visits, too many | CG | 92 (16.1) | NR
McDuffie, 1996^97^ Fair | Satisfaction with prenatal care at 6 weeks postpartum | Quality of prenatal care, excellent or good, n (%) | IG | 574 (97.5) | NR; p=0.67
McDuffie, 1996^97^ Fair | Satisfaction with prenatal care at 6 weeks postpartum | Quality of prenatal care, excellent or good, n (%) | CG | 587 (97.8) | NR; p=0.67
Rhode, 2007^115^* Fair | Preeclampsia | Preeclampsia/eclampsia, n (%) | IG | 23 (2.3) | NR; p=0.001
Rhode, 2007^115^* Fair | Preeclampsia | Preeclampsia/eclampsia, n (%) | CG | 36 (3.8) | NR; p=0.001
Rhode, 2007^115^* Fair | Preterm birth | Preterm delivery, n (%) | IG | 50 (4.9) | NR; p=0.14
Rhode, 2007^115^* Fair | Preterm birth | Preterm delivery, n (%) | CG | 72 (7.7) | NR; p=0.14
Rhode, 2007^115^* Fair | Cesarean delivery | Cesarean delivery, n (%) | IG | 181 (17.8) | NR; p=0.029
Rhode, 2007^115^* Fair | Cesarean delivery | Cesarean delivery, n (%) | CG | 173 (18.5) | NR; p=0.029
Rhode, 2007^115^* Fair | Other maternal morbidity | Cystitis, n (%) | IG | 33 (3.3) | NR; p<0.0001
Rhode, 2007^115^* Fair | Other maternal morbidity | Cystitis, n (%) | CG | 15 (1.7) | NR; p<0.0001
Rhode, 2007^115^* Fair | Other maternal morbidity | Gestational diabetes, n (%) | IG | 42 (4.2) | NR; p=0.82
Rhode, 2007^115^* Fair | Other maternal morbidity | Gestational diabetes, n (%) | CG | 81 (9.3) | NR; p=0.82
Rhode, 2007^115^* Fair | Other maternal morbidity | Gestational hypertension, n (%) | IG | 58 (5.7) | NR; p<0.0001
Rhode, 2007^115^* Fair | Other maternal morbidity | Gestational hypertension, n (%) | CG | 38 (4.1) | NR; p<0.0001
Rhode, 2007^115^* Fair | Other maternal morbidity | High blood pressure, n (%) | IG | 81 (8.0) | NR; p=0.0005
Rhode, 2007^115^* Fair | Other maternal morbidity | High blood pressure, n (%) | CG | 74 (7.9) | NR; p=0.0005
Rhode, 2007^115^* Fair | Other maternal morbidity | Pyelonephritis, n (%) | IG | 4 (0.40) | NR; p<0.0001
Rhode, 2007^115^* Fair | Other maternal morbidity | Pyelonephritis, n (%) | CG | 4 (0.40) | NR; p<0.0001
Rhode, 2007^115^* Fair | Other maternal morbidity | Asymptomatic bacteriuria, n (%) | IG | 67 (6.8) | NR; p=0.051
Rhode, 2007^115^* Fair | Other maternal morbidity | Asymptomatic bacteriuria, n (%) | CG | 79 (8.7) | NR; p=0.051
Rhode, 2007^115^* Fair | Other maternal morbidity | Urinary tract infection, n (%) | IG | 141 (14.2) | NR; p=0.043
Rhode, 2007^115^* Fair | Other maternal morbidity | Urinary tract infection, n (%) | CG | 140 (15.4) | NR; p=0.043

* Rhode, 2007 used statistical tests for noninferiority. A p-value <0.05 indicates rates are statistically equivalence (no greater than 0.04 in one direction).

Abbreviations: CG=control group; CI=confidence interval; IG=intervention group; NR=not reported; PE=preeclampsia; RR=relative risk; SD=standard deviation; SGA=small for gestational age.

### KQ 2 What Is the Effectiveness of Risk Assessment in Early Pregnancy for Identifying Women at High Risk for Preeclampsia?

#### Summary

We identified five multivariable risk prediction models whose external validation studies (k=4) indicated, based on the c-statistic, good or better discrimination. Three of the models (Models A, B, and C) aimed to predict early-onset preeclampsia (requiring delivery) and two to predict preeclampsia occurring or requiring delivery after 34 weeks (Models D and E). The models predicting early-onset preeclampsia included clinical indicators, serum markers, and the uterine artery pulsatility index as parameters on which risk prediction was based, whereas models for predicting later preeclampsia did not include serum markers. Detection (i.e., sensitivity of the risk-based prediction model at a 90% specificity cutpoint) was generally low (52% to 92%) with wide CIs, and PPV was low (4% to 39%) for all of the models. The relationship between the predicted probabilities and observed outcomes (calibration) was not reported, so we could not evaluate model performance with this important metric. There was no clear evidence of high performance or clinical benefits for any of the externally validated models.

#### Evidence

Seven articles reported on results for four external validation studies (for 16 models) (Table 4; Appendix B Figure 1; Appendix G).^98-101,116-118^ Six models were developed for prediction of preeclampsia requiring delivery before 34 weeks' gestation,^121,122,124,127,128,130^ one before 37 weeks' gestation,^120^ seven after 34 weeks' gestation,^123-127,129,130^ and two at any time.^120,126^ External validation of the five models in the Italian cohort^98^ was for prediction of preeclampsia diagnosed after 34 weeks' gestation, regardless of delivery status. An additional 11 articles reported on the model development studies related to these external validations.^120-130^ Each external validation study^98-101^ had at least one model with a c-statistic indicating discrimination of 0.80 or higher, with a total of five models meeting this standard (Table 5).^120,122,123,127^ Models were labeled A through E for clarity of communication.

Table 4 Study Characteristics of Preeclampsia Risk Prediction External Validation Studies (Key Question 2)

External Validation Studies | Oliveira 2014^99^ Baltimore, MD PE requiring delivery: <34 weeks' gestation (early) ≥34 weeks' gestation (late) | Park 2013^100^ Sydney, Australia PE requiring delivery: <34 weeks' gestation (early) | Skrastad 2014^101^ Trondheim, Norway PE requiring delivery: <37 weeks' gestation (early) <42 weeks' gestation (any) >34 weeks' gestation (late) | Farina 2011^98^ Bologna, Italy PE diagnosis: >34 weeks' gestation
Study design | Prospective cohort | Prospective cohort | Prospective cohort | Prospective cohort
Study population | Women with singleton pregnancies | Women with singleton pregnancies presenting for aneuploidy screening | Nulliparous women | Women with singleton pregnancies enrolled at screening visit for early diagnosis of chromosomal and other fetal abnormalities, and delivery in tertiary care center
Study period | 2007–2010 | April 2010–March 2012 | September 2010–March 2012 | December 2007–April 2010
Sample size (n) | 871–2,962 (model n depended on availability of variables needed for each predictive model) | 3,066 | 541 | 554
Outcome prevalence (%) | Early PE: 1.0–1.2 (10–30 cases) Late PE: 4.1–5.0 (78–116 cases) | Early PE: 0.4 (12 cases) | Any PE: 3.9 (21 cases) Preterm PE requiring delivery (<37 wks): 0.9 (5 cases) | Late PE: 7.0 (39 cases)
Funding | Diagnostic Technologies Limited and PerkinElmer | NR | Norwegian University of Science and Technology; National Center for Fetal Medicine | Ricerca Fondamentale Orientata

Abbreviations: PE=preeclampsia; wks=weeks.

Table 5 External Validation Performance of Five Preeclampsia Risk Prediction Models With Good or Better Discrimination (c-statistic ≥0.80) (Key Question 2)

| MODEL A: Poon 2010^127,**,††^ London, UK | MODEL A: Poon 2010^127,**,††^ London, UK | MODEL B: Odibo 2011^122^ St. Louis, MO | MODEL C: Akolekar 2013^120^ London and Gillingham, UK | MODEL D: Poon 2010^127,**,††^ London, UK | MODEL E: Onwudiwe 2008^123^ London, UK
Cohort study for external validation of model | Oliveira 2014^99^ Baltimore, MD | Park 2013^100^ Sydney, Australia | Oliveira 2014^99^ Baltimore, MD | Skrastad 2014^101^ Trondheim, Norway | Farina 2011^98^ Bologna, Italy | Farina 2011^98^ Bologna, Italy
Number of participants eligible for model validation cohort | 2,833 | 3,014 | 871 | 541 | 554 | 554
PE timing^*^ | PE requiring early delivery (<34 weeks) | PE requiring early delivery (<34 weeks) | PE requiring early delivery (<34 weeks) | PE requiring early delivery (<37 weeks) | Late PE diagnosis (>34 weeks) | Late PE diagnosis (>34 weeks)
% PE outcome (n cases) | 1.0 (29 cases) | 0.4 (12 cases) | 1.2 (10 cases) | 0.9 (5 cases) | 7.0 (39 cases) | 7.0 (39 cases)
c-statistic,^†^ (95% CI) | 0.80 (0.71–0.89) | 0.93 (0.92–0.94) | 0.86 (0.73–0.99) | 0.94 (0.86–1.00) | 0.93 (0.88–0.98) | 0.85 (0.78–0.93)
Calibration^‡^ | NR | NR | NR | NR | NR | NR
Detection,^§^% (95% CI) | 52 (NR) | 91.7 (61.5–98.6) | 80 (NR) | 80.0 (28.4–99.5) | 84.6 (73.3–95.9) | 74.4 (60.7–88.1)
PPV^║^ | 4.2 (2.6–6.5) | 3.6 (2.0–7.0) | 11.3 (5.3–21.5) | 6.8 (1.9–16.5) | 39.3 | 36.3
NPV^¶^ | 99.6 (99.0–100.0) | 99.9 (99.7–99.9) | 99.8 (99.0–100.0) | 99.8 (98.8–100.0) | 98.7 | 97.9
Model variables | Race, chronic HTN history, conception mode, parity, MAP, PAPP-A, Doppler ultrasound uterine artery pulsatility index | Race, chronic HTN history, conception mode, parity, MAP, PAPP-A, Doppler ultrasound uterine artery pulsatility index | Chronic HTN, PAPP-A, PP13, Doppler ultrasound uterine artery pulsatility index | Age, weight, height, race/ethnicity, personal PE history, mother PE history, parity, mode of conception, chronic health conditions, MAP, PAPP-A, PIGF, Doppler ultrasound uterine artery pulsatility index | Age, BMI, race/ethnicity, mother PE history, parity, MAP, Doppler ultrasound uterine artery pulsatility index | BMI, race/ethnicity, parity, personal PE history, MAP, Doppler ultrasound uterine artery pulsatility index

* Preeclampsia defined as requiring delivery, with the exception of the Farina external validation study, which defined the outcome as the diagnosis of preeclampsia.

† A test performance statistic (equivalent to AUC) used to assess discrimination, a model performance measure that refers to how well a model differentiates between those with and without the outcome.^83^

‡ A model performance measure that refers to how well predicted risks compare with observed outcomes, preferably evaluated graphically by calibration plots and supplemented by a formal statistical test (the Hosmer-Lemeshow test for logistic regression and its equivalent for Cox regression).^83^

§ Analogous to sensitivity. The percent of cases correctly classified based on a predefined false-positive risk threshold.^83^ Detection for preeclampsia in this table was based on a fixed 10% false-positive rate (risk cutpoint for 90% specificity), which was the most commonly reported.

║ A test performance statistic used to measure what proportion of patients who test positive have the disease; PPV not reported in the Farina external validation study and was calculated by hand.

¶ A test performance statistic used to measure what proportion of patients who test negative do not have the disease; NPV not reported in the Farina external validation study and was calculated by hand.

** Derived from the Fetal Medicine Foundation Algorithm.

†† Clinical history algorithm described in Poon 2010^65^ and Poon 2009.^128^

Abbreviations: AUC=area under the curve; BMI=body mass index; CI=confidence interval; DBP=diastolic blood pressure; HTN=hypertension; MAP=mean arterial pressure; NPV=negative predictive value; NR=not reported; PAPP-A=pregnancy-associated plasma protein A; PE=preeclampsia; PIGF=placental growth factor; PPV=positive predictive value; SBP=systolic blood pressure.

The external validation of models A through E was conducted using prospective cohort data collected in the United States by Oliveira et al (n=2,962),^99^ in Australia by Park et al (n=3,014),^100^ in Italy by Farina et al (n=554),^98^ and in Norway by Skrastad et al (n=541).^101^ The Farina and Park studies enrolled women with singleton pregnancies presenting for aneuploidy screening, the Oliveira study enrolled women with singleton pregnancies presenting for prenatal care in the first trimester, and the Skrastad study enrolled nulliparous women. All of the cohorts were enrolled sometime between 2007 and 2012.

The external validation study evaluating the performance of Models A and B within a U.S. cohort of women with singleton pregnancies presenting in the first trimester for prenatal care at one of four centers in Baltimore, MD, was identified as the most likely to provide results applicable to U.S. prenatal care patients.^99^ Of these two models, Model B had better discrimination and detection and had also been developed in a U.S. population by Odibo et al.^122^ Model B used clinical history, placental protein 13, pregnancy-associated plasma protein A, and the mean artery pulsatility index (c-statistic, 0.86) to predict preeclampsia-required delivery before 34 weeks' gestation. It was validated with a smaller subset of the available cohort (n=871; 29% of the 2,969 women in the external validation cohort) because not all women had data on one of the serum markers needed for the model. Model B was initially developed and internally validated in a cohort of women presenting for aneuploidy screening, where discrimination and detection were similar to the external validation results.^122^

Model A was the only risk tool externally validated in more than one setting.^99,100^ In the U.S. cohort validation study, discrimination was moderate (c-statistic, 0.80 [95% CI, 0.71 to 0.89]) and the detection (52%) and PPV (4.2%) were low based on 29 cases (1% incidence). The same model was externally validated in the Australian cohort of women with singleton pregnancies attending aneuploidy screening (n=3,014), where only 12 cases of early-onset preeclampsia occurred.^100^ In that cohort, discrimination was high (c-statistic, 0.93 [95% CI, 0.92 to 0.94]), as was the detection (91.7% [95% CI, 61.5 to 98.6]), but the PPV was low (3.6%). Model A was also evaluated in an observational study occurring alongside the Australian external validation cohort study to assess the impact of using the model to assign women to low-dose aspirin prophylaxis.^118^

High discrimination was seen for Model C when validated in a small Norwegian cohort of nulliparous women.^101^ The model was used to predict any preeclampsia requiring delivery before 37 weeks' gestation (c-statistic, 0.94 [95% CI, 0.86 to 1.00]). There were five cases of early-onset preeclampsia requiring delivery (0.9% incidence). Detection was 80 percent and the PPV was 6.8 percent. Models D and E used clinical history and uterine Doppler measures to detect later-onset preeclampsia; when validated with a small Italian cohort, they had good to excellent discrimination, with detection of 85 and 74 percent and PPVs of 39.3 and 36.3 percent, respectively.^123,127^

Information on model calibration was not provided in any of the model external validation studies, precluding a complete assessment of model performance. There were no randomized impact studies evaluating the effects of these models when used as risk assessment tools in clinical application relative to usual care.

### KQ 3 What Are the Harms of Preeclampsia Risk Assessment?

#### Summary

One fair-quality prospective cohort study (n=255) found no differences in anxiety before and after counseling on preeclampsia risk and categorization as high or low risk based on results of a multivariable risk prediction model. High-risk women were subject to changes in their clinical care, with usual care for the low-risk group. Measures of anxiety over time did not change but were collected from less than half of the study participants.

#### Evidence

We identified one fair-quality, prospective cohort study conducted in Spain that examined whether first-trimester risk assessment and clinical care protocols based on risk status increased anxiety in pregnant women (Appendix F Tables 1–3).^102^ Risk for early-onset preeclampsia requiring delivery before 34 weeks was assessed using a model developed in Spain^130^ and externally validated in a U.S. cohort ^99^ (Appendix G). Pregnant women screened as high risk were recruited and matched with the next low-risk screened woman in the first trimester screening unit (n=255; 135 low-risk, 120 high-risk).

After risk assessment, all participating women were provided counseling on the potential risks of preeclampsia. Women at high risk underwent a followup management protocol that included recommended daily intake of acetylsalicylic acid (150 mg) from the day of screening until 36 weeks' gestation and second-trimester ultrasonography at 20 to 22 weeks that included uterine artery Doppler velocimetry.^102^ There were no statistically significant differences in the demographic characteristics of women screened as high versus low risk at the enrollment visit.^102^

Anxiety levels were assessed within 1 hour post-counseling using a self-reported anxiety questionnaire (Spielberg State-Trait Anxiety Inventory [STAI]) to measure trait (STAI-T) and state (STAI-S) anxiety.^102^ Study participants completed the STAI-T on the day of preeclampsia screening (prior to risk counseling) and were asked to answer the STAI-S immediately after the counseling visit. In a subgroup of women (51 low-risk and 50 high-risk), anxiety levels were also measured during the second and third trimesters (data not shown).

At baseline, low- and high-risk women did not differ in STAI-T scores (41.2 [standard deviation (SD), 6.7] vs. 40.4 [SD, 8.1]; p=0.35).^102^ After risk assessment and counseling, STAI-S scores for low- and high-risk women were 35.0 (SD, 9.9) and 34.6 (SD, 10.1), respectively (p=0.77).^102^ The proportion of women with high anxiety was also not significantly different between the two groups (28/134 [20.7%] vs. 24/120 [20%]; p=0.88). Measurements of anxiety levels taken during the second and third trimesters indicated no differences in the low- and high-risk subgroups, but less than half of the baseline participants provided data for these comparisons (data not shown).^102^ Overall, first-trimester preeclampsia risk assessment and counseling did not increase maternal anxiety, but risk assessment was coupled with counseling for all women and changes in clinical care for high-risk patients.

### KQ 4 How Effectively Do Routine Screening Tests Identify Women With Preeclampsia?

We found no evidence to evaluate the effectiveness of routine screening tests in identifying women with preeclampsia. Such studies would have evaluated how accurately clinical blood pressure measurement or urinalysis identified women with the diagnosis of preeclampsia at that time. The only available evidence was for various screening approaches for establishing the presence of proteinuria (one diagnostic criterion for preeclampsia).

### KQ 4a How Accurate Are Different Point-of-Care Screening Tests for Proteinuria?

#### Summary

Fourteen studies evaluated the diagnostic accuracy of urine tests in detecting proteinuria compared with 24-hour urine collection (reference standard). All of the studies examined the test performance of protein urine testing in women with suspected preeclampsia. None considered accuracy in the context of repeated testing. The limited and variable evidence on test accuracy did not support conclusions about which test would perform best for routine screening. Twelve studies evaluated protein:creatinine test sensitivity (range, 0.65 to 0.96; I^2^=80.5%; 11 studies) and specificity (range, 0.49 to 1.00; I^2^=91.8%; 11 studies). Studies conducted among women with 1+ or higher dipstick protein at enrollment had higher test sensitivity than those conducted among women seen for other indications of suspected preeclampsia (e.g., de novo hypertension). Two studies evaluating albumin:creatinine urine tests had similarly high sensitivity (0.94 and 1.00) and disparate specificity (0.94 and 0.68). Four studies tested the accuracy of automated protein dipstick test (≥1+), with variable results—only one protein dipstick test had evidence of both specificity and sensitivity greater than 80 percent. Spectrum bias likely influenced all of the study results, so these are probably overestimates of the likely test performance in routine prenatal care.

#### Evidence

We identified 14 studies (four good-quality and 10 fair-quality) evaluating the accuracy of different screening tests for proteinuria (Appendix F Tables 1 and 2).^94,103-114,119^ Twelve studies evaluated protein:creatinine urine tests,^103-111,113,114,119^ two studies evaluated albumin:creatinine urine tests,^94,106^ and four studies evaluated urine protein dipstick tests (Figure 2; Table 6).^94,105, 106,112^ Most studies evaluated the test performance characteristics for significant proteinuria across a wide range of thresholds (Appendix F Table 4). The reference standard for inclusion was 24-hour urine collection; all studies used a urinary protein excretion threshold of 300 mg over 24 hours to diagnose significant proteinuria. The prevalence of significant proteinuria ranged from 8.7 to 93.8 percent (Appendix F Table 3). Four studies evaluated test performance characteristics for identifying severe proteinuria (e.g., urinary protein excretion threshold of ≥3,000 mg over 24 hours); all urine tests performed as well as expected and are not further discussed (Appendix F Table 5).^104,105,113,119^

Figure 2 Diagnostic Accuracy of Point-of-Care Tests for Proteinuria (Key Question 4a)

Note: One study^114^ is not plotted as it did not provide enough information to determine a 2×2 table.

Abbreviations: A=albumin; CI=confidence interval; Cr=creatinine; P=protein.

This figure displays two forest plots (i.e., sensitivity, specificity) of the diagnostic accuracy of point-of-care tests for proteinuria.

Table 6 Index Tests and Reference Standard Characteristics of Included Diagnostic Accuracy Studies (Key Question 4a)

Study, Quality | Index Test (Make, Manufacturer) | Index Test Sampling Methods | Index Test Machine and Assay | Index Test Operator and Reader | 24-Hour Ref Stand Collection Method | Ref Stand Machine and Assay | Ref Stand Operator and Reader
Index Test, Protein:Creatinine
Tun, 2012^110^ Fair | P/Cr spot test (NR) | Number of samples: 1 Initial urine specimen (which was otherwise discarded). Some had it collected from the timed specimen (24-hour) or immediately after the timed collection. | NR NR | NR, sent to Health Network Laboratory | Started at time of admission; collected in 2 consecutive 12-hour collections; total protein a combination of both 12-hour urine specimens | NR ADVIA total protein urine assay (modified Fujita method) | NR, sent to Health Network Laboratory
Stout, 2013^109^ Fair | P/Cr spot ratio (NR) | Number of samples: 1 Ratio assessment prior to initiation of 24-hour collection | NR Enzymatic creatinase | NR | First 24-hour urine collection was used for each patient. | NR Benzethonium chloride | NR
Wheeler, 2007^113^ Fair | P/Cr spot ratio (NR) | Number of samples: 1 Samples obtained at the beginning of the 24-hour urine collection | Johnson & Johnson Vitros 250 Biuret method (protein); 2-point rate method (creatinine) | NR | NR | NR NR | NR
Young, 1996^114^ Fair | P/Cr spot test (NR) | Number of samples: 1 Single voided specimen collected when patient emptied bladder to begin the timing of the 24-hour urine collection (in 66% of samples); otherwise, single voided sample collected after the completion of the 24-hour collection (34% of samples). No specimen collected as the first void of the morning. | Beckman analyzer Standard spectrophoto-metric technique | NR | No specimen collected as the first void of the morning. | NR NR | NR
Verdonk, 2014^111^ Good | P/Cr spot test (Albustix, Siemens Healthcare Diagnostics) | Number of samples: 3 Began at midnight with 5-mL aliquots saved for P/Cr testing from requested spontaneous voids at approximately 8 am, 12 pm (noon), and 5 pm; visually analyzed. | CREA plus, Roche Diagnostics Enzymatic assay (Cr), colorimetric assay (P) | NR | Began at midnight, nurses monitored for completeness and when errors occurred, the procedure was stopped and restarted at midnight the next day. | NR NR | NR
Sethuram, 2011^108^ Fair | P/Cr spot test (NR) | Number of samples: 1 10-mL sample of urine collected before 24-hour collection; avoided the first void sample. | Abbott Diagnostics analyzer Benzethonium chloride turbidometric method (protein); Jaffe method (Cr) | NR | Avoided the first void sample. | Abbott Diagnostics analyzer Benzethonium chloride turbidometric method (protein) | NR
Lamontagne, 2014^107^ Good | P/Cr spot ratio (NR) | Number of samples: 1 When women entered study, urinalysis, urine culture, and P/Cr calculated on same urine sample provided at any moment during the day before 24-hour urine collection; not collected with catheter. | Beckman Coulter multianalyzer with the Synchron LX system Colorimetric method using pyrogallol red-molybdate (P); Jaffe method (Cr) | NR | Inpatients instructed on how to proceed by a nurse, while ambulatory women given oral and written instructions; not collected with catheter. | Beckman Coulter multianalyzer with Synchron LX system Colorimetric method using pyrogallol red-molybdate (P); Jaffe method (Cr) | NR
Kyle, 2008^106^ Fair | P/Cr spot test (NR) | Number of samples: 1 Aliquot from midstream urine specimen before 24-hour, performed at health laboratory | Abbott Ci8200 Analyzer NR | Research midwife | 24-hour urine collection as an outpatient. Discard first void in the toilet and write date/time of the sample on the request form, all subsequent voids were collected. Final void collected 24 hours later and placed in the specimen container. | NR Benzethonium chloride assay | NR
Bhide, 2015^103^ Fair | P/Cr spot test (NR) | Number of samples: 1 Usually collected and sent to the laboratory on the day/time of presentation to day assessment unit (but if not, within 48 hours from attendance at no specific time of day), before 24-hour. Only data from the first attendance included in study. | NR Pyragallol red (protein), Jaffe kinetic method (Cr) | NR | 24-hour urine collection | NR Pyragallol red (protein) | NR
Dwyer, 2008^105^ Good | P/Cr spot test (NR) | Number of samples: 1 Obtained before 24-hour collection, taken immediately after 24-hour. All samples collected via clean catch unless the membranes had been ruptured, in which case specimens were captured by catheter. | Synchron LX Systems Pyrogallol red/molybdate (P) and Jaffe rate (Cr) | Laboratory technician | Most collected as outpatients, all samples collected via clean catch unless the membranes had been ruptured, in which case specimens were captured by catheter. | NR NR | Laboratory technician
Durnwald, 2003^104^ Fair | P/Cr spot ratio (NR) | Number of samples: 1 Random urine collection before initiation of 24-hour collection | NR Biuret reaction; modified Jaffe reaction | NR | Outpatients collected all urine in a container for 24 hours and returned it to the outpatient laboratory; inpatients who had vaginal bleeding and/or active labor were receiving Mg sulfate seizure prophylaxis, those who had delivered collected by Foley catheter. | NR NR | NR
Valdes, 2015^119^ Fair | P/Cr spot test (NR) | Number of samples: 1 Additional urine sample (15-20 mL) collected for storage at -20° C for quantification of P:Cr concentrations on completion of the study period | NR NR | NR | Upon admission, patients underwent a 24-hour proteinuria test. | NR NR | NR
Index Test, Albumin:Creatinine
Waugh, 2005^94^ Good | Dipstick Clinitek Microalbumin (automated) (Bayer) | Number of samples: 1 Early morning sample before the final 24-hour specimen was added to the 24-hour collection, a mixed 10-mL aliquot was removed for urinalysis. | Clinitek 50 Two semiquantitative immunoassays for albumin and Cr | NR | On waking, the first void was discarded and the sample started with the second urine specimen; the final specimen was the first void the following day. | NR Benzethonium chloride assay | NR
Waugh, 2005^94^ Good | Dipstick Microalbustix (visual) (Bayer) | Number of samples: 1 Early morning sample before the final 24-hour specimen was added to the 24-hour collection, a mixed 10-mL aliquot was removed for urinalysis. | NA Two semiquantitative immunoassays for albumin and Cr | Two observers | On waking, the first void was discarded and the sample started with the second urine specimen; the final specimen was the first void the following day. | NR Benzethonium chloride assay | NR
Waugh, 2005^94^ Good | DCA 2000 POC test (Bayer) | Number of samples: 1 Early morning sample before the final 24-hour specimen was added to the 24-hour collection, a mixed 10-mL aliquot was removed for urinalysis. Utilizes a cartridge system and 40 μL of sample. | NR Immunoturbidometric assay (albumin), colorimetric assay (Cr) | NR | On waking, the first void was discarded and the sample started with the second urine specimen; the final specimen was the first void the following day. | NR Benzethonium chloride assay | NR
Kyle, 2008^106^ Fair | Albumin:Cr spot test (DCA 2000, Bayer Healthcare LLC) | Number of samples: 1 Aliquot from midstream urine specimen before 24-hour; performed at antenatal clinic | NR NR | Research midwife | 24-hour urine collection as an outpatient. Discard first void into the toilet and write date/time of the sample on the request form, all subsequent voids were collected. Final void collected 24 hours later and placed in specimen container. | NR Benzethonium chloride assay | NR
Index Test, Protein Dipstick
Waugh, 2001^112^ Fair | Dipstick (BM-Test 5L, Boehringer Mannheim UK) | Number of samples: 2 Two 10-mL aliquots of thoroughly mixed urine from the 24-hour urine; removed for dipstick analysis and protein assays. | NR NR | Observer | Collections performed between 8 am and 8 am on consecutive days; women instructed regarding collection procedures. | ExcelGel with silver staining kit Benzethonium chloride or Bradford assay | NR
Kyle, 2008^106^ Fair | Dipstick (NR) | Number of samples: 1 Aliquot from midstream urine specimen before 24-hour | NR NR | Research midwife | 24-hour urine collection as an outpatient. Discard first void into the toilet and write date/time of the sample on the request form, all subsequent voids were collected. Final void collected 24 hours later and placed in specimen container. | NR Benzethonium chloride assay | NR
Waugh, 2005^94^ Good | Dipstick Multistix 8SG (visual) (Bayer) | Number of samples: 1 Early morning sample before the final 24-hour specimen was added to the 24-hour collection, a mixed 10-mL aliquot was removed for urinalysis. | NA NA | Two observers | On waking, the first void was discarded and the sample started with the second urine specimen; the final specimen was the first void the following day. | NR Benzethonium chloride assay | NR
Waugh, 2005^94^ Good | Dipstick Multistix 8SG (automated) (Bayer) | Number of samples: 1 Early morning sample before the final 24-hour specimen was added to the 24-hour collection, a mixed 10-mL aliquot was removed for urinalysis. | Clinitek 50 NR | NR | On waking, the first void was discarded and the sample started with the second urine specimen; the final specimen was the first void the following day. | NR Benzethonium chloride assay | NR
Dwyer, 2008^105^ Good | P/Cr automated dipstick (Iris test strips, IRIS Inc or Arcray Inc) | Number of samples: 1 Urinalysis; obtained before 24-hour collection, if a sample unavailable, taken immediately after 24-hour. All samples collected via clean catch unless the membranes had been ruptured, in which case specimens were captured by catheter. | Autoanalyzers 3′3″5′5″ tetrachlorophenol-3,4,5,6-tetrabromo-sulfophthalein (protein error of pH indicator) | Laboratory technician | Most collected as outpatients, all samples collected via clean catch unless the membranes had been ruptured, in which case specimens were captured by catheter. | NR NR | Laboratory technician

Abbreviations: Cr=creatinine; NR=not reported; P=protein; ref=reference; stand=standard.

All studies were conducted in pregnant women with suspected preeclampsia, which included those referred to 24-hour urine collection for suspected preeclampsia, chronic or de novo hypertension, and/or proteinuria (i.e., tested positive on at least one previous protein dipstick). Study participants were generally in their late 20s and early 30s and were evaluated near the end of their third trimester of pregnancy. The majority of studies were conducted in predominantly white populations; other racial/ethnic groups were underrepresented. Personal or family history of preeclampsia was not reported. Six studies were conducted in the United States,^104,105,109,110,113, 114^ four in the United Kingdom,^94,103,108,112^ one in New Zealand,^106^ one in Canada,^107^ one in Chile,^119^ and one in the Netherlands.^111^

Twelve studies evaluated the accuracy of protein:creatinine urine tests in 1,516 pregnant women (Figure 2).^103-111,113,114,119^ One study did not provide the raw data necessary for pooled analyses and we were unable to retrieve the data from the study authors, but the reported sensitivity and specificity are included in our results narrative.^114^ Only one study reported the make or manufacturer of the protein:creatinine urine test being evaluated (Albustix, Siemens Healthcare Diagnostics, Malvern, PA).^111^ Sensitivity of the protein:creatinine urine test ranged from 0.65 (95% CI not calculable)^114^ to 0.96 (95% CI, 0.88 to 0.99),^111^ with most studies reporting sensitivity greater than 0.81; the combined sensitivity (k=11) was 0.85 (95% CI, 0.78 to 0.90), with high heterogeneity (I^2^=80.5%) (Appendix F Figure 1). Specificity ranged from 0.49 (95% CI, 0.36 to 0.63)^110^ to 1.00 (95% CI, 0.16 to 1.00);^108^ the combined specificity (k=11) was 0.85 (95% CI, 0.72 to 0.92), with very high heterogeneity (I^2^=91.8%). In pooled ROC analysis (Appendix F Figure 2), the area under the curve (AUC) was 0.91 (95% CI, 0.88 to 0.93), with similar numbers of studies in the space above the curve and below. The dispersion of study data points reflects the considerable heterogeneity seen for both sensitivity and specificity and limits drawing summary conclusions about overall performance from the pooled ROC analysis.

To evaluate statistical and clinical heterogeneity, we examined the data using forest plots sorted by theoretically plausible factors. A correlation between test accuracy and the degree of likely spectrum bias was observed. Studies enrolling patients with a 1+ or higher dipstick result^103,108,111^ or including any patients already diagnosed with preeclampsia^110^ would likely be subject to greater spectrum bias than those recruiting all patients with 24-hour tests for suspected preeclampsia, regardless of indication.^105,107,109,119^ Three studies fell somewhere in the middle, where patients could be enrolled with a 1+ or higher protein dipstick reading but also for other specific indications (e.g., worsening hypertension) that did not require a positive protein dipstick result.^104,106,113^ Sorting by the population enrolled, we observed that most of the highest sensitivities were in studies that enrolled only patients with a positive dipstick test; differences between groups were statistically significant in meta-regression (Appendix F Figure 3). Heterogeneity was low after adjustment for enrollment criteria (I^2^=15.9%). For specificity, however, these differences did not explain the high statistical heterogeneity, nor were alternative explanations found. Poor reporting across the included studies on the specific type of test assay limited our ability to evaluate the possible contribution of the index test used against the observed heterogeneity.

Two studies evaluated the accuracy of albumin:creatinine urine tests in 321 pregnant women.^94, 106^ Both studies evaluated the DCA 2000 point-of-care system (Bayer Healthcare, Whippany, NJ) that estimates albumin:creatinine in 7 minutes from a 40-μL urine sample utilizing immunoturbidometric (albumin) and colorimetric (creatinine) assays. The samples were collected before the 24-hour urine collection was initiated^94^ or in the early morning before the final 24-hour specimen.^106^ Sensitivity was similar at the common threshold of 2.0 mg/mmol, but specificity differed (Figure 2). Sensitivity was 0.94 (95% CI, 0.85 to 0.98) and specificity was 0.94 (95% CI, 0.87 to 0.98) in the good-quality study of 171 pregnant women (45% significant proteinuria).^94^ In the fair-quality study of 150 pregnant women (8.7% significant proteinuria), sensitivity was 1.00 (95% CI, 0.75 to 1.00) and specificity was 0.68 (95% CI, 0.59 to 0.76).^106^ This study also evaluated the albumin:creatinine urine test at two other thresholds (3.5 and 8.0 mg/mmol) and found similar sensitivity (1.00) and higher specificity than for studies using the 2.0 mg/mmol threshold (0.88 and 0.96, respectively) (Appendix F Table 4).

The good-quality study in 171 pregnant women also evaluated the Microalbustix and Clinitek albumin:creatinine urine dipsticks (Bayer Healthcare, Whippany, NJ).^94^ The Microalbustix dipstick was read visually by two observers, while the Clinitek dipstick could only be read on the Clinitek 50 urine chemistry analyzer. The visually read Microalbustix dipstick had lower sensitivity (0.49 [95% CI, 0.38 to 0.61]) than the automated Clinitek dipstick (0.58 [95% CI, 0.47 to 0.70]) but identical specificity (0.83 [95% CI, 0.74 to 0.90]) (Appendix F Table 4).

Four studies evaluated the accuracy of protein dipsticks in 634 pregnant women with mixed test performance characteristics.^94,105,106,112^ None of the protein dipsticks were the same make or model; only the reference standard (benzethonium chloride [BEC] assay) was similar between studies. Two studies obtained the urinalysis sample before the initiation of the 24-hour collection,^105,106^ the other two studies used aliquots from the thoroughly mixed 24-hour collection.^94,112^ Sensitivity ranged from 0.22 to 1.00 and specificity ranged from 0.36 to 1.00 (Figure 2). Of these, only one study had both sensitivity and specificity greater than 0.80.^94^ This good-quality study of 171 pregnant women evaluated visual reading by two observers and automated reading using the Clinitek 50 urine chemistry analyzer of the Multistix 8 SG dipstick (Bayer Healthcare, Whippany, NJ).^94^ The visually read protein dipstick had a lower sensitivity (0.51 [95% CI, 0.39 to 0.62]) than the automated reading (0.82 [95% CI, 0.71 to 0.90]) but specificity was similar (0.78 and 0.81, respectively). Apart from that study, the others had very high sensitivity and low specificity or vice versa (Appendix F Table 4).

### KQ 4b How Effective Are Different Screening Protocols for Identifying Women With Preeclampsia?

#### Summary

There was no evidence evaluating the effectiveness of blood pressure or urine screening for identifying women with preeclampsia and no evidence to inform comparisons among various screening protocols using these tests. However, a few of the studies for KQ 4a on various screening approaches for detecting proteinuria, a diagnostic criterion for preeclampsia, reported on the effect of variations in urine sample collection, assay methods, and reading approaches for urine screening tests. On the basis of the included studies for KQ 4a, within-study comparisons suggest that automated rather than visually read tests have higher test performance, the time of day of testing is not predictive of performance for the protein:creatinine test, and the sensitivity of tests depends on the 24-hour test assay used.

#### Evidence

##### Visual Versus Automated Readings

One good-quality study compared visual and automated readings of protein dipsticks and albumin:creatinine urine tests in 171 pregnant women.^94^ Two trained observers, who were blinded to each other's readings, visually read the results of the tests and the same samples were then retested using the automated analyzers. For both types of tests, the visual reading had lower performance than the automated reading (Appendix F Table 4).

##### Time of Urine Sample Collection

One good-quality study evaluated the test performance characteristics of the Albustix protein:creatinine urine test when collected from 105 pregnant women in the morning (8:00 a.m.), afternoon (12:00 p.m.), and evening (5:00 p.m.).^111^ Using a protein:creatinine excretion threshold of 30 mg/mmol, there were no statistically significant differences in the sensitivity (p=0.12) and specificity (p=0.89) between timepoints (Appendix F Table 4).

##### 24-Hour Assay

One fair-quality study evaluated the test performance characteristics of the BM-Test 5L urine protein dipstick (Boehringer Mannhein, East Sussex, UK) and compared it with two standard qualitative protein assays using the pooled 24-hour urine collection (BEC assay and the Bradford assay) in 197 pregnant women with hypertension.^112^ The BEC assay is an immunoturbidometric assay that is the most frequently used method in clinical practice to assess proteinuria in a 24-hour collection aliquot.^131^ The Bradford assay is based on the ability of proteins in the urine to bind to Coomassie blue dye and is more frequently used in laboratories.^132^ The prevalence of significant proteinuria among 197 women varied greatly between assays (70.1% for BEC assay and 24.9% for Bradford assay); therefore, the sensitivity of the dipstick was markedly different between assays (0.22 vs. 0.57, respectively), while the specificity was similar (0.98 and 0.97, respectively) (Appendix F Table 4).

### KQ 4c How Should Women at High Risk for Preeclampsia Be Screened Differently From Women at Low or Average Risk?

We found no evidence that compared different screening strategies among women at high risk for preeclampsia versus women at low or average risk.

### KQ 5 What Are the Harms of Preeclampsia Screening and Do They Differ by Risk Status or Screening Protocol?

#### Summary

Two fair-quality studies were identified that reported on potential harms of different approaches to preeclampsia screening. Neither found evidence of harms, but both were underpowered to provide evidence on rare but important clinical outcomes.

#### Evidence

The fair-quality trial included for KQ 1a found no difference in birth outcomes (e.g., low birth weight, preterm birth, number of cesarean deliveries) with an intended reduction in the number of prenatal care visits from 14 to nine visits (Table 3).^97^ The difference in the mean number of visits was not as great as expected (12.0 visits in the intervention group and 14.7 in the control group; p<0.001). As previously noted, power was not sufficient to detect differences for rare outcomes related to preeclampsia, particularly serious adverse maternal events such as progression to eclampsia, organ failure, stroke, and death.

We also identified one fair-quality retrospective before-after comparison cohort study (N=1,952) that evaluated the differences in health outcomes after a change in the standard of care at a hospital-based nurse midwifery practice that primarily served low-income Hispanic women (74% of eligible study participants) from routine prenatal dipstick urine testing to “clinically indicated” urine testing (Appendix F Tables 1–3).^115^ All women in the study received urine tests at their first prenatal visit, but women giving birth before August 15, 2002 (n=933) received routine urine screening with chemical reagent strips testing for bacteria or protein at all subsequent visits, whereas women giving birth after August 15, 2002 (n=1,019) had subsequent urine screening only when certain conditions were indicated (symptoms of a urinary tract infection; severe vomiting; weight loss ≥0.9 kg since previous visit; SBP ≥140 mm Hg; DBP ≥90 mm Hg; or a condition requiring periodic urine testing, such as chronic hypertension or renal disease). Women who were enrolled before but gave birth after August 15, 2002 were excluded (n=570). The two cohorts delivering before and after the practice change were similar in terms of baseline characteristics except for insurance payment source (p<0.0001).

Women in the routine urine testing group had used an average of 7.8 (range, 0 to 19) chemical reagent strips—equivalent to the number of tests—while women in the indicated testing group had used an average of 1.4 (range, 0 to 16). Among the indicated testing group, the reasons for urine testing were urinary tract infection or vaginitis symptoms (31.5%) and elevated blood pressure or significant preeclampsia-related symptomatology (35.6%).

Since the purpose of the study was to evaluate whether changes in the urine screening approach were safe (i.e., did not change preeclampsia or other adverse condition diagnosis rates or other health outcomes), statistical tests were designed to evaluate noninferiority; thus, statistically significant p-values indicated equivalent diagnosis rates between the two groups (Table 3). These results suggest there were no differences in diagnosis rates of preeclampsia/eclampsia, high blood pressure, or gestational hypertension or in number of cesarean deliveries. Preterm delivery rates were not equivalent (p=0.14) but were lower with indicated testing (7.7% with routine testing vs. 4.9% with indicated testing). Overall, there was no evidence of reduced diagnosis of preeclampsia or adverse health outcomes when changing from routine to clinically indicated urine testing. There was also no evidence suggesting underdiagnosis of adverse outcomes related to urinalysis for bacteriuria.