# 2 Methods

## Scope and Purpose

This report will be used by the USPSTF to update its 1996 recommendation on screening for preeclampsia and was developed using standard USPSTF procedures.^76^ Investigators in collaboration with the USPSTF and the Agency for Healthcare Research and Quality (AHRQ) created an analytic framework incorporating the KQs and outlining the patient populations, interventions, outcomes, and potential adverse effects for this review (Figure 1). The target population includes pregnant women, including adolescents. All KQs include studies of high- and low-risk populations unless otherwise specified.

Figure 1 Analytic Framework

This figure depicts the analytic framework, which outlines key questions addressed and the evidence covered in the evidence review, including populations, risk assessment, screening strategies and their effects on health outcomes. On the left, the population of interest is specified as asymptomatic pregnant women. Moving from left to right, the figure depicts risk assessment to identify women at high or low/normal risk for preeclampsia (key question 2). This risk assessment may result in harms (key question 3). Next, the figure considers the effectiveness of screening tests (e.g., blood pressure, proteinuria) for identifying women with preeclampsia (key question 4). Screening may result in harms (key question 5). The overarching question (key question 1) of the framework considers the association between screening and maternal and perinatal health outcomes.

We sought high-level evidence on the value of screening for preventing health outcomes compared with no screening (KQ 1) and comparing different approaches to screening (KQ 1a). We also reviewed multivariable tools for assessing the risk of preeclampsia that could be used to identify women for whom screening and clinical care could differ (KQ 3). Evidence on the performance of routine screening tests for detecting preeclampsia (KQ 4) and on harms of risk assessment (KQ 3) and screening (KQ 5) were also reviewed to balance any negative, inadvertent effects that clinical screening might incur.

## KQs and Analytic Framework

An analytic framework (Figure 1) and five KQs (listed below) were developed in consultation with USPSTF members.

1. How effectively does screening for preeclampsia reduce maternal and perinatal morbidity and mortality?
  a. Does effectiveness differ by screening protocol (e.g., tests used, timing of tests, rescreening intervals) or preeclampsia risk status?
2. What is the effectiveness of risk assessment in early pregnancy for identifying women at high risk for preeclampsia?
3. What are the harms of preeclampsia risk assessment?
4. How effectively do screening tests (e.g., blood pressure, proteinuria) identify women with preeclampsia?
  a. How accurate are different screening tests for proteinuria?
  b. How effective are different screening protocols (e.g., instruments, test procedures, timing of tests, rescreening intervals) for identifying women with preeclampsia?
  c. How should women at high risk for preeclampsia be screened differently from women at low or average risk?
5. What are the harms of screening for preeclampsia and do they differ by risk status or screening protocol?

## Data Sources and Searches

We conducted an initial search for existing systematic reviews published from 1995 to February 17, 2014, in MEDLINE, PubMed, the Database of Abstracts of Reviews of Effects, the Cochrane Database of Systematic Reviews, and the Centre for Reviews and Dissemination Health Technology Assessment. We also reviewed systematic reviews and reports published by AHRQ, British Medical Journal Clinical Evidence, the Institute of Medicine, Clinical Key, DynaMed, and NICE. The literature search strategies can be found in Appendix B.

We performed comprehensive literature searches for primary literature in the MEDLINE, PubMed, and Cochrane Central Register of Controlled Trials databases from 1990 through September 1, 2015 (Appendix B). We excluded studies published before 1990, as changes in diagnostic criteria and treatments made data from the preceding era less applicable to practices in the past 25 years. Before 1990, relative increases in blood pressure or mean arterial pressure and the presence of edema were included in the diagnostic criteria, so those screening approaches would not be applicable to current practices or the disease definition. Moreover, important developments in the prevention of eclampsia with magnesium sulfate and in the treatment of early-preterm babies with lung surfactants occurred in the late 1980s and early 1990s, changing the balance of harms and benefits with regard to health outcomes for different preeclampsia screening and management strategies. Nevertheless, we remained attentive to the possibility that a landmark study predating 1990 could be relevant to our review and therefore included references from the 1996 USPSTF report. We reviewed reference lists of relevant studies and reviews to identify additional potentially relevant studies that were not identified by our literature searches. Additional references were obtained from expert reviewers.

## Study Selection

Two investigators independently reviewed titles and abstracts using an online screening platform, Abstrackr.^77^ The same investigators reviewed full-text articles against prespecified inclusion and exclusion criteria (Appendix B Table 1).

The diagnostic criteria for preeclampsia have changed over time and vary worldwide (Appendix C).^78^ Any standard diagnostic criterion for preeclampsia was allowed, as defined by the study. For evidence on KQs pertaining to the benefits and harms (KQs 1 and 5) of preeclampsia screening for maternal, fetal, and infant health outcomes and the accuracy of screening for detecting women with preeclampsia (KQ 4), we considered studies of screening occurring from 20 weeks' gestation until delivery, since widely used diagnostic criteria for preeclampsia specify that screening occur after 20 weeks' gestation.^1,79^ For KQs relating to risk assessment (KQs 2 and 3), we included studies evaluating risk assessment tools applied in the first 20 weeks of pregnancy, prior to the onset of disease as defined by the diagnostic criteria for preeclampsia. One purpose of risk assessment would be to identify high-risk patients who are eligible for low-dose aspirin prophylaxis, which may be more beneficial when begun early in the second trimester.^80,81^ Eligible study populations were pregnant women without a diagnosis of preeclampsia and asymptomatic for the condition. We did not exclude studies that included pregnant women with common chronic conditions often seen in primary care settings (i.e., chronic hypertension and diabetes mellitus) or those at elevated risk for preeclampsia. We did, however, exclude studies that solely focused on women seeking high-risk obstetric care, infertility treatment, inpatients, and other nongeneralizable populations with select preexisting health conditions.

Health outcomes considered for KQ 1 were any benefits or harms related to maternal, fetal, or infant health. We placed priority on health outcomes known to be directly related to preeclampsia, such as eclampsia, HELLP syndrome, organ damage or failure, fetal growth restriction, preterm delivery, low birth weight, stillbirth, and placental abruption, some of which are associated with both short- or long-term health and developmental consequences.

Screening and risk assessment interventions considered were point-of-care tests, measures, and evaluations conducted in routine primary prenatal care. For screening, point-of-care blood pressure measurements using manual or automated devices and point-of-care urine tests for proteinuria with qualitative, quantitative, visual, or automated readings were included. When assessing the diagnostic accuracy of point-of-care urine tests used to detect proteinuria (KQ 4a), we excluded studies that did not use a 24-hour urine test as the reference standard. Secondary evaluations and tests used to assess preeclampsia severity or to confirm diagnosis were not included.

For risk assessment (KQ 2), our a priori inclusion/exclusion criteria aimed to include externally validated multivariable risk assessment tools that used patient history and routinely collected clinical measures (e.g., BMI, weight, blood pressure). We subsequently broadened our inclusion/exclusion criteria for risk assessment tools based on the low yield of potentially eligible studies, since most externally validated models to date also include serum markers, Doppler measures, or both. The serum marker and Doppler reading could be available for women who opt for aneuploidy testing in the first or early second trimester of pregnancy. Approximately 67 to 72 percent of pregnant women in the United States participate in aneuploidy screening,^82^ so these markers could be available for a large proportion of prenatal care patients.

Our inclusion criteria specified that we would exclude models that were not externally validated (i.e., models not tested in another population than the derivation study, assessing either performance or impact); internal validation studies are suited best to the population in which they were derived, and most biases of internal validation studies are in the direction of overly optimistic results.^83,84^ Testing the predictive algorithm in a new population, ideally with a new study team, gives an approximation of the performance to be expected with broader application of a tool.

In the hierarchy of risk prediction tool validation, randomized impact studies are most valuable for purposes of clinical implementation since they give evidence on the expected effect of clinical application of the tool on health outcomes.^85^ The ideal impact study design would compare standard care to care with the risk assessment tool in a randomized, controlled trial (RCT). The second-best level of evidence for a risk assessment tool comes from well-conducted external validation studies of a model in a different cohort (i.e., time, place, or both) by different investigators. External validation is important given that many of the threats to validity in model development studies lead to overestimation of model performance (e.g., overfitting, selection of parameters).

We did not include studies not published in English or in which the majority of participants were from countries that are not designated as having a very high Human Development Index, as defined by the United Nations Development Programme (2014).^86^ Studies conducted in other settings are less likely to offer evidence that would translate to the U.S. primary care setting in terms of the laboratory testing operations, screening modes, access and use of health care, treatments, and health outcomes. A list of excluded studies and reason for exclusion are provided in Appendix D.

## Quality Assessment and Data Abstraction

Two investigators independently assessed the quality of all included studies using criteria predefined by the USPSTF^87^ and supplemented them with other criteria from the Quality Assessment of Diagnostic Accuracy (QUADAS) II for diagnostic accuracy studies (KQ 4a),^88^ the Newcastle-Ottawa Scale (NOS),^89^ and the Before After Quality Assessment tool^89^ for observational studies (KQs 3 and 5) (Appendix B Table 2). The critical appraisal of risk prediction models (KQ 2) was developed for this review based on recent guidance on reporting on and quality appraisal for multivariable risk prediction models.^83,85^ Each included study that was appraised with a quality rating tool received a final quality rating of good, fair, or poor, and disagreements in quality were resolved through discussion. We excluded poor-quality studies (i.e., attrition >40%, differential attrition >20%, or other fatal flaws or cumulative effects of multiple minor flaws or missing information significant enough to limit our confidence in the validity of results). Good-quality studies met all or most of the assessment criteria. We rated studies as fair if they did not meet most of the good quality criteria.

One investigator abstracted data from all included studies into a Microsoft Access® database (Microsoft Corporation, Redmond, WA). A second investigator checked the data for accuracy. We abstracted study design characteristics, baseline population demographics, screening and risk assessment characteristics, health outcomes, adverse events, and diagnostic accuracy where applicable.

### Approach to Review of Clinical Risk Prediction Studies

Our approach to the appraisal of the external prediction models identified in our literature search was informed by recent guidance articulated in the Transparent Reporting of a Multivariable Prediction Model for Individual Prognosis or Diagnosis (TRIPOD) Statement^85^ and the Checklist for Critical Appraisal and Data Extraction for Systematic Reviews of Prediction Modeling Studies (CHARMS).^83^ We used domains defined in both the TRIPOD statement and CHARMS tool, as well as related methods reports,^83-85,90,91^ to evaluate the externally validated risk prediction tools we identified. No published tool for quality appraisal of external model validation studies is currently available; existing guidance is focused on risk of bias in model development and internal validation studies. Since we included only models that have been subjected to external validation, the bias risks outlined in CHARMS regarding problems with overfitting and overoptimistic performance were not as relevant, since these are generally addressed through the process of external validation. Therefore, we did not exclude any of the modeling studies for quality concerns and instead described the performance of all of the externally validated models we identified, providing detailed information on the validation studies and reported measures of model performance. More details on methodological considerations that informed our evaluation of risk prediction models are available in Appendix E.

### Measures of Risk Prediction Model Performance

Discrimination was consistently reported using the concordance index (c-statistic), or area under a receiver operator curve plot, which represents the probability that a case will have a higher risk score than a non-case will. The degree to which a model correctly orders true positive and true negative results is represented by this statistic. Discrimination is also described with sensitivity, specificity, positive predictive value (PPV), and negative predictive value (NPV). A priori risk-level cutpoints are optimal, but in this literature, “detection rates,” analogous to sensitivity, were commonly reported with risk cutpoints corresponding to a 10 percent false-positive rate (90% specificity).^83^

Calibration is another measure of model performance that reflects the extent to which the model predictions match the observed outcomes for individuals across risk levels. Goodness-of-fit tests (e.g., Hosmer-Lemeshow test) are sometimes used to report calibration, but calibration plots that graphically depict the observed outcome frequencies against predicted probabilities are more informative.^85^ Principles that are the basis for the TRIPOD statement indicate that discrimination and calibration are both “fundamental” for evaluating model performance in validation studies.^85^

## Data Synthesis and Analysis

We created summary evidence tables for each of the KQs that include important population characteristics and study design features.

Our analysis was primarily qualitative owing to the low number of included studies identified for each KQ. For KQ 2, we focused our reporting on models having at least good discrimination but extracted data from all models. In evaluating c-statistic values we defined values below 0.70 as inadequate, from 0.70 to 0.79 as adequate, and 0.80 or higher as good to excellent.^92^ Our description of externally validated models focused on those with good to excellent discrimination.

Quantitative meta-analysis was conducted only for KQ 4a. We calculated the diagnostic accuracy of point-of-care urine tests using the 24-hour urine collection as the reference standard (significant proteinuria defined as 300 mg with exertion over the 24-hour collection). We converted all urine excretion ratios to mg/mmol by converting any values to mg/g and multiplying this value by 0.113.^75^ We stratified results by the type of point-of-care index test: protein:creatinine, albumin:creatinine, and protein dipstick. For studies reporting multiple thresholds, we selected the most clinically acceptable cutoff for each urine test to be used when pooling (30 mg/mmol,^93^ 2.0 mg/mmol,^94^ and 1+, respectively). Due to the small number of studies evaluating the diagnostic accuracy of the albumin:creatinine tests and protein dipstick, we qualitatively described the results and visually displayed the data. For studies evaluating the diagnostic accuracy of protein:creatinine tests, we ran bivariate analyses to simultaneously examine sensitivity and specificity using the “midas” meta-analysis for diagnostic accuracy command in Stata version 13.1 (Stata Corp LP, College Station, TX). The pooled sensitivity and specificity, heterogeneity, and pooled receiver operator curve (ROC) were calculated when enough studies using the same index test and reference standard were identified (≥8 studies). Our strategy for exploring heterogeneity was to examine patterns in the results based on population, intervention, comparator, outcomes, timing, and setting factors that might be associated with different findings. Factors we expected to be important a priori included the index test threshold, clinical setting, and inclusion criteria. For example, we stratified women by the entry criteria of enrollment due to high blood pressure, enrollment due to high blood pressure or other indications for proteinuria screening, and previous positive (+1) urine protein dipstick result. We conducted random-effects meta-regression using the “metareg” procedure in Stata to statistically test the contribution of factors likely to explain heterogeneity based on the patterns observed in the stratified test accuracy results. We used the restricted maximum likelihood method with the Knapp-Hartung adjustment.^95^

We conducted sensitivity analyses, excluding studies that did not provide complete 2×2 results (e.g., studies reporting sensitivity and specificity only), those with cutoffs beyond 30 ± 5 mg/mmol, and those that were not at a threshold of 30 mg/mmol.^96^

Statistical meta-analysis was not performed for all outcomes because of methodological limitations of the studies and heterogeneity in study designs, interventions, populations, and other factors, but we did conduct them when appropriate. Studies included in prior reviews were reviewed for consistency with current results; however, lack of studies and differences in scope, KQs, and inclusion criteria limited aggregate synthesis with the updated evidence.

## Expert Review and Public Comment

A draft research plan for this review was available for public comment from May 22 to June 18, 2014. The draft version of this report was reviewed by content experts, USPSTF members, AHRQ Medical Officers, and federal partners.

## USPSTF Involvement

This research was funded by AHRQ under a contract to support the USPSTF. We consulted with four USPSTF liaisons during the development of the research plan. An AHRQ Medical Officer provided project oversight and reviewed the draft report. The USPSTF and AHRQ had no role in the study selection, quality assessment, or writing of the systematic review.