# 1 Introduction

## Condition Definition

Preeclampsia is a multisystem syndrome that is primarily defined by the development of new-onset hypertension, persistent systolic blood pressure [SBP] of 140 mm Hg or higher, or diastolic blood pressure [DBP] of 90 mm Hg or higher after 20 weeks' gestation in a woman with previously normal blood pressure.^1^ Although preeclampsia is usually accompanied by new-onset proteinuria, the American Congress of Obstetrics and Gynecology (ACOG) recently revised the diagnostic criteria for preeclampsia so that the presence of proteinuria for diagnosis was no longer required, noting that elevated blood pressure accompanied by other signs and symptoms is sufficient for diagnosis. These other signs are also included in new terminology proposed by ACOG to identify cases with severe features. Those severe features are: very high blood pressure, thrombocytopenia, renal insufficiency, impaired liver function, pulmonary edema, and cerebral or visual symptoms. The proportion of women who develop preeclampsia without proteinuria or who have proteinuria without hypertension preceding preeclampsia is unclear, with inconsistent definitions and approaches to measurement, and few studies examining these atypical presentations.^2,3^ Proteinuria levels among women diagnosed with preeclampsia, however, are not found to be consistently associated with adverse outcomes.^4,5^

Systems for diagnosing and classifying the severity of disease vary across professional societies and organizations, including ACOG, the American Society of Hypertension, and obstetrics and gynecology professional organizations in the United Kingdom, Canada, New Zealand, and Australia. Fetal complications of preeclampsia include intrauterine growth restriction (IUGR) and can occur due to placental perfusion problems. Preeclampsia often remains stable until delivery but sometimes can rapidly and unpredictably take a more serious turn. Severe hypertension, eclampsia, or HELLP syndrome (hemolysis, elevated liver enzymes, and low platelet counts) and organ and systemic complications can lead to maternal or fetal injury and death.^6,7^ For this reason, the term “mild preeclampsia” has been recommended against in the new ACOG diagnostic criteria.

Other hypertensive conditions overlap and can coexist with preeclampsia. Chronic hypertension is defined as predating the pregnancy and/or continuing beyond 12 weeks postpartum. Women with chronic hypertension are diagnosed with superimposed preeclampsia if proteinuria develops after 20 weeks' gestation. Pregnant women who develop hypertension during pregnancy (without proteinuria) that subsides within 12 weeks postpartum are defined as having gestational hypertension.

The concepts of early- and late-onset preeclampsia have been used to define different manifestations of the syndrome and may reflect differences in pathophysiology as well as long-term outcomes. These timing categories usually distinguish between cases developing prior to 34 weeks' gestation versus later in pregnancy.^8^ Early-onset preeclampsia is associated with more severe maternal and fetal outcomes and may be especially influenced by aberrations in the placentation process, particularly in the remodeling of the maternal uterine spiral arteries.^8,9^ Later-onset disease may also involve placental dysfunction, but it often occurs in women with proinflammatory maternal constitutional and environmental factors, such as multiple gestation, high body mass index (BMI), comorbid conditions, and chronic hypertension. Although pathophysiologic markers and processes underlying the development of preeclampsia are becoming more clearly understood, there remain considerable gaps in science that confer challenges for diagnosis and treatment.^10^

## Prevalence and Burden of Preeclampsia

Approximately 2 to 8 percent of pregnancies are affected by preeclampsia, which is the second leading cause of maternal mortality worldwide.^11,12^ In the United States, the rate of preeclampsia increased from 3.4 percent in 1980 to 3.8 percent in 2010,^13^ and was accompanied by a rise in severe cases, which increased from 0.3 percent in 1980 to 1.4 percent in 2010.

Based on the most recent analysis of the Centers for Disease Control and Prevention Pregnancy Mortality Surveillance System data, 9 percent of maternal deaths are directly attributed to preeclampsia and eclampsia.^14^ Complications of preeclampsia also indirectly contribute to approximately 1 in 10 pregnancy-related deaths attributed to anesthesia, cardiomyopathy, or placental abruption.^15^ Serious morbidity is far more common than mortality; it has been estimated that more than one third of severe obstetric morbidities are related to preeclampsia.^16^ Significant maternal morbidities include cerebrovascular bleeding, retinal detachment, and complications from HELLP syndrome, such as major organ damage and failure.^8^ Eclampsia occurs in approximately 1 to 2 percent of preeclampsia cases, with complications such as brain damage, aspiration pneumonia, pulmonary edema, placental abruption, disseminated coagulopathy, acute renal failure, cardiopulmonary arrest, and coma.^12^ Cohort data from obstetric patients attending 25 U.S. medical centers comprising the Maternal-Fetal Medicine Units Network in 2008 to 2011 indicated that at least 21 percent of severe maternal morbidity was related to hypertension-related complications.^17^ The prevalence of hospitalizations from severe preeclampsia or eclampsia rose from 9.4 to 12.4 per 1,000 deliveries in the United States between 1998 and 2006,^18^ and there is some recent indication that hospitalizations due to eclampsia may be falling.^19^

Preeclampsia also dramatically increases risks to the fetus or neonate. These risks include IUGR, small for gestational age (SGA), low birth weight, premature birth, oligohydramnios, placental abruption, low Apgar score, neonatal intensive care unit admission, stillbirth, and neonatal death.^6,20^ Because the treatment for preeclampsia is delivery, it is a leading cause of induced preterm birth and low birth weight. It has been estimated that preeclampsia is an indication in 6 percent of preterm births and 19 percent of medically indicated preterm births.^21^ Infants born before term (<37 weeks' gestation) are at increased risk of morbidity and mortality, with risks rising dramatically with earlier delivery. When preeclampsia occurs before 34 weeks, maternal and perinatal risks are greater and management decisions have to balance maternal and perinatal health risks. The majority of preeclampsia cases occur after 34 weeks, but morbidity and mortality is greater for early-onset disease.^22^

Obstetric interventions are more common in pregnancies complicated by preeclampsia, and can include induction of labor (preterm or term), intravenous magnesium sulfate treatment, and emergency or planned cesarean delivery. Early delivery interventions can improve maternal health and reduce some risks to the neonate, such as stillbirth, while increasing others, depending on the severity of disease and gestational timing.^23,24^ There is evidence that preeclampsia itself is associated with poor psychosocial outcomes, posttraumatic stress syndrome, and postpartum depression,^25-28^ with fetal or neonatal morbidity or mortality contributing to but not entirely accounting for the relationship.

In the United States, the prevalence of preeclampsia reveals marked disparities by race/ethnicity.^29-31^ The rate of pregnancy-related death is 4 times greater among non-Hispanic black women, and preeclampsia is a major contributor to this disparity.^32^ National data on chronic and gestational hypertension show the conditions are more common and increasing over time among non-Hispanic black women, least common among Asian/Pacific Islander and Hispanic women, and intermediate among non-Hispanic white women.^33^ Case fatality rates for preeclampsia are 3 times higher among black non-Hispanic women than among white women, contributing to the large mortality disparity.^34^ Approximately one third of the disparity in mortality from preeclampsia among black women stems from higher prevalence, and the remainder is due to a higher case fatality rate.^34^ Disparities in risk factors for preeclampsia, such as chronic hypertension, diabetes, and high BMI, contribute to a higher prevalence of preeclampsia among black women, and disparities in access to adequate prenatal care decrease opportunities to intervene before preeclampsia becomes more severe.^35^ Inadequate prenatal care is associated with higher case fatality rates for preeclampsia among all women, which is likely due to the reduced opportunity for monitoring, detection, and early intervention.^15,32^ Nevertheless, even in a large population (n=35,529) provided with early access to prenatal care, racial/ethnic disparities have been observed, with minority women experiencing higher rates of preeclampsia than non-Hispanic white women.^36^ Finally, recurrent preeclampsia in subsequent pregnancies is often more severe for black women than for white or Hispanic women.^37^

## Etiology and Natural History

Preeclampsia is a complex disease with multiple causes and interactions leading to its clinical manifestation. Its intractability to effective treatment (apart from delivery of the placenta) makes it an area of considerable scientific inquiry with important implications for women's health worldwide. The heightened risk of preeclampsia in first pregnancies and in women who undergo in vitro fertilization with donor eggs have led to numerous investigations regarding a potential role of the immune system and paternal genetic influences.^6^ Preeclampsia is generally understood to be an immunologic and inflammatory condition that involves the process of placentation, but the underlying causes, precipitating factors, and conditions are not fully understood.

Preeclampsia may develop through different processes that can occur either alone or in combination. “Placental” disease may lead to earlier onset and more severe disease, while “maternal” disease may result in later-onset disease.^7,8^ Placental preeclampsia is thought to arise from problems with the process of placentation whereby trophoblast cells fail to fully activate transformation of uterine spiral arteries (at about 12 to 16 weeks' gestation), resulting in placental ischemia. This relative ischemia and lowered placental perfusion could cause the release of damaging factors (e.g., cellular debris, oxidized lipids, antiangiogenic factors) into the maternal bloodstream, resulting in inflammation and oxidative stress. In contrast, maternal preeclampsia is thought to involve overactive inflammatory responses to normal placentation. Preexisting hypertension, diabetes, and other inflammatory conditions (e.g., lupus) as well as twin or higher-order pregnancies are thought to precipitate a systemic inflammatory response and oxidative stress process. Consistent with this theory, women with early-onset placental preeclampsia exhibit abnormal uterine artery ultrasound Doppler readings and placental morphology compared with women without preeclampsia or later-onset disease.^7,8,38^ Adding to the complexity, maternal and environmental factors may also contribute to the risk of developing placental preeclampsia.

Preeclampsia can occur without immediate apparent adverse health consequences for the mother or infant. Challenges in preventing and treating the disease are heightened by the difficulty in determining who will develop preeclampsia and go on to experience severe or life-threatening complications. Preeclampsia also may pose a longer-term risk factor for poor cardiovascular health in mothers and their offspring.^39^ The association may be explained by common risk factors, and it is unclear whether or not preventing preeclampsia would benefit the long-term cardiovascular health of women or children of mothers with preeclampsia is the subject of ongoing inquiry.

Despite intensive research, understanding of this complex disease is not complete. Most recently, the possibility that preeclampsia is a syndrome comprised of multiple subtypes has been proposed to explain its diverse etiology and unpredictable course.^40,41^

## Risk Factors

There are a number of well-established clinical and historical risk factors for preclampsia.^42^ Chronic health conditions with increasing prevalence in the United States, such as essential hypertension and diabetes, affect the risk for preeclampsia. Women with preexisting hypertension or new-onset hypertension in pregnancy are at elevated risk of developing preeclampsia.^43^ A recent systematic review of more than 50 studies, including nearly 800,000 pregnancies, estimated the incidence of superimposed preeclampsia among women with chronic hypertension to be 26 percent (95% confidence interval [CI], 21% to 32%).^44^ In pregnant women with preexisting diabetes, the incidence of preeclampsia increased from 18 percent in women without preexisting proteinuria or chronic hypertension to 28 percent when one or both of these conditions were present (odds ratio [OR], 1.75 [95% CI, 1.02 to 3.01]).^45^

Other risk factors based on medical history are also used for risk-stratified clinical preventive services. For example, the U.S. Preventive Services Task Force (USPSTF) recommends a pragmatic approach to identify patients at low, moderate, or high risk for preeclampsia in its recommendation on low-dose aspirin prophylaxis in pregnancy.^46^ The National Institute for Health and Care Excellence (NICE) risk assessment approach is similar (Table 2).^47^ High-risk pregnant women include those with a history of preeclampsia, multifetal gestation, chronic hypertension, type 1 or 2 diabetes, renal disease, or autoimmune disease.^46^ Moderate-level risk factors include nulliparity, obesity, family history of preeclampsia, sociodemographic characteristics such as African American race or low socioeconomic status, age, or personal history factors (including low birth weight, previous adverse pregnancy outcome, and a pregnancy interval of more than 10 years).^46^ A pregnant woman with a previous uncomplicated, full-term delivery is at lower risk for preeclampsia.^46^

Table 2 Factors for Clinical Assessment of Preeclampsia Risk^*^

American Congress of Obstetricians and Gynecologists (ACOG)^1^ | USPSTF Risk Assessment for Low-Dose Aspirin Prophylaxis^46^ | National Institute of Health and Care Excellence (NICE)^47^
Risk factors Primiparity Previous preeclamptic pregnancy Chronic hypertension, chronic renal disease, or both History of thrombophilia Multifetal pregnancy In vitro fertilization Family history of preeclampsia Type 1 or 2 diabetes mellitus Obesity Systemic lupus erythematosus Advanced maternal age (age >40 years) | High risk^†^ History of preeclampsia Multifetal gestation Chronic hypertension Type 1 or 2 diabetes Renal disease Autoimmune disease (i.e., systemic lupus erythematosus, antiphospholipid syndrome) Moderate risk^‡^ Nulliparity Obesity (BMI >30 kg/m^2^) Family history of preeclampsia Sociodemographic characteristics (African American race, low socioeconomic status) Age ≥35 years Personal history factors (e.g., low birth weight or small for gestational age, previous adverse pregnancy outcome, >10-year pregnancy interval) Low risk Previous uncomplicated full-term delivery | High risk^†^ Hypertensive disease during previous pregnancy Chronic hypertension Type 1 or 2 diabetes Chronic kidney disease Autoimmune disease (i.e., systemic lupus erythematosus, antiphospholipid syndrome) Moderate risk^‡^ First pregnancy Obesity (BMI ≥35 kg/m^2^) Family history of preeclampsia Age ≥40 years Pregnancy interval >10 years Multiple pregnancy

* Includes only risk factors that can be obtained from the patient medical history. Clinical measures, such as uterine artery Doppler ultrasound, may additionally be used by some clinicians to evaluate risk.

† The USPSTF and NICE recommend low-dose aspirin if the patient has ≥1 high-risk factors.

‡ The USPSTF recommends considering low-dose aspirin if the patient has several of the listed moderate-risk factors. NICE recommends low-dose aspirin if the patient has at least two moderate-risk factors.

Abbreviations: BMI=body mass index.

## Rationale and Strategies for Screening

Screening for preeclampsia occurs periodically throughout pregnancy for all women receiving prenatal care. The aim of screening is to identify and diagnose the condition early in its course, to allow closer monitoring and effective disease management. Blood pressure measurement and testing for proteinuria have long been routine primary care screening tools for preeclampsia, and are core components of the diagnostic criteria. The timing of prenatal care visits, and the inclusion of both of these tests at every visit on a routine or indicated basis, is variable and not well described in the United States.

The gestational age at the time of diagnosis has a strong relationship with maternal and neonatal outcomes. Once diagnosed, care can be managed according to protocols that have been found to reduce the likelihood of maternal and neonatal harm. Depending on the timing of disease occurrence and spacing of visits, preeclampsia occurring at or very near term may not be detected during prenatal screening visits, but are likely to be detected when women present for delivery. The detection of earlier-term preeclampsia, particularly cases that develop before 34 weeks' gestation, is particularly important given the risks to the mother and neonate if severe disease features emerge.

## Disease Management and Treatment

Effective management and treatment of diagnosed preeclampsia can prevent complications and poor health outcomes. Identification of women with preeclampsia allows health care providers to reduce the risk of eclampsia and maternal cerebral, vascular, hepatic, and renal complications. These most commonly occur among women who develop severe features of preeclampsia but can unexpectedly develop even in cases without severe features.^48^ The clinically proven approaches for management of preeclampsia to reduce the likelihood of poor maternal and perinatal health outcomes include delivery, intravenous administration of magnesium sulfate, and treatment of high blood pressure. Importantly, delivery is the only curative treatment for preeclampsia once the condition develops; depending on the gestational timing of diagnosis and the seriousness of the maternal and fetal condition, induction of labor can reduce the risk of major morbidity and mortality. For women who develop severe preeclampsia, intravenous administration of magnesium sulfate is effective for reducing the risk of eclamptic seizures.^49,50^ Pharmacological treatment of very high blood pressure is recommended to reduce the risk of stroke and cerebral vascular events. These treatments are supported by a broad range of medical and public health organizations, including the World Health Organization, ACOG, and NICE.^1,47, 51^ While there is variability in the strength of scientific evidence underlying different aspects of treatment,^52^ there is broad consensus that diagnosis and treatment improve perinatal and maternal health outcomes.^1,53,54^ A detailed discussion of the trial evidence for these interventions is provided in Appendix A. Recent developments in prognostic evaluation using the fullPIERS (Pre-eclampsia Integrated Estimate of RiSk) model and other markers also hold promise for improving disease management.^55,56^

Once a diagnosis of preeclampsia is made, increased maternal and fetal surveillance begin, and often referral to specialty care, with recommended treatments undertaken as needed during the course of monitoring. The clinical evidence for some management practices is less established than for others, but treatment is clearly associated with better outcomes in the case of magnesium sulfate, as well as early delivery in defined circumstances. Preeclampsia is among the most preventable causes of maternal mortality. Analyses of causes of maternal mortality from preeclampsia suggest that substandard clinical care often contributes to poor outcomes.^57^ Delayed responses to clinical warning signs and ineffective management have been found to be contributing factors in the majority of cases.^31,58^ Data based on medical charts from the United Kingdom suggests that fewer than half of women who developed eclampsia were diagnosed with both hypertension and proteinuria in the week preceding the event (38%), and that preeclampsia with atypical presentation comprises a greater proportion of eclampsia cases, owing in part to delays in diagnosis.^50,59^ Inaccuracies in proteinuria tests or record keeping, however, could also account for a portion of these findings.

## Rationale and Strategies for Risk Assessment

Early identification of women who are most likely to develop preeclampsia is potentially important for at least two reasons. First, women at higher risk may benefit from heightened surveillance and timely interventions if severe features of the disease appear, to mitigate the risk of negative health consequences for the mother and fetus.^8^ Second, low-dose aspirin for women at high risk, when commenced after the first trimester of pregnancy, ideally before 16 weeks' gestation, reduces the incidence of preeclampsia and the likelihood of experiencing serious complications, such as preterm birth and IUGR.^60,61^ Risk assessment generally relies on factors that are known to be associated with preeclampsia.^42,62^ However, no recommendations currently specify the use of clinical risk prediction tools for estimating a patient's individual risk for developing preeclampsia. Reviews of serum markers and uterine artery Doppler testing as singular prediction tools do not support their use in routine clinical care to identify women at great risk for preeclampsia.^1,63,64^ Efforts to develop multivariable predictive models for identifying women who will develop preeclampsia and its adverse consequences are ongoing.^65,66^

## Current Risk Assessment and Screening Practice in the United States

In the United States, the number of prenatal care visits and the specific tests used for screening may vary across clinical settings and populations. Risk factor assessment via medical history taking is a routine part of prenatal care and is included in Medicaid standards of practice for prenatal care.^67^ Data from the National Maternal and Infant Health survey found that 80 percent of pregnant women had a medical history taken and 98 percent had their weight and height measured in the first or second prenatal visit.^68^ Routine blood pressure measurement at prenatal visits is recommended by most prenatal care guidelines, including ACOG, and is considered best practice.^67^ In one survey, 96 percent of women reported receiving a blood pressure measurement at their first or second prenatal visit.^68^ According to national data on health care utilization from 2004 through 2006, pregnant women received an estimated 4.26 (95% CI, 3.35 to 5.16) urinalysis tests per pregnancy, but the number varied by patient race, insurance status, geographic location, and risk status.^69^ A 2007 survey of residency programs found that urine dipstick tests at every prenatal care visit was taught to 94 percent of respondents.^70^ None of the prevailing clinical guidelines provide specific recommendations for the optimal number or interval of screening tests for preeclampsia in routine care (Table 1). Descriptions of the timing of routine prenatal care visits for healthy patients vary but generally suggest eight to 14 visits, with greater frequency closer to term.^71,72^

Table 1 Recent Recommendations for Preeclampsia Screening

Organization | Year | Recommendation
Society of Obstetricians and Gynecologists of Canada (SOGC)^143^ | 2014 | The diagnosis of hypertension should be based on office or in-hospital BP measurements. (II-B; Low/Strong) [Additional detailed recommendations for blood pressure measurement and diagnosis are provided.] All pregnant women should be assessed for proteinuria. (II-2B; Low/Weak) [Comments: We suggest screening with urinary dipstick at each antenatal visit. Proteinuria should be quantified by PrCr or 24h collection if preeclampsia is suspected.] Significant proteinuria should be suspected when urinary dipstick proteinuria is ≥1+. (II-2A; Moderate/Strong) Screening using biomarkers or Doppler ultrasound velocimetry of the uteroplacental circulation cannot be recommended routinely at present for women at low or increased risk of preeclampsia until such screening has been shown to improve pregnancy outcome. (II-2C; Very low/Weak)
American Congress of Obstetricians and Gynecologists (ACOG)^1^ | 2013 | Specific preeclampsia screening recommendations are not provided (e.g., type or frequency of screening tests to use); guidelines are primarily focused on diagnostic criteria and disease management.
National Institute of Health and Care Excellence (NICE)^47^ | 2008 | Blood pressure measurement and urinalysis for protein should be carried out at each antenatal visit to screen for preeclampsia.
Royal College of Obstetricians and Gynaecologists (RCOG)^173^ | 2003 | All women with blood pressure >140/90 mm Hg, with or without proteinuria, should be referred to a day assessment or obstetric unit. (Grade A) All women with persistent proteinuria, even in the absence of hypertension, should be referred for further investigation. (Grade A) Although pregnancies associated with an abnormal uterine artery Doppler waveform are at significant risk of adverse outcome (particularly severe preeclampsia requiring early delivery), its introduction as a screening test for all women cannot currently be recommended other than in clinical trials. (Grade B) Automated instruments for BP measurement are generally not validated for use during pregnancy and preeclampsia. Therefore, the use of mercury sphygmomanometers remains preferable. (Grade B) Due to the variation in urine concentration, largely determined by hydration, all urine screening in obstetric day units should be by protein:creatinine ratio; this can be by laboratory test or at point of care. (Grade C) The definition of gestational proteinuria is derived from studies calculating the 95th centile for an uncomplicated population. A protein loss of >300 mg in 24 hours is associated with an increased morbidity to the mother and her baby. (Grade B)
U.S. Preventive Services Task Force (USPSTF)^74^ | 1996, reaffirmed 2002 No longer posted – out of date | Screening for preeclampsia with blood pressure measurement is recommended for all pregnant women at the first prenatal visit and periodically throughout the remainder of the pregnancy. Further diagnostic evaluation and clinical monitoring, including frequent BP monitoring and urine testing for protein, are indicated if BP does not decrease normally during the middle trimester, if the SBP increases 30 mm Hg above baseline, if the DBP increases 15 mm Hg above baseline, or if the blood pressure exceeds 140/90 mm Hg above baseline. (B recommendation)

Abbreviations: BMI=body mass index; BP=blood pressure; DBP=diastolic blood pressure; SBP=systolic blood pressure.

General recommendations to screen for proteinuria throughout pregnancy are offered, although the value of proteinuria as a predictor of disease has been questioned. A systematic review including 11 studies (n=4,388) found low predictive accuracy for adverse outcomes from screening for total proteinuria; sensitivity was 35 percent and specificity was 89 percent.^73^ It has also been suggested that due to the lack of sensitivity and specificity, routine protein dipstick testing should be reconsidered.^69,74^ The gold standard 24-hour urine protein test is not a practical screening tool, and there is increasing interest in the potential of using spot urine tests to determine the protein:creatinine ratio for diagnosis and point-of-care screening.^1,75^

Several organizations have guidelines to identify women at greatest risk of developing preeclampsia that are based on the clinical judgment of providers, guided by an evaluation of risk factors that can be identified during a routine medical history (Table 2). No guidelines recommend the use of a specific risk assessment instrument or tool.

## Previous USPSTF Recommendation

In 1996, the USPSTF recommended screening for preeclampsia with office-based blood pressure measurement using sphygmomanometry for all pregnant women at the first prenatal visit and periodically throughout the remainder of the pregnancy (B recommendation).^74^ The 1996 evidence report did not contain an analytic framework or Key Questions (KQs), and it was not conducted as a systematic review according to current USPSTF procedures.