# Appendix G Characteristics of Externally Validated Risk Prediction Models (Key Question 2)

Appendix G Table 1 Test Performance Characteristics of Externally Validated Preeclampsia Risk Prediction Models

External Validation Studies Models | Oliveira 2014^99^ Baltimore, MD PE requiring delivery: <34 weeks' gestation (early) ≥34 weeks' gestation (late) | Park 2013^100^ Sydney, Australia PE requiring delivery: <34 weeks' gestation (early) | Skrastad 2014^101^ Trondheim, Norway PE requiring delivery: <37 weeks' gestation (early) <42 weeks' gestation (any) >34 weeks' gestation (late) | Farina 2011^98^ Bologna, Italy PE diagnosis: >34 weeks' gestation
Caradeux 2013^121^ Santiago and Valdivia, Chile [clinical history and Doppler]^§^ Women presenting for 11 to 14 weeks ultrasound in pregnancy N=627 % early PE=1.4 (9 cases) | N=2,962 % early PE=1.0 (30 cases) C^*^=NR AUC=0.69 (0.59−0.80) early DR=30 (CI not reported) [history, Doppler]
Odibo 2011^122^ St. Louis, MO [clinical history, serum, and Doppler]^§^ Women presenting for 1st trimester aneuploidy screening in pregnancy N=452 % early PE=2.7 (12 cases) | N=871 % early PE=1.2 (10 cases) C=NR AUC=0.86 (0.73−0.99) early DR=80 (CI not reported) [history, serum, Doppler]
Parra-Cordero 2013^124^ Santiago, Chile [clinical history, serum, and Doppler]^§^ Asymptomatic women undergoing routine Doppler scan at 11+0 to 13+6 weeks in pregnancy N=5,367 % early PE=0.3 (17 cases) | N=1,558 % early PE=1.1 (17 cases) C=NR AUC=0.70 (0.58−0.83) early DR=29 (CI not reported) early [history, serum, Doppler]
Parra-Cordero 2013^124^ Santiago, Chile [clinical history, serum, and Doppler]^§^ Asymptomatic women undergoing routine Doppler scan at 11+0 to 13+6 weeks in pregnancy N=5,367 % late PE=1.0 (53 cases) | N=1,558 % late PE=5.0 (78 cases) C=NR AUC=0.61 (0.55−0.68) late DR=18 (CI not reported) late [history, serum, Doppler]
Poon 2009^128║#^ London, UK [clinical history and Doppler]^§^ Women presenting for first routine hospital visit in pregnancy N=8,061 % early PE=0.5 (37 cases) | N=2,962 % early PE=1.0 (30 cases) C=NR AUC=0.78 (0.69−0.88) early DR=53 (CI not reported) [history, Doppler]
Scazzocchio 2013^130^** Barcelona, Spain [clinical history and Doppler]^§^ Women with singleton pregnancies presenting for routine 1st trimester screening N=5,170 % early PE=0.5 (26 cases) | N=2,962 % early PE=1.0 (30 cases) C=NR AUC=0.77 (0.67−0.86) early DR=43 (CI not reported) early [history, Doppler]
Scazzocchio 2013^130^ Barcelona, Spain [clinical history and Doppler]^§^ Women with singleton pregnancies presenting for routine 1st trimester screening N=5,170 % late PE=2.1 (110 cases) | N=2,833 % late PE=4.1 (116 cases) C=NR AUC=0.69 (0.64−0.75) late DR=31 (CI not reported) late [history, Doppler]
Poon 2010^127║#^ London, UK [clinical history, serum, and Doppler]^§^ Women presenting for first routine hospital visit in pregnancy N=8,061 % early PE=0.5 (37 cases) | N=2,833 % early PE=1.0 (29 cases) C=NR AUC=0.80 (0.71−0.89) early DR=52 (CI not reported) [history, serum, Doppler] | N=3,014 % early PE=0.4 (12 cases) C=NR AUC=0.93 (0.92−0.94) early DR=91.7 (61.5−98.6) early [history, serum, Doppler]
Akolekar 2013^120║^ London and Gillingham, UK [clinical history, serum, and Doppler]^§^ Women with singleton pregnancies presenting for 1st trimester aneuploidy screening N=58,884 % preterm PE (<37 wks)=1.0 (568 cases) | | | N=541 % preterm PE (<37 wks)=0.9 (5 cases) C=NR AUC 0.94 (0.86−1.00) <37 wks DR=80.0 (28.4−99.5) <37 wks [history, serum, Doppler]
Akolekar 2013^120║^ London and Gillingham, UK [clinical history, serum, and Doppler]^§^ Women with singleton pregnancies presenting for 1st trimester aneuploidy screening N=58,884 % any PE=2.4 (1,426 cases) | | | N=541 % any PE=3.9 (21 cases) C=NR AUC=0.77 (0.67−0.87) any DR=40.0 (19.1−63.9) any [history, serum, Doppler]
PREDICTOR algorithm [clinical history, serum, and Doppler]^§^ Proprietary model, derived from multiple studies, not reported in detail | | | N=541 % any PE=3.9 (21 cases) C=NR AUC=0.74 (0.63−0.84) any DR=30.0 (11.9−54.3) any [history, serum, Doppler]
Onwudiwe 2008^123^ London, UK [clinical history and Doppler]^§^ Women with singleton pregnancies presenting for routine antenatal care N=3,347 % late PE=2.3 (78 cases) | | | | N=554 % late PE=7.0 (39 cases) C=NR AUC=0.85 (0.78−0.93) late DR=74.4 (60.7−88.1) [history, Doppler]
Plasencia 2008^125^ London, United Kingdom [clinical history and Doppler]^§^ Women with singleton pregnancies presenting for routine antenatal care N=3,107 % late PE=2.3 (71 cases) | | | | N=554 % late PE=7.0 (39 cases) C=NR AUC=0.76 (0.67−0.84) late DR=41.0 (25.6−56.4) [history, Doppler]
Plasencia 2007^126^ London, UK [clinical history only]^§^ Women with singleton pregnancies presenting for routine assessment of risk for chromosomal abnormalities N=6,015 % any PE=1.8 (107 cases) % late PE=NR | | | | N=554 % late PE=7.0 (39 cases) C=NR AUC^†^=0.72 (0.62−0.82) late DR^‡^=53.8 (38.1−69.4) [history]
Poon 2010^127║#^ London, UK [clinical history and Doppler]^§^ Women presenting for first routine hospital visit in pregnancy N=8,061 % late PE=1.6 (128 cases) | | | | N=554 % late PE=7.0 (39 cases) C=NR AUC=0.93 (0.88−0.98) late DR=84.6 (73.3−95.9) [history, Doppler]
Poon 2009^║129^ London, UK [clinical history and serum]^§^ Women with singleton pregnancies presenting for routine assessment of risk for chromosomal abnormalities N=8,051 % late PE=1.5 (124 cases) | | | | N=554 % late PE=7.0 (39 cases) C=NR AUC=0.70 (0.60−0.79) late DR=35.9 (20.8−51.0) [history, serum]

* A model performance measure that refers to how well predicted risks compare to observed outcomes preferably evaluated graphically by calibration plots and supplemented by a formal statistical test, the Hosmer-Lemeshow test for logistic regression and its equivalent for Cox regression.^83^

† A test performance statistic (equivalent to the c-statistic) used to assess discrimination, a model performance measure that refers to how well a model differentiates between those with and without the outcome.^83^

‡ The percent of cases correctly classified based on a predefined false-positive probability threshold.^83^ Detection rates for preeclampsia in this table are based on a fixed 10% false- positive rate, which was the most commonly reported.

§ Clinical history includes maternal characteristics, medical history, and routine clinical measures (e.g., family history of PE, personal history of PE, parity, race/ethnicity, prior preterm labor, CHTN, diabetes, thrombophilia, renal disease, mode of conception, smoking status, DBP, SBP, weight, MAP, BMI). Serum markers include PAPP-A, PIGF, PP13. Doppler ultrasound includes UtA-PI. Some variables are expressed as adjusted multiples of the median.

║ Derived from the Fetal Medicine Foundation Algorithm.

¶ Leona Poon and Kypros Nicolaides are authors on many of the model development papers for preeclampsia risk assessment. They also hold patents related to the use of biological makers for prenatal screening. The Fetal Medicine Foundation (founded by Nicolaides) and PerkinElmer are assignees on several patents on prenatal screening held by Poon and Nicolaides.

# Clinical history algorithm described in Poon 2010^65^ and Poon 2009.^128^

** This model was used in the study included for KQ3 to evaluate potential harms of risk assessment.

Abbreviations: AUC=area under the curve; BMI=body mass index; CHTN=chronic hypertension; CI=confidence interval; DBP=diastolic blood pressure; DR=detection rate; MAP=mean arterial pressure; NR=not reported; PE=preeclampsia; PIGF=placental growth factor; SBP=systolic blood pressure.