# Appendix F Evidence Tables and Additional Figures (Key Questions 1a, 3, 4a, and 5)

Appendix F Table 1 Study Design Characteristics of Included Studies (Key Questions 1a, 3, 4a, and 5)

Study and Quality | Study Design | Study Period | Country | Inclusion Criteria | Exclusion Criteria | n | Group
Key Questions 1a and 5
McDuffie, 1996^97^ Fair | RCT | 1992-1994 (enrollment) | United States | Healthy women in first trimester of pregnancy who presented for an intake visit | Age <18 or >39 years; completed 13 weeks' gestation; had a past (preterm delivery, preterm labor, abruption placentae, severe PE, classic cesarean delivery, gestational diabetes, incompetent cervix, uterine anomaly, diethylstil-bestrol exposure, isoimmunization, >1 2nd-trimester abortion, fetal anomaly, or SGA neonate) or current (multiple gestation, assisted pregnancy, large leiomyoma) high-risk obstetrical condition; had a current medical condition (diabetes, chronic HTN, drug or alcohol abuse, any ongoing medical or psychiatric illness requiring treatment or monitoring); were non-English speaking; or were planning to change insurance carriers during pregnancy | 2,764 (randomized) | IG: Schedule of less perinatal visits (9 visits) CG: Routine number of prenatal care visits (14 visits)
Rhode, 2007^115^ Fair | Before-After | November 2000 to March 2004 | United States | All pregnant women who enrolled for care and delivered at a hospital-based nursing-midwifery practice between November 2000 and March 2004 | Spontaneous abortion, transfer of care, transfer to high-risk care | 1,952 | IG: Indicated urine testing CG: Routine urine screening
Key Question 3
Simeone, 2015^102^ Fair | Prospective cohort study | July 2013 to February 2014 (recruitment) | Spain and Italy | Consecutive women if they had a singleton pregnancy, absence of psychiatric disorder, and low-risk Down syndrome screening (<1/240); high-risk woman matched with the next visited low-risk woman in the 1st trimester screening unit. | NR | 255 | IG: High-risk women CG: Low-risk women
Key Question 4a (sorted by type of test)
Protein:creatinine spot urine tests
Tun, 2012^110^ Fair | Diagnostic accuracy | July 1, 2010 to December 31, 2011 | United States | Pregnant women ages 18-55 years, >20 weeks' gestation who were admitted to the Lehigh Valley Health Network antepartum unit, undergoing 24-hour urine collection for diagnosis and/or management of PE | Prepregnancy renal disease (24-hour urine protein ≥300 mg), clinical indication for delivery at time of admission, outside maternal or gestational age range, did not speak English, did not give informed consent, or had been enrolled previously in the study | 90 | P/Cr spot test
Stout, 2013^109^ Fair | Diagnostic accuracy | 2005-2007 | United States | Pregnant women after 20 weeks' gestation who underwent evaluation for suspected PE | Proteinuria (i.e., ≥300 mg in 24 hours) before 20 weeks' gestation | 356 | P/Cr spot ratio
Wheeler, 2007^113^ Fair | Diagnostic accuracy | December 2000 to July 2002 | United States | Pregnant women admitted to the Greenville Hospital System University Medical Center for evaluation of preeclampsia, which was, in general, new-onset persistent HTN, worsening HTN, or proteinuria; new-onset HTN was SBP >140 mm Hg or DBP >90 mm Hg after 20 weeks' gestation in a previously normotensive patient, whereas worsening HTN was an increase in BP from baseline taken before 20 weeks' gestation | Women who had bacteriuria on microscopy or who were on more than 24 hours' bed rest, because of a potential poor correlation between spot P/Cr and 24-hour urine collections for protein after prolonged recumbency | 126 | P/Cr spot ratio
Young, 1996^114^ Fair | Diagnostic accuracy | June 1992-June 1993; December 1993-August 1994 | United States | Ambulatory women suspected of having PIH (BP >140/90 mm Hg, SBP >30 mm Hg above baseline or DBP 15 mm Hg above baseline) | Previously diagnosed as having PIH and had been placed on long-term bed rest at home or strict bed rest in the hospital for more than 36 hours | 45 | P/Cr spot test
Kyle, 2008^106^ Fair | Diagnostic accuracy | NR | New Zealand | Pregnant women attending a high-risk obstetric medical antenatal clinic if they had automated dipstick analysis of ≥1+ of new-onset proteinuria on a midstream urine specimen; group of negative or trace proteinuria women on automated dipstick also recruited; women attending clinic included those with pre-existing HTN, preexisting DM, gestational DM, renal disease, connective tissue disorders, and other high-risk obstetric and fetal conditions. | Positive urine culture for UTI, underlying proteinuric renal disease, those w/ diabetes w/ an abnormal albumin/Cr in the first trimester. | 150 | P/Cr spot test
Sethuram, 2011^108^ Fair | Diagnostic accuracy | January-September 2007 | United Kingdom | Women >24 weeks' gestation undergoing evaluation for PE (BP >140/90 mm Hg and urine protein >1+ on dipstick); women with secondary PE to HTN or GDM also included | UTI, renal pathologies, delivered before they could complete their 24-hour urine collection | 32 | P/Cr spot test
Bhide, 2015^103^ Fair | Diagnostic accuracy | NR | United Kingdom | Pregnant women with suspected PE (SBP ≥140 mm Hg and/or DBP ≥90 mm Hg in the antenatal clinic or in the community when checked by midwives or doctors and a spot urine dipstick proteinuria of ≥1+) | >72 hours between starting the 24-hour urine collection and taking the spot P/Cr ratio sample; 24-hour urinary Cr excretion <97 μM/kg (to avoid under collection) or >220 μM/kg (to avoid over collection over 24 hours); known or suspected UTI; documented proteinuria at booking; delivered elsewhere | 117 | P/Cr spot test
Lamontagne, 2014^107^ Good | Diagnostic accuracy | November 2005-November 2006 | Canada | Women age ≥18 years, in their second or third trimester of pregnancy, ambulatory, and had an indication for a 24-hour urine collection as part of an investigation for PE | Serum Cr >150 μmol/L, history of renal transplant, preexisting microalbuminuria or proteinuria, macroscopic hematuria, or known UTI. Specimens discarded if UTI, hematuria, vaginal bleeding, rupture of membranes, labor, or induction of labor occurred during 24-hour collection; incomplete urine defined as Cr <10 mmol/kg of prepregnancy weight | 91 | P/Cr spot ratio
Verdonk, 2014^111^ Good | Diagnostic accuracy | NR, but 2- year study | Netherlands | Women with suspected PE (de novo HTN with BP ≥140/90 mm Hg after 20 weeks' gestation and a urine protein dipstick reading ≥1+) admitted as inpatients; pregnant women with chronic HTN who developed new-onset proteinuria after mid-gestation also invited to participate | UTI, preexisting proteinuria, delivery before the 24-hour urinary collection was completed | 105 | P/Cr spot test
Dwyer, 2008^105^ Good | Diagnostic accuracy | September 2002-March 2004 | United States | All pregnant women being evaluated for PE, regardless of the alerting signs or symptoms, suspected severity or comorbid conditions | If urinalysis contained >10 white blood cells per high-power field, if a catheter was not used after membrane rupture or if an outpatient 24-hour collection was incomplete (complete collection defined as total Cr >1000 mg [850 mg for obese women] or total Cr 13 mg per kg body weight); in general, if a 24-hour urine protein not done, urinalysis not done, P/Cr ratio not done. | 116 | P/Cr spot test
Durnwald, 2003^104^ Fair | Diagnostic accuracy | January 2001 to July 2002 | United States | Women at ≥24 weeks' gestation who were undergoing evaluation for suspected PE (≥1 of the following findings: HTN, edema, new-onset proteinuria on urinary dipstick) | Concurrent diagnosis of chronic HTN, DM, or preexisting renal disease; documented preexisting proteinuria (1+ urine dipstick on initial office visit) | 220 | P/Cr spot ratio
Valdes, 2015^119^ Fair | Diagnostic accuracy | January-December 2012 | Chile | Women admitted to the maternity unit of the Hospital Clinico Universidad de Chile with a diagnosis of pregnancy hypertensive disorder | Twin pregnancies, fetal birth defects (antenatal diagnosis or diagnosed during the neonatal period), chronic nephropathies, maternal age <18 years, gestational age <20 weeks, incomplete demographic and perinatal data | 72 | P/Cr spot test
Albumin:creatinine spot urine tests
Waugh, 2005^94^ Good | Diagnostic accuracy | October 2000-June 2001 | United Kingdom | Pregnant women >20 weeks' gestation referred for assessment of de novo HTN occurring for the first time to the day assessment unit if they had an estimated and sustained SBP >140 mm Hg or a DBP of >90 mm Hg using mercury sphygmomanometry | Preexisting HTN | 171 | Dipstick- Microalbustix (visual) Dipstick- Clinitek Microalbumin (automated) DCA 2000- POC test
Kyle, 2008^106^ Fair | Diagnostic accuracy | NR | New Zealand | Pregnant women attending a high-risk obstetric medical antenatal clinic if they had automated dipstick analysis of ≥1+ of new-onset proteinuria on a midstream urine specimen; group of negative or trace proteinuria women on automated dipstick also recruited; women attending clinic included those with pre-existing HTN, preexisting DM, gestational DM, renal disease, connective tissue disorders, and other high-risk obstetric and fetal conditions. | Positive urine culture for UTI, underlying proteinuric renal disease, those with diabetes with an abnormal albumin/Cr in the 1st trimester. | 150 | Albumin/Cr spot test
Protein dipsticks
Waugh, 2001^112^ Fair | Diagnostic accuracy | NR | United Kingdom | Pregnant women presenting either for assessment of HTN in pregnancy or as referrals to the antenatal HTN clinic, >20 weeks' gestation | NR | 197 | Dipstick
Kyle, 2008^106^ Fair | Diagnostic accuracy | NR | New Zealand | Pregnant women attending a high-risk obstetric medical antenatal clinic if they had automated dipstick analysis of ≥1+ of new-onset proteinuria on a midstream urine specimen; group of negative or trace proteinuria women on automated dipstick also recruited; women attending clinic included those with pre-existing HTN, preexisting DM, gestational DM, renal disease, connective tissue disorders, and other high-risk obstetric and fetal conditions. | Positive urine culture for UTI, underlying proteinuric renal disease, those with diabetes with an abnormal albumin/Cr in the 1st trimester. | 150 | Dipstick
Waugh, 2005^94^ Good | Diagnostic accuracy | October 2000-June 2001 | United Kingdom | Pregnant women >20 weeks' gestation referred for assessment of de novo HTN occurring for the first time to the day assessment unit if they had an estimated and sustained SBP >140 mm Hg or a DBP of >90 mm Hg using mercury sphygmomanometry | Pre-existing HTN | 171 | Dipstick - Multistix 8SG (automated) Dipstick - Multistix 8SG (visual) DCA 2000 - POC test
Dwyer, 2008^105^ Good | Diagnostic accuracy | September 2002-March 2004 | United States | All pregnant women being evaluated for PE, regardless of the alerting signs or symptoms, suspected severity, or comorbid conditions | If urinalysis contained >10 white blood cells per high-power field, if a catheter was not used after membrane rupture or if an outpatient 24-hour collection was incomplete (complete collection defined as total Cr >1000 mg [850 mg for obese women] or total Cr 13 mg per kg body weight); in general, if a 24-hour urine protein not done, urinalysis not done, P/Cr ratio not done. | 116 | P/Cr automated dipstick

Abbreviations: BP=blood pressure; CG=control group; Cr=creatinine; DBP=diastolic blood pressure; DM=diabetes mellitus; GDM=gestational diabetes mellitus; HTN=hypertension; IG=intervention group; NR=not reported; P=protein; PE=preeclampsia; PIH=pregnancy-induced hypertension; POC=point of care; RCT=randomized, controlled trial; SBP=systolic blood pressure; SGA=small for gestational age; UTI=urinary tract infection.

Appendix F Table 2 Baseline Characteristics of Included Studies (Key Questions 1a, 3, 4a, and 5)

Study and Quality | Maternal age, years (range) | Race/Ethnicity (%) | Gestational age, weeks (range) | HTN (%) | Diabetes (%) | BMI (kg/m^2^) | Nulliparity (%) | Singleton pregnancy (%) | Suspected PE (%) or significant proteinuria(%)^*^ | Inpatient (%)
Key Questions 1a and 5
McDuffie, 1996^97^ Fair | 28.5 (18-39) | White: 81.0 Black: 4.3 Hispanic: 11.7 Asian: NR | 8.6 (NR) | Chronic: NR Gestational: NR | Pre-existing: NR Gestational: NR | NR | 48.5 | 99.1 | NR | NR
Rhode, 2007^115^ Fair | 24.7 (NR) | White: 10.2 Black: 9.2 Hispanic: 74.4 Asian: NR | 20.4 (NR) | Chronic: NR Gestational: NR | Pre-existing: NR Gestational: NR | NR | NR | NR | NR | NR
Key Question 3
Simeone, 2015^102^ Fair | 33.4 (NR) | White: 74.9 Black: NR Hispanic: NR Asian: NR | NR (NR) | Chronic: NR Gestational: NR | Pre-existing: NR Gestational: NR | 23.3 | 67.1 | 100 | NR | NR
Key Question 4a (sorted by type of test)
Protein:creatinine spot urine tests
Tun, 2012^110^ Fair | 29 (19-42) | White: 78.9 Black: 5.6 Hispanic: 2.2 Asian: 3.3 | 33.8 (24.0-39.0) | Chronic: 22.2 Gestational: 24.4 | Pre-existing: 5.6 Gestational: 15.6 | 34.1 | 45.6 | 87.8 | 31.4 | 100
Stout, 2013^109^ Fair | 27.1 (26.0-28.6) | White: NR Black: 65.2 Hispanic: NR Asian: NR | 31.8 (30.7-32.8) | Chronic: 23.9 Gestational: 2 | Pre-existing: 17.7 Gestational: NR | 35.5 | NR | 90.4 | 40.4 | 93.7
Wheeler, 2007^113^ Fair | 26.6 (NR) | White: 72 Black: 27 Hispanic: 1 Asian: NR | 34 (NR) | Chronic: NR Gestational: NR | Pre-existing: NR Gestational: NR | NR | 56 | NR | 54.0 | 100
Young, 1996^114^ Fair | NR (NR) | White: NR Black: NR Hispanic: NR Asian: NR | 33.4 (NR) | Chronic: NR Gestational: 57.8 | Pre-existing: NR Gestational: NR | NR | NR | NR | NR | 100
Kyle, 2008^106^ Fair | NR (NR) | White: 90.7 Black: NR Hispanic: NR Asian: NR | 34.0 (20.1-39.7) | Chronic: 12.7 Gestational: NR | Pre-existing: 4.7 Gestational: 9.3 | 32.5 | 36.7 | 92.0 | 8.7 | 0
Sethuram, 2011^108^ Fair | 28 (17-43) | White: NR Black: NR Hispanic: NR Asian: NR | 36 (24-41) | Chronic: NR Gestational: NR | Pre-existing: NR Gestational: NR | NR | 62 | NR | 93.8 | NR
Bhide, 2015^103^ Fair | 30.8 (NR) | White: NR Black: NR Hispanic: NR Asian: NR | 36.1 (21.0-41.0) | Chronic: NR Gestational: NR | Pre-existing: NR Gestational: NR | 28.1 | NR | NR | 65.0 | NR
Lamontagne, 2014^107^ Good | 31.8 (≥ 18) | White: 62.6 Black: 28.6 Hispanic: NR Asian: NR | 32.3 (NR) | Chronic: 37.4 Gestational: NR | Pre-existing: 8.8 Gestational: 16.5 | 29.0 | 46.2 | 95.6 | 47.3 | 62.6
Verdonk, 2014^111^ Good | 31 (IQR 28-34) | White: NR Black: NR Hispanic: NR Asian: NR | 31 (IQR 29-35) | Chronic: NR Gestational: NR | Pre-existing: NR Gestational: NR | NR | 56.2 | NR | 69.5 | 100
Dwyer, 2008^105^ Good | 30.8 (NR) | White: 40.5 Black: 12 Hispanic: 31 Asian: 16 | NR (NR) | Chronic: 22.4 Gestational: NR | Pre-existing: 6.9 Gestational: NR | NR | NR | NR | 48.3 | 100
Durnwald, 2003^104^ Fair | 26.1 (NR) | White: NR Black: 43.2 Hispanic: NR Asian: NR | 36.5 (NR) | Chronic: 0 Gestational: NR | Pre-existing: 0 Gestational: NR | NR | NR | NR | 76.4 | 94
Valdes, 2015^119^ Fair | 30.5 (NR) | White: NR Black: NR Hispanic: NR Asian: NR | NR (NR) | Chronic: 100 Gestational: NR | Pre-existing: NR Gestational: NR | 32.2 | 44.4 | 100 | 58.3 | 100
Albumin:creatinine spot urine tests
Waugh, 2005^94^ Good | 29 (19-40) | White: 97.7 Black: NR Hispanic: NR Asian: 2.3 | NR (NR) | Chronic: NR Gestational: 100 | Pre-existing: NR Gestational: NR | NR | 58 | NR | 45.0 | NR
Kyle, 2008^106^ Fair | NR (NR) | White: 90.7 Black: NR Hispanic: NR Asian: NR | 34.0 (20.1-39.7) | Chronic: 12.7 Gestational: NR | Pre-existing: 4.7 Gestational: 9.3 | 32.5 | 36.7 | 92.0 | 8.7 | 0
Protein dipsticks
Waugh, 2001^112^ Fair | 27 (18.4-36) | White: 86.8 Black: NR Hispanic: NR Asian: NR | 36.14 (24.1-39.6) | Chronic: NR Gestational: NR | Pre-existing: NR Gestational: NR | NR | 37.5 | NR | 70.1 | NR
Kyle, 2008^106^ Fair | NR (NR) | White: 90.7 Black: NR Hispanic: NR Asian: NR | 34.0 (20.1-39.7) | Chronic: 12.7 Gestational: NR | Pre-existing: 4.7 Gestational: 9.3 | 32.5 | 36.7 | 92.0 | 8.7 | 0
Waugh, 2005^94^ Good | 29 (19-40) | White: 97.7 Black: NR Hispanic: NR Asian: 2.3 | NR (NR) | Chronic: NR Gestational: 100 | Pre-existing: NR Gestational: NR | NR | 58 | NR | 45.0 | NR
Dwyer, 2008^105^ Good | 30.8 (NR) | White: 40.5 Black: 12 Hispanic: 31 Asian: 16 | NR (NR) | Chronic: 22.4 Gestational: NR | Pre-existing: 6.9 Gestational: NR | NR | NR | NR | 48.3 | 100

* For Key Question 4a only, all pregnant women had suspected preeclampsia; the data in this column reflects those with significant proteinuria according to the 24-hour urine collection (reference standard).

Abbreviations: BMI=body mass index; HTN=hypertension; NR=not reported; PE=preeclampsia.

Appendix F Table 3 Intervention Characteristics of Included Trials (Key Questions 1a, 3, and 5)

Study and Quality | Group | n | Group Name | Description | Provider
Key Questions 1a and 5
McDuffie, 1996^97^ Fair | IG | 1165 | 9 perinatal visits | Experimental schedule consisted of visits at 8, 12, 16, 24, 28, 32, 36, 38 and 40 weeks (total of nine visits) with ongoing risk assessment. For parous women, a telephone call was scheduled at 12 weeks instead of a visit. Since not all women presented at 8 weeks of gestation: 7-8 weeks seen according to schedule; 9-10 weeks asked to return at 14 weeks and have blood drawn at 16 weeks; 11-12 weeks asked to return at 16 weeks. Visits ranged from 45 minutes (intake) to 10-15 minutes with practitioners or physicians. | OBGYN, NPs, PA, or nurse midwives
McDuffie, 1996^97^ Fair | CG | 1163 | Usual care | Routine clinical schedule consisted of visits every 4 weeks from 8 to 28 weeks, then every 2 weeks until 36 weeks and weekly thereafter (total of 14 visits) with ongoing risk assessment. Since not all women presented at 8 weeks of gestation: 7-8 weeks seen according to schedule; 9-10 weeks asked to return at 14 weeks and have blood drawn at 16 weeks; 11-12 weeks asked to return at 16 weeks. Visits ranged from 45 minutes (intake) to 10-15 minutes with practitioners or physicians. | OBGYN, NPs, PA, or nurse midwives
Rhode, 2007^115^ Fair | IG | 1251 | Indicated urine testing | Women who were enrolled and delivered on or after August 15, 2002. Indicated urine testing was substituted for routine urine screening; a urine specimen was obtained prior to the patient's visits with a care provider whenever any of the criteria were present (first prenatal visit, patient complaint of symptoms of UTI, patient complaint of severe vomiting, weight loss ≥ 0.9 kg since previous visit, SBP ≥ 140 mm Hg, DBP ≥ 90 mm Hg, or any pregnancy requiring periodic urine testing such as chronic HTN and renal disease). Chemical reagent strips use for all urine tests, mean (SD) number of test strips: 1.4 (1.3), range, 0-16. Indications for urine test also reported. | NR
Rhode, 2007^115^ Fair | CG | 1160 | Routine urine screening | Women who were enrolled and delivered prior to August 15, 2002. First prenatal visit included routine urine screening, a urine culture and blood pressure determination; urine screening and BP determination were included in all subsequent visits. Chemical reagent strips use for all urine tests, mean (SD) number of test strips: 7.8 (3.4), range, 0-19. | NR
Key Question 3
Simeone, 2015^102^ Fair | IG | 140 | High-risk women | At screening, women were informed about PE and its consequences by trained midwives; counseling concerned the concept of risk, the parental expectations of the screening, and the consequences of a positive test. High-risk women underwent a followup protocol consisting of daily aspirin (150 mg) from the day of screening until 36 weeks gestation and second trimester ultrasound at 20-22 weeks including UtA Doppler velocimetry. Dietary calcium intake was evaluated in each case and when < 3 daily products/day, a supplementation w/ 1 g/day was recommended. Pts w/ normal second trimester UtA mean pulsatility index (<95th percentile) underwent a subsequent ultrasound and blood/urine test at 28 and 32 weeks, whereas those w/ abnormal results underwent same evaluation at 24, 28, 32 and 36 weeks. | Trained midwives
Simeone, 2015^102^ Fair | CG | 140 | Low-risk women | At screening, women were informed about PE and its consequences by trained midwives; counseling concerned the concept of risk, the parental expectations of the screening, and the consequences of a positive test. | Trained midwives

Abbreviations: BP=blood pressure; CG=control group; DBP=diastolic blood pressure; HTN=hypertension; IG=intervention group; NP=nurse practitioner; NR=not reported; OBGYN=obstetrician/gynecologist; PA=physician's assistant; PE=preeclampsia; pts=participants; SD=standard deviation; SBP=systolic blood pressure; UtA=uterine artery; UTI=urinary tract infection.

Appendix F Table 4 Results of Diagnostic Accuracy Studies (Key Question 4a): Significant Proteinuria

Study and Quality | Threshold^*^ | n | tp | fp | fn | tn | Sensitivity^†^ | Specificity^†^ | PPV^†^ | NPV^†^
P:Cr Spot Urine Tests
Tun, 2012^110^ Fair | 17.0 mg/mmol | 86 | 24 | 30 | 3 | 29 | 89 | 49 | 32 | 91
Stout, 2013^109^ Fair | >9.0 mg/mmol | 356 | 140 | 180 | 4 | 32 | 97 | 15 | 44 | 86
Stout, 2013^109^ Fair | >13.6 mg/mmol | 356 | 130 | 129 | 14 | 83 | 90 | 39 | 50 | 86
Stout, 2013^109^ Fair | >21.5 mg/mmol | 356 | 112 | 64 | 32 | 148 | 78 | 70 | 64 | 82
Stout, 2013^109^ Fair | >45.2 mg/mmol | 356 | 72 | 17 | 72 | 195 | 50 | 92 | 81 | 74
Stout, 2013^109^ Fair | >50.9 mg/mmol | 356 | 68 | 8 | 76 | 204 | 47 | 96 | 88 | 73
Stout, 2013^109^ Fair | >134.5 mg/mmol | 356 | 44 | 2 | 98 | 212 | 31 | >99 | 96 | 67
Wheeler, 2007^113^ Fair | 23.7 mg/mmol | 126 | 59 | 13 | 9 | 45 | 86.8 | 77.6 | 81.9 | 83.3
Young, 1996^114^ Fair | ≥5.7 mg/mmol | 45 | NR | NR | NR | NR | 100 | 0 | NR | NR
Young, 1996^114^ Fair | ≥11.3 mg/mmol | 45 | NR | NR | NR | NR | 96 | 18 | NR | NR
Young, 1996^114^ Fair | ≥17.0 mg/mmol | 45 | NR | NR | NR | NR | 91 | 41 | NR | NR
Young, 1996^114^ Fair | ≥22.6 mg/mmol | 45 | NR | NR | NR | NR | 78 | 59 | NR | NR
Young, 1996^114^ Fair | ≥28.3 mg/mmol | 45 | NR | NR | NR | NR | 65 | 82 | NR | NR
Young, 1996^114^ Fair | ≥33.9 mg/mmol | 45 | NR | NR | NR | NR | 57 | 100 | NR | NR
Young, 1996^114^ Fair | ≥39.6 mg/mmol | 45 | NR | NR | NR | NR | 48 | 100 | NR | NR
Kyle, 2008^106^ Fair | ≥30 mg/mmol | 150 | 12 | 4 | 1 | 133 | 92.3 | 97.1 | 75.0 | 99.3
Sethuram, 2011^108^ Fair | >30 mg/mmol | 32 | 25 | 0 | 5 | 2 | 83 | 92 | NR | NR
Bhide, 2015^103^ Fair | ≥18 mg/mmol | 117 | 76 | 17 | 0 | 24 | 100 | 59.6 | NR | NR
Bhide, 2015^103^ Fair | ≥30 mg/mmol | 117 | 72 | 9 | 4 | 32 | 95 | 78 | NR | NR
Bhide, 2015^103^ Fair | ≥60 mg/mmol | 117 | 57 | 0 | 19 | 41 | 74.5 | 100 | NR | NR
Lamontagne, 2014^107^ Good | ≥30 mg/mmol | 65 | 28 | 0 | 3 | 34 | 90 | 100 | 100 | 92
Lamontagne, 2014^107^ Good | ≥30 mg/mmol^§^ | 26 | 7 | 1 | 5 | 13 | 58 | 93 | 88 | 72
Lamontagne, 2014^107^ Good | ≥30 mg/mmol^║^ | 91 | 35 | 1 | 8 | 47 | 81 | 98 | 97 | 86
Verdonk, 2014^111^ Good | ≥30 mg/mmol^¶^ | 104 | 68 | 7 | 4 | 25 | 94 | 78 | NR | NR
Verdonk, 2014^111^ Good | ≥35.4 mg/mmol^¶^ | 104 | 67 | 3 | 5 | 29 | 93 | 91 | NR | NR
Verdonk, 2014^111^ Good | ≥30 mg/mmol^**^ | 105 | 65 | 8 | 8 | 24 | 89 | 75 | NR | NR
Verdonk, 2014^111^ Good | ≥50.4 mg/mmol^**^ | 105 | 59 | 1 | 14 | 31 | 81 | 97 | NR | NR
Verdonk, 2014^111^ Good | ≥30 mg/mmol^††^ | 105 | 70 | 7 | 3 | 25 | 96 | 78 | NR | NR
Verdonk, 2014^111^ Good | ≥42.4 mg/mmol^††^ | 105 | 69 | 4 | 4 | 28 | 95 | 88 | NR | NR
Dwyer, 2008^105^ Good | ≥17.0 mg/mmol | 116 | 54 | 28 | 2 | 32 | 96 | 53 | 66 | 94
Dwyer, 2008^105^ Good | ≥19.2 mg/mmol | 116 | 51 | 25 | 5 | 35 | 91 | 58 | 67 | 88
Dwyer, 2008^105^ Good | ≥21.5 mg/mmol | 116 | 50 | 18 | 6 | 42 | 89 | 70 | 74 | 88
Dwyer, 2008^105^ Good | ≥27.1 mg/mmol | 116 | 41 | 8 | 15 | 52 | 73 | 87 | 84 | 78
Dwyer, 2008^105^ Good | ≥31.6 mg/mmol | 116 | 37 | 3 | 19 | 57 | 66 | 95 | 93 | 75
Dwyer, 2008^105^ Good | ≥44.1 mg/mmol | 116 | 31 | 0 | 25 | 60 | 55 | 100 | 100 | 71
Durnwald, 2003^104^ Fair | ≥17.0 mg/mmol | 220 | 156 | 35 | 12 | 17 | 92.9 | 32.7 | 81.7 | 58.6
Durnwald, 2003^104^ Fair | ≥22.6 mg/mmol | 220 | 152 | 27 | 16 | 25 | 90.5 | 48.1 | 84.9 | 61.0
Durnwald, 2003^104^ Fair | ≥33.9 mg/mmol | 220 | 136 | 23 | 32 | 29 | 81.0 | 55.8 | 85.5 | 47.5
Durnwald, 2003^104^ Fair | ≥44.1 mg/mmol | 220 | 122 | 14 | 46 | 38 | 72.6 | 73.1 | 89.7 | 45.2
Durnwald, 2003^104^ Fair | ≥45.2 mg/mmol | 220 | 120 | 12 | 48 | 40 | 71.4 | 76.9 | 90.9 | 45.5
Durnwald, 2003^104^ Fair | ≥ 56.5 mg/mmol | 220 | 106 | 9 | 62 | 43 | 63.1 | 82.7 | 92.2 | 41.0
Valdes, 2015^119^ Fair | ≥40.7 mg/mmol | 72 | 31 | 3 | 11 | 27 | 73 | 91 | 95 | 62
A:Cr Spot Urine Tests
Waugh, 2005^94^ Good | 2.0 mg/mmol^║║^ | 171 | 72 | 6 | 5 | 88 | 94 | 94 | 92 | 95
Waugh, 2005^94^ Good | ≥3.4 mg/mmol^‡‡^ | 171 | 45 | 16 | 32 | 78 | 58 | 83 | NR | NR
Waugh, 2005^94^ Good | ≥3.4 mg/mmol^§§^ | 171 | 38 | 16 | 39 | 78 | 49 | 83 | NR | NR
Kyle, 2008^106^ Fair | ≥2.0 mg/mmol | 150 | 13 | 44 | 0 | 93 | 100 | 67.9 | 22.8 | 100
Kyle, 2008^106^ Fair | ≥3.5 mg/mmol | 150 | 13 | 17 | 0 | 120 | 100 | 87.6 | 43.3 | 100
Kyle, 2008^106^ Fair | ≥8.0 mg/mmol | 150 | 13 | 5 | 0 | 132 | 100 | 96.4 | 72.2 | 100
Dipstick
Waugh, 2001^112^ Fair | ≥1+^‡^ | 197 | 31 | 1 | 76 | 89 | 29.0 | 98.9 | 96.9 | 53.9
Waugh, 2001^112^ Fair | ≥1+^‡^ | 197 | 30 | 2 | 13 | 152 | 69.8 | 98.7 | 93.8 | 92.1
Waugh, 2001^112^ Fair | ≥1+ | 197 | 31 | 1 | 107 | 58 | 22.5 | 98.3 | 96.9 | 35.2
Waugh, 2001^112^ Fair | ≥1+ | 197 | 28 | 4 | 21 | 144 | 57.1 | 97.3 | 87.5 | 87.3
Kyle, 2008^106^ Fair | 1+ | 150 | 13 | 87 | 0 | 50 | 100 | 36.5 | 13.0 | 100
Waugh, 2005^94^ Good | 1+^¶¶^ | 171 | 63 | 18 | 14 | 76 | 82 | 81 | NR | NR
Waugh, 2005^94^ Good | 1+^***^ | 171 | 39 | 21 | 38 | 73 | 51 | 78 | NR | NR
Dwyer, 2008^105^ Good | ≥1+ | 116 | 23 | 0 | 33 | 60 | 41 | 100 | 100 | 65
Dwyer, 2008^105^ Good | ≥2+ | 116 | 13 | 0 | 43 | 60 | 23 | 100 | 100 | 58
Dwyer, 2008^105^ Good | ≥3+ | 116 | 7 | 0 | 49 | 60 | 11 | 100 | 100 | 55
Dwyer, 2008^105^ Good | ≥negative | 116 | 56 | 60 | 0 | 0 | 100 | 0 | 48 | NC

* We converted all urine exertion ratios to g/mmol by converting any values to mg/g and multiplying this value by 0.113.

† Study-reported.

‡ Reference standard used concentration, not excretion.

§ First morning void sample.

║ Other void samples.

¶ Evening sample (5 pm).

** Morning sample (8 am).

†† Noon sample (12 pm).

‡‡ Clinitek Microalbumin (automated) dipstick (ACR).

§§ Microalbustix (visual) dipstick (ACR).

║║ DCA 2000 - POC test.

¶¶ Multistix 8SG (automated) (ACR) dipstick.

*** Multistix 8SG (visual) (ACR) dipstick.

Abbreviations: A=albumun; Cr=creatinine; fn=false negative; fp=false positive; P=protein; tn=true negative; tp=true positive.

Appendix F Table 5 Results of Diagnostic Accuracy Studies (Key Question 4a): Severe Proteinuria

Study and Quality | Index Test | Threshold^*^ | n | tp | fp | fn | tn | Sensitivity^†^ | Specificity^†^ | PPV^†^ | NPV^†^
Durnwald, 2003^104^ Fair | P/Cr spot | ≥214.7 mg/mmol | 220 | 15 | 34 | 3 | 168 | 83.7 | 83.3 | 31.3 | 98.3
Durnwald, 2003^104^ Fair | P/Cr spot | ≥565.0 mg/mmol | 220 | 13 | 8 | 5 | 194 | 72.2 | 96.0 | 61.9 | 97.5
Dwyer, 2008^105^ Good | Dipstick | ≥1+ | 116 | 3 | 18 | 0 | 95 | 100 | 83 | 14 | 100
Dwyer, 2008^105^ Good | Dipstick | ≥2+ | 116 | 3 | 9 | 0 | 104 | 100 | 92 | 25 | 100
Dwyer, 2008^105^ Good | Dipstick | ≥3+ | 116 | 3 | 2 | 0 | 111 | 100 | 98 | 60 | 100
Dwyer, 2008^105^ Good | Dipstick | ≥negative | 116 | 3 | 113 | 0 | 0 | 100 | 0 | 3 | NC
Dwyer, 2008^105^ Good | P/Cr spot | ≥226.0 mg/mmol | 116 | 3 | 5 | 0 | 108 | 100 | 96 | 38 | 100
Dwyer, 2008^105^ Good | P/Cr spot | ≥339.0 mg/mmol | 116 | 3 | 3 | 0 | 110 | 100 | 97 | 50 | 100
Dwyer, 2008^105^ Good | P/Cr spot | ≥452.0 mg/mmol | 116 | 3 | 2 | 0 | 111 | 100 | 98 | 60 | 100
Dwyer, 2008^105^ Good | P/Cr spot | ≥565.0 mg/mmol | 116 | 3 | 0 | 0 | 113 | 100 | 100 | 100 | 100
Dwyer, 2008^105^ Good | P/Cr spot | ≥1528.9 mg/mmol | 116 | 2 | 0 | 1 | 113 | 67 | 100 | 100 | 99
Valdes, 2015^119^ Fair | P/Cr spot test | ≥517.5 mg/mmol | 72 | 17 | 3 | 0 | 52 | 100 | 95 | 73 | 100
Wheeler, 2007^113^ Fair | P/Cr spot | 52.0 mg/mmol | NR | NR | NR | NR | NR | 87.5 | 82.4 | 53.8 | 96.6
Wheeler, 2007^113^ Fair | P/Cr spot | 92.7 mg/mmol | NR | NR | NR | NR | NR | 100 | 94.8 | 62.5 | 100
Wheeler, 2007^113^ Fair | P/Cr spot | 339.0 mg/mmol | NR | NR | NR | NR | NR | 100 | 100 | 100 | 100

* We converted all urine exertion ratios to g/mmol by converting any values to mg/g and multiplying this value by 0.113.

† Study-reported.

Abbreviations: A=albumun; Cr=creatinine; fn=false negative; fp=false positive; P=protein; tn=true negative; tp=true positive.

Appendix F Figure 1 Diagnostic Accuracy of Protein:Creatinine Spot Urine Tests (Key Question 4a), Sorted by Threshold

Abbreviations: CI=confidence interval; df=degrees of freedom; N=number of participants.

This figure displays two forest plots (i.e., sensitivity, specificity) of the diagnostic accuracy of protein:creatinine spot urine tests sorted by threshold.

Appendix F Figure 2 Summary Receiver Operative Characteristics of Protein:Creatinine Spot Urine Tests (Key Question 4a)

Abbreviations: AUC=area under curve; sens=sensitivity; spec=specificity; SROC=summary receiver operating characteristics.

(1) Valdes, 2015; (2) Durnwald, 2003; (3) Dwyer, 2008; (4) Bhide, 2015; (5) Kyle, 2008; (6) Sethuram, 2011; (7) Verdonk, 2014; (8) Lamontagne, 2014; (9) Wheeler, 2007; (10) Stout, 2013; (11) Tun, 2012; (12) Young, 1996 (not plotted).

This figure is a summary receiver operating characteristic (ROC) curve illustrating protein:creatinine spot urine tests.

Appendix F Figure 3 Diagnostic Accuracy of Protein:Creatinine Spot Urine Tests (Key Question 4a), Sorted by Study Population

Abbreviations: CI=confidence interval; df=degrees of freedom; N = number of participants.

This figure displays two forest plots (i.e., sensitivity, specificity) of the diagnostic accuracy of protein:creatinine spot urine tests sorted by study population.