# Appendix E Summary of Methodological Principles Used in Evaluating Risk Prediction Models

1. The source of data for risk prediction models is ideally from cohort, nested case-control or case-cohort studies.^83^ Prospective cohort data are less prone to missing data and predictors than are retrospective cohort data. RCT and registry databases also are sometimes used for risk prediction model validation, but they are subject to greater risk of bias relative to cohort and nested designs.
2. The size of the study and incidence of preeclampsia determines the number of outcome events available for the model development process.^83^ For model internal validation, a rule of thumb is that there should be ten events for every predictor in the model. The low prevalence of preterm preeclampsia poses model development challenges. Models developed with this risk of bias are less likely to perform well in external validation.
3. Discrimination and calibration characterize the model performance, and without information on both it is difficult to determine the degree to which a model correctly classifies those who ultimately develop the condition of interest, and to compare models as new predictors are added and removed during model development and validation. As stated in the Checklist for Critical Appraisal and Data Extraction for Systematic Reviews of Prediction Modeling Studies (CHARMS) checklist, the absence of either calibration or discrimination hinders the full appraisal of models.^83^
4. The discriminatory capacity of predictive tools is often represented with the Area under the Receiver Operator Curve (AUC) which in general terms depicts the degree to which a test correctly classifies those with and without the condition of interest.^195^ Values of the AUC range from 0.5 to 1.0, with 0.5 representing discrimination no better than a coin toss and 1.0 representing perfect classification. Guidelines for interpretation of discriminatory power are as follows: AUC values below 0.70 are generally considered as inadequate, from 0.70 to 0.79 as adequate, and 0.80 or higher as good to excellent.^92^ The AUC, or c statistic, is the most commonly reported measure of performance, specifically model discrimination, and provides a general basis for evaluating the models we identified. An AUC of at least 0.70 is often cited as the lowest threshold for a clinically useful test.^196^
5. Based on the CHARMS checklist, for external validity studies the risk of bias is greater when the research team and setting engaged for the external validation study is independent from the team that developed the model and conducted internal validation.^83^
6. Models developed following established methods for reducing the risk of bias are more likely to be reproducible in similar populations. Information on differences in the derivation study population and the validation study population is important for interpreting differences in the performance of a model in external validation.^84^ If calibration and discrimination are not upheld in a population with similar characteristics to the model development study, overfitting and risk of bias in the model development process likely account for the lack of reproducibility. When the performance is not upheld in a population with different prevalence of important predictors and the outcome, then a model is not considered transportable – and further adjustments for application in different populations are likely necessary.
7. Clarity in reporting of the risk prediction algorithm and how it would be applied in the clinical setting are important to appraisal of models for potential clinical use recommendations. Clear reporting on the risk algorithm and its calculation, including the necessary variables, coding rules and risk cut-offs are practical requirements for model application.^83,85^