# Appendix D Excluded Studies

Code | Reason for Exclusion
E1 | Setting Clinics and study sites treating only high risk maternity patients Countries not categorized as “very high HDI” equivalent or not applicable to U.S. clinical settings
E2 | Population Patients seeking high risk obstetric care or those with known chronic conditions (other than hypertension or diabetes) Hospitalized patients
E3 | Study Design Editorial, narrative review, commentary, post-marketing surveillance, case reports Not approved study design for the KQ Risk factor screening occurred after 20 weeks gestation (KQ2) Case-control study (KQ4) Case-control study, but not nested (KQ1, KQ2) N too small (<100) (KQ2)
E4 | Outcomes Non-clinical health outcomes, such as length of hospital stay (without indication), ICU admission, or NICU admission
E5 | Disease/Condition Not preeclampsia or eclampsia (KQ1, KQ2) Not proteinuria (KQ4a) Not hypertension (KQ4b)
E6 | Interventions Serum markers or ultrasound measurements not routinely collected Secondary evaluations or diagnostic tests Experimental tests Not a screening tool (e.g., prognostic assessment)
E7 | Comparisons Comparators (e.g., not the appropriate reference standard)
E8 | Language Non-English publication
E9 | Publication Date Published before 1990
E10 | Study Quality Poor
E11 | Unable to locate article
E12 | Study Aim Not applicable/relevant to key question
E13 | Non-externally validated risk prediction models (KQ2)

1 Abebe J, Eigbefoh J, Isabu P, . Accuracy of urine dipsticks, 2-h and 12-h urine collections for protein measurement as compared with the 24-h collection. J Obstet Gynaecol 2008 Jul;28(5):496-500. PMID: 18850422. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.18850422
2 Abi-Said D, Annegers JF, Combs-Cantrell D, . Case-control study of the risk factors for eclampsia. Am J Epidemiol 1995 Aug 15;142(4):437-41. PMID: 7625409. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.7625409
3 Abou El HM, Diamandis EP, Karumanchi SA, . Preeclampsia: An Old Disease with New Tools for Better Diagnosis and Risk Management. Clin Chem 2015 Jan 22;61(5):694-8. PMID: 25614469. KQ1E3, KQ1aE3, KQ2E3, KQ3E3, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.25614469
4 Adelberg AM, Miller J, Doerzbacher M, . Correlation of quantitative protein measurements in 8-, 12-, and 24-hour urine samples for the diagnosis of preeclampsia. Am J Obstet Gynecol 2001 Oct;185(4):804-7. PMID: 11641655. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.11641655
5 Akaishi R, Yamada T, Morikawa M, . Clinical features of isolated gestational proteinuria progressing to pre-eclampsia: retrospective observational study. BMJ Open 2014;4(4):e004870. PMID: 24747797. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.24747797
6 Akolekar R, Syngelaki A, Sarquis R, . Prediction of early, intermediate and late pre-eclampsia from maternal factors, biophysical and biochemical markers at 11-13 weeks. Prenat Diagn 2011 Jan;31(1):66-74. PMID: 21210481. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.21210481
7 Akolekar R, Syngelaki A, Poon L, . Competing risks model in early screening for preeclampsia by biophysical and biochemical markers. Fetal Diagn Ther 2013;33(1):8-15. PMID: 22906914. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.22906914
8 Al RA, Baykal C, Karacay O, . Random urine protein-creatinine ratio to predict proteinuria in new-onset mild hypertension in late pregnancy. Obstet Gynecol 2004 Aug;104(2):367-71. PMID: 15292013. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.15292013
9 Al RA, Borekci B, Yapca O, . Albumin/creatinine ratio for prediction of 24-hour albumin excretion of > or =2 g in manifest preeclampsia. Clin Exp Obstet Gynecol 2009;36(3):169-72. PMID: 19860361. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.19860361
10 Albers LL, Overman B, Sedler KD. Intrapartum hypertension in a low-risk obstetric population. J Nurse Widwifery 1998 Mar;43(2):106-10. PMID: 9581096. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.9581096
11 Alves E, Azevedo A, Rodrigues T, . Impact of risk factors on hypertensive disorders in pregnancy, in primiparae and multiparae. Ann Hum Biol 2013 Sep;40(5):377-84. PMID: 23682598. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.23682598
12 Amin SV, Illipilla S, Hebbar S, . Quantifying proteinuria in hypertensive disorders of pregnancy. Int J Hypertens 2014;2014:941408. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.25302114
13 Ananth CV, Vintzileos AM. Ischemic placental disease: epidemiology and risk factors. Eur J Obstet Gynecol Reprod Biol 2011 Nov;159(1):77-82. PMID: 21839575. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.21839575
14 Anderson UD, Gram M, Akerstrom B, . First trimester prediction of preeclampsia. Current Hypertension Reports 2015 Sep;17(9):584. PMID: 26232922. KQ1E3, KQ1aE3, KQ2E3, KQ3E3, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.26232922
15 Anumba DO, Lincoln K, Robson SC. Predictive value of clinical and laboratory indices at first assessment in women referred with suspected gestational hypertension. Hypertens Pregnancy 2010 Jan;29(2):163-79. PMID: 20367506. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.20367506
16 Arfeen ZU, Maran NJ, Simon EJ, . A comparison of non-invasive methods of blood pressure measurement in normotensive and hypertensive pregnant women. Int J Obstet Anesth 1996 Jul;5(3):168-71. PMID: 15321344. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.15321344
17 August P, Helseth G, Cook EF, . A prediction model for superimposed preeclampsia in women with chronic hypertension during pregnancy. Am J Obstet Gynecol 2004 Nov;191(5):1666-72. PMID: 15547540. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.15547540
18 Ayala DE, Hermida RC, Mojon A, . Blood pressure variability during gestation in healthy and complicated pregnancies. Hypertension 1997 Sep;30(3:Pt 2):t-8. PMID: 9322990. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.9322990
19 Bahado-Singh RO, Syngelaki A, Akolekar R, . Validation of metabolomic models for prediction of early-onset preeclampsia. Am J Obstet Gynecol 2015 Jun 23 PMID: 26116099. KQ1E12, KQ1aE12, KQ2E6, KQ3E6, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.26116099
20 Bahasadri S, Kashanian M, Khosravi Z. Comparison of pregnancy outcome among nulliparas with and without microalbuminuria at the end of the second trimester. Int J Gynaecol Obstet 2011 Oct;115(1):34-6. PMID: 21794863. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.21794863
21 Baker PN, Hackett GA. The use of urinary albumin-creatinine ratios and calcium-creatinine ratios as screening tests for pregnancy-induced hypertension. Obstet Gynecol 1994 May;83(5:Pt 1):t-9. PMID: 8164937. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE6, KQ4bE4, KQ4cE4, KQ5E4.8164937
22 Bakker R, Steegers EA, Hofman A, . Blood pressure in different gestational trimesters, fetal growth, and the risk of adverse birth outcomes: the generation R study. Am J Epidemiol 2011 Oct 1;174(7):797-806. PMID: 21859836. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.21859836
23 Bar J, Hod M, Erman A, . Microalbuminuria as an early predictor of hypertensive complications in pregnant women at high risk. Am J Kidney Dis 1996 Aug;28(2):220-5. PMID: 8768917. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.8768917
24 Bar J, Friedman S, Erman A, . Microalbuminuria as an early marker of severity in hypertensive pregnant women. J Hum Hypertens 1996 Sep;10(Suppl 3):S111-S114. PMID: 8872840. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.8872840
25 Bar J, Maymon R, Padoa A, . White coat hypertension and pregnancy outcome. J Hum Hypertens 1999 Aug;13(8):541-5. PMID: 10455476. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.10455476
26 Barton JR, Barton LA, Istwan NB, . Elective delivery at 340(/)7 to 366(/)7 weeks' gestation and its impact on neonatal outcomes in women with stable mild gestational hypertension. Am J Obstet Gynecol 2011 Jan;204(1):44-5. PMID: 20934682. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.20934682
27 Baschat AA, Magder LS, Doyle LE, . Prediction of preeclampsia utilizing the first trimester screening examination. Am J Obstet Gynecol 2014 Apr 15;211(5):e1-e7. PMID: 24746997. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.24746997
28 Bateman BT, Bansil P, Hernandez-Diaz S, . Prevalence, trends, and outcomes of chronic hypertension: a nationwide sample of delivery admissions. Am J Obstet Gynecol 2012 Feb;206(2):134-8. PMID: 22177190. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.22177190
29 Baweja S, Kent A, Masterson R, . Prediction of pre-eclampsia in early pregnancy by estimating the spot urinary albumin: creatinine ratio using high-performance liquid chromatography. BJOG 2011 Aug;118(9):1126-32. PMID: 21481153. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E3, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.21481153
30 Becker R, Keller T, Kiesewetter H, . Individual risk assessment of adverse pregnancy outcome by multivariate regression analysis may serve as basis for drug intervention studies: retrospective analysis of 426 high-risk patients including ethical aspects. Arch Gynecol Obstet 2013 Jul;288(1):41-8. PMID: 23389246. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.23389246
31 Bellomo G, Rondoni F, Pastorelli G, . Twenty four-hour ambulatory blood pressure monitoring in women with pre-eclampsia. J Hum Hypertens 1995 Aug;9(8):617-21. PMID: 8523375. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.8523375
32 Bellomo G, Narducci PL, Rondoni F, . Prognostic value of 24-hour blood pressure in pregnancy. JAMA 1999 Oct 20;282(15):1447-52. PMID: 10535435. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.10535435
33 Bener A, Saleh NM. The impact of socio-economic, lifestyle habits, and obesity in developing of pregnancy-induced hypertension in fast-growing country: global comparisons. Clin Exp Obstet Gynecol 2013;40(1):52-7. PMID: 23724507. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.23724507
34 Beunis MH, Schweitzer KJ, van Hooff MH, . Midtrimester screening for microalbuminuria in healthy pregnant women. J Obstet Gynaecol 2004 Nov;24(8):863-5. PMID: 16147637. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE7, KQ4bE4, KQ4cE4, KQ5E4.16147637
35 Bhide A, Rana R, Dhavilkar M, . The value of the urinary protein:creatinine ratio for the detection of significant proteinuria in women with suspected preeclampsia. Acta Obstet Gynecol Scand 2015 Mar 3;94(5):542-6. PMID: 25737188. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E4, KQ4bE4, KQ4cE4, KQ5E2.25737188
36 Binstock MA, Wolde-Tsadik G. Alternative prenatal care. Impact of reduced visit frequency, focused visits and continuity of care. J Reprod Med 1995 Jul;40(7):507-12. PMID: 7473439. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.7473439
37 Biswas A, Choolani MA, Anandakumar C, . Ambulatory blood pressure monitoring in pregnancy induced hypertension. Acta Obstet Gynecol Scand 1997 Oct;76(9):829-33. PMID: 9351407. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.9351407
38 Booker CJ, Dodson WC, Kunselman AR, . Twenty-four-hour ambulatory blood pressure monitor heart rate: a potential marker for gestational hypertension in at-risk women. Am J Perinatol 2012 May;29(5):339-46. PMID: 22147639. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.22147639
39 Boucoiran I, Thissier LS, Wu Y, . Risk for preeclampsia and intrauterine growth restriction: Effective value of PlGF, Sflt-1 and Inhibin A in singleton and multiple pregnancies. Am J Obstet Gynecol 2012;206:S336-S337. PMID: None. KQ1E12, KQ1aE12, KQ2E6, KQ3E6, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.
40 Bramham K, Poli-de-Figueiredo CE, Seed PT, . Association of proteinuria threshold in pre-eclampsia with maternal and perinatal outcomes: a nested case control cohort of high risk women. PLoS One 2013;8(10):e76083. PMID: 24130760. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.24130760
41 Broughton PF, Sharif J, Lal S. Predicting high blood pressure in pregnancy: a multivariate approach. J Hypertens 1998 Feb;16(2):221-9. PMID: 9535150. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.9535150
42 Brown MA, Buddle ML, Whitworth JA. Measurement of blood pressure during pregnancy: evaluation of the ‘TriCUFF’. Aust N Z J Obstet Gynaecol 1993 Feb;33(1):48-50. PMID: 8498938. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.8498938
43 Brown MA, Buddle ML, Cario GM, . Ambulatory blood pressure monitoring during pregnancy. Comparison with mercury sphygmomanometry. Am J Hypertens 1993 Sep;6(9):745-9. PMID: 8110427. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.8110427
44 Brown MA, Wang MX, Buddle ML, . Albumin excretory rate in normal and hypertensive pregnancy. Clin Sci (Colch) 1994 Mar;86(3):251-5. PMID: 8156734. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.8156734
45 Brown MA, Buddle ML. Inadequacy of dipstick proteinuria in hypertensive pregnancy. Aust N Z J Obstet Gynaecol 1995 Nov;35(4):366-9. PMID: 8717555. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.8717555
46 Brown MA, Buddle ML. Hypertension in pregnancy: maternal and fetal outcomes according to laboratory and clinical features. Med J Aust 1996 Oct 7;165(7):360-5. PMID: 8890841. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.8890841
47 Brown MA, Buddle ML, Farrell T, . Randomised trial of management of hypertensive pregnancies by Korotkoff phase IV or phase V. Lancet 1998 Sep 5;352(9130):777-81. PMID: 9737283. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.9737283
48 Brown MA, Robinson A, Bowyer L, . Ambulatory blood pressure monitoring in pregnancy: what is normal? Am J Obstet Gynecol 1998 Apr;178(4):836-42. PMID: 9579453. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.9579453
49 Brown MA, Robinson A, Buddle ML. Accuracy of automated blood pressure recorders in pregnancy. Aust N Z J Obstet Gynaecol 1998 Aug;38(3):262-5. PMID: 9761149. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.9761149
50 Brown MA, Robinson A, Jones M. The white coat effect in hypertensive pregnancy: much ado about nothing? Br J Obstet Gynaecol 1999 May;106(5):474-80. PMID: 10430198. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.10430198
51 Brown MA, Bowyer L, McHugh L, . Twenty-four-hour automated blood pressure monitoring as a predictor of preeclampsia. Am J Obstet Gynecol 2001 Sep;185(3):618-22. PMID: 11568788. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.11568788
52 Brown MA, Davis GK, McHugh L. The prevalence and clinical significance of nocturnal hypertension in pregnancy. J Hypertens 2001 Aug;19(8):1437-44. PMID: 11518852. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.11518852
53 Brown MA, McHugh L, Mangos G, . Automated self-initiated blood pressure or 24-hour ambulatory blood pressure monitoring in pregnancy? BJOG 2004 Jan;111(1):38-41. PMID: 14687050. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.14687050
54 Brown MA, Mangos G, Davis G, . The natural history of white coat hypertension during pregnancy. BJOG 2005 May;112(5):601-6. PMID: 15842284. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.15842284
55 Brown MA, Roberts L, Davis G, . Can we use the Omron T9P automated blood pressure monitor in pregnancy? Hypertens Pregnancy 2011;30(2):188-93. PMID: 20846049. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.20846049
56 Brown MA, Roberts LM, Mackenzie C, . A prospective randomized study of automated versus mercury blood pressure recordings in hypertensive pregnancy (PRAM Study). Hypertens Pregnancy 2012;31(1):107-19. PMID: 21219121. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.21219121
57 Brown MA. Is there a role for ambulatory blood pressure monitoring in pregnancy? Clin Exp Pharmacol Physiol 2014 Jan;41(1):16-21. PMID: 23651133. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.23651133
58 Bryant M, Santorelli G, Lawlor DA, . A comparison of South Asian specific and established BMI thresholds for determining obesity prevalence in pregnancy and predicting pregnancy complications: findings from the Born in Bradford cohort. Int J Obes (Lond) 2014 Mar;38(3):444-50. PMID: 23797188. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.23797188
59 Bullarbo M, Rylander R. Diastolic blood pressure increase is a risk indicator for pre-eclampsia. Arch Gynecol Obstet 2015 Apr;291(4):819-23. PMID: 25241271. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.25241271
60 Cade TJ, Gilbert SA, Polyakov A, . The accuracy of spot urinary protein-to-creatinine ratio in confirming proteinuria in pre-eclampsia. Aust N Z J Obstet Gynaecol 2012 Apr;52(2):179-82. PMID: 22335428. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.22335428
61 Campbell N, Ogle R, Thornton C, . Urinary placental growth factor differentiates the hypertensive disorders of pregnancy. Aust N Z J Obstet Gynaecol 2011 Dec;51(6):523-6. PMID: 21883135. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.21883135
62 Caradeux J, Serra R, Nien JK, . First trimester prediction of early onset preeclampsia using demographic, clinical, and sonographic data: a cohort study. Prenat Diagn 2013 Aug;33(8):732-6. PMID: 23584890. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.23584890
63 Caritis S, Sibai B, Hauth J, . Predictors of pre-eclampsia in women at high risk. National Institute of Child Health and Human Development Network of Maternal-Fetal Medicine Units. Am J Obstet Gynecol 1998 Oct;179(4):946-51. PMID: 9790376. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.9790376
64 Catov JM, Ness RB, Kip KE, . Risk of early or severe pre-eclampsia related to pre-existing conditions. Int J Epidemiol 2007 Apr;36(2):412-9. PMID: 17255351. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.17255351
65 Chan P, Brown M, Simpson JM, . Proteinuria in pre-eclampsia: how much matters? BJOG 2005 Mar;112(3):280-5. PMID: 15713140. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.15713140
66 Chappell LC, Seed PT, Myers J, . Exploration and confirmation of factors associated with uncomplicated pregnancy in nulliparous women: prospective cohort study. BMJ 2013;347:f6398. PMID: 24270055. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.24270055
67 Chappell LC, Bramham K, Shennan AH. Short-term prediction of preeclampsia: how close are we? Biomark Med 2014;8(4):455-8. PMID: 24796609. KQ1E3, KQ1aE3, KQ2E3, KQ3E3, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.24796609
68 Chen BA, Parviainen K, Jeyabalan A. Correlation of catheterized and clean catch urine protein/creatinine ratios in preeclampsia evaluation. Obstet Gynecol 2008 Sep;112(3):606-10. PMID: 18757659. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE7, KQ4bE4, KQ4cE4, KQ5E4.18757659
69 Chen CL, Cheng Y, Wang PH, . Review of pre-eclampsia in Taiwan: a multi-institutional study. Zhonghua Yi Xue Za Zhi (Taipei) 2000 Dec;63(12):869-75. PMID: 11195137. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.11195137
70 Chen CY, Kwek K, Tan KH, . Our experience with eclampsia in Singapore. Singapore Med J 2003 Feb;44(2):88-93. PMID: 14503783. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.14503783
71 Chung Y, Brochut MC, Greeff A, . Clinical accuracy of inflationary oscillometry in pregnancy and pre-eclampsia: Omron-MIT Elite. Pregnancy Hypertens 2012;2(4):411-5. PMID: 26105612. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.26105612
72 Churchill D, Beevers DG. Differences between office and 24-hour ambulatory blood pressure measurement during pregnancy. Obstet Gynecol 1996 Sep;88(3):455-61. PMID: 8752258. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.8752258
73 Clark S, Hofmeyr GJ, Coats AJ, . Ambulatory blood pressure monitoring during pregnancy: validation of the TM-2420 monitor. Obstet Gynecol 1991 Jan;77(1):152-5. PMID: 1984216. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.1984216
74 Coghill AE, Hansen S, Littman AJ. Risk factors for eclampsia: a population-based study in Washington State, 1987-2007. Am J Obstet Gynecol 2011 Dec;205(6):553-7. PMID: 21855842. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.21855842
75 Cohen JL, Smilen KE, Bianco AT, . Predictive value of combined serum biomarkers for adverse pregnancy outcomes. Eur J Obstet Gynecol Reprod Biol 2014 Oct;181:89-94. PMID: 25129153. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25129153
76 Combs CA, Wheeler BC, Kitzmiller JL. Urinary protein/creatinine ratio before and during pregnancy in women with diabetes mellitus. Am J Obstet Gynecol 1991 Oct;165(4:Pt 1):t-3. PMID: 1951554. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.1951554
77 Combs CA, Rosenn B, Kitzmiller JL, . Early-pregnancy proteinuria in diabetes related to preeclampsia. Obstet Gynecol 1993 Nov;82(5):802-7. PMID: 8414328. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E6, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.8414328
78 Cote AM, Firoz T, Mattman A, . The 24-hour urine collection: gold standard or historical practice? Am J Obstet Gynecol 2008 Dec;199(6):625-6. PMID: 18718568. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.18718568
79 Crovetto F, Figueras F, Triunfo S, . Added value of angiogenic factors for the prediction of early and late preeclampsia in the first trimester of pregnancy. Fetal Diagn Ther 2014;35(4):258-66. PMID: 24714555. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.24714555
80 Crovetto F, Figueras F, Crispi F, . Forms of Circulating Luteinizing Hormone Human Chorionic Gonadotropin Receptor for the Prediction of Early and Late Preeclampsia in the First Trimester of Pregnancy. Fetal Diagn Ther 2015 Feb 11 PMID: 25676660. KQ1E12, KQ1aE12, KQ2E3, KQ3E3, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25676660
81 Crovetto F, Figueras F, Triunfo S, . First trimester screening for early and late preeclampsia based on maternal characteristics, biophysical parameters, and angiogenic factors. Prenat Diagn 2015 Feb;35(2):183-91. PMID: 25346181. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25346181
82 Cruz MO, Gao W, Hibbard JU. Obstetrical and perinatal outcomes among women with gestational hypertension, mild preeclampsia, and mild chronic hypertension. Am J Obstet Gynecol 2011 Sep;205(3):260-9. PMID: 22071056. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.22071056
83 Das V, Bhargava T, Das SK, . Microalbuminuria: a predictor of pregnancy-induced hypertension. Br J Obstet Gynaecol 1996 Sep;103(9):928-30. PMID: 8813317. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.8813317
84 Davis GK, Roberts LM, Mangos GJ, . Comparisons of auscultatory hybrid and automated sphygmomanometers with mercury sphygmomanometry in hypertensive and normotensive pregnant women: Parallel validation studies. J Hypertens 2015;33:499-506. PMID: 25380148. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.25380148
85 De Silva DA, Halstead AC, Cote AM, . Unexpected random urinary protein:creatinine ratio results-limitations of the pyrocatechol violet-dye method. BMC Pregnancy Childbirth 2013;13:152. PMID: 23865673. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE7, KQ4bE7, KQ4cE12, KQ5E12.23865673
86 De GA, Ghosh D, Anthony J, . Accuracy assessment of the Dinamap ProCare 400 in pregnancy and preeclampsia. Hypertens Pregnancy 2010 Jan;29(2):198-205. PMID: 20367507. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.20367507
87 Deis S, Rouzier R, Kayem G, . Development of a nomogram to predict occurrence of preeclampsia. Eur J Obstet Gynecol Reprod Biol 2008 Apr;137(2):146-51. PMID: 17669579. KQ1E12, KQ1aE12, KQ2E3, KQ3E3, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.17669579
88 Delic R, Stefanovic M. Optimal laboratory panel for predicting preeclampsia. J Matern Fetal Neonatal Med 2010 Jan;23(1):96-102. PMID: 19658035. KQ1E2, KQ1aE2, KQ2E3, KQ3E3, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.19658035
89 Demirci O, Kumru P, Arinkan A, . Spot protein/creatinine ratio in preeclampsia as an alternative for 24-hour urine protein. Balkan Med J 2015 Jan;32(1):51-5. PMID: 25759772. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.25759772
90 Di Lorenzo G, Ceccarello M, Cecotti V, . First trimester maternal serum PIGF, free beta-hCG, PAPP-A, PP-13, uterine artery Doppler and maternal history for the prediction of preeclampsia. Placenta 2012 Jun;33(6):495-501. PMID: 22459245. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.22459245
91 Duggan PM. Which Korotkoff sound should be used for the diastolic blood pressure in pregnancy? Aust N Z J Obstet Gynaecol 1998 May;38(2):194-7. PMID: 9653859. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.9653859
92 Duggan PM. Quiet resting is not necessary prior to routine antenatal blood pressure measurement. Aust N Z J Obstet Gynaecol 1999 Feb;39(1):19-20. PMID: 10099741. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.10099741
93 Dunsmuir DT, Payne BA, Cloete G, . Development of mHealth applications for pre-eclampsia triage. IEEE J Biomed Health Inform 2014 Nov;18(6):1857-64. PMID: 25375683. KQ1E1, KQ1aE1, KQ2E1, KQ3E1, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.25375683
94 Durnwald C, Mercer B. A prospective comparison of total protein/creatinine ratio versus 24-hour urine protein in women with suspected preeclampsia. Am J Obstet Gynecol 2003 Sep;189(3):848-52. PMID: 14526328. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4bE4, KQ4cE4, KQ5E4.14526328
95 Dwyer BK, Gorman M, Carroll IR, . Urinalysis vs urine protein-creatinine ratio to predict significant proteinuria in pregnancy. J Perinatol 2008 Jul;28(7):461-7. PMID: 18288120. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4bE4, KQ4cE4, KQ5E4.18288120
96 Ekholm E, Erkkola R, Hartiala J. Comparison of cardiovascular reflex tests and blood pressure measurement in prediction of pregnancy-induced hypertension. Eur J Obstet Gynecol Reprod Biol 1994 Mar 31;54(1):37-41. PMID: 8045331. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.8045331
97 Elvan-Taspinar A, Uiterkamp LA, Sikkema JM, . Validation and use of the Finometer for blood pressure measurement in normal, hypertensive and pre-eclamptic pregnancy. J Hypertens 2003 Nov;21(11):2053-60. PMID: 14597848. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.14597848
98 Emonts P, Seaksan S, Seidel L, . Prediction of maternal predisposition to preeclampsia. Hypertens Pregnancy 2008;27(3):237-45. PMID: 18696352. KQ1E2, KQ1aE2, KQ2E2, KQ3E2, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.18696352
99 Eskenazi B, Fenster L, Sidney S. A multivariate analysis of risk factors for preeclampsia. JAMA 1991 Jul 10;266(2):237-41. PMID: 2056625. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.2056625
100 Eslamian L, Behnam F, Tehrani ZF, . Random urine protein creatinine ratio as a preadmission test in hypertensive pregnancies with urinary protein creatinine ratio. Acta Med Iran 2011;49(2):81-4. PMID: 21598214. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.21598214
101 Farina A, Rapacchia G, Freni SA, . Prospective evaluation of ultrasound and biochemical-based multivariable models for the prediction of late pre-eclampsia. Prenat Diagn 2011 Dec;31(12):1147-52. PMID: 22009522. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.22009522
102 Ferrazzani S, Caruso A, De CS, . Proteinuria and outcome of 444 pregnancies complicated by hypertension. Am J Obstet Gynecol 1990 Feb;162(2):366-71. PMID: 2309816. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.2309816
103 Flores L, Levy I, Aguilera E, . Usefulness of ambulatory blood pressure monitoring in pregnant women with type 1 diabetes. Diabetes Care 1999 Sep;22(9):1507-11. PMID: 10480517. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.10480517
104 Fong A, Chau CT, Pan D, . Clinical morbidities, trends, and demographics of eclampsia: a population-based study. Am J Obstet Gynecol 2013 Sep;209(3):229-7. PMID: 23727516. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.23727516
105 Forest JC, Masse J, Bujold E, . PP054. Predicting preeclampsia at late mid-term pregnancy before occurrence of clinical symptoms: Clinical utility of biomarkers and clinical parameters in a low-risk population. Pregnancy Hypertens 2012 Jul;2(3):271. PMID: 26105377. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.26105377
106 Forest JC, Masse J, Bujold E, . OS090. Performance of candidate clinical and biochemical markers in screening early in pregnancy to detect women at high risk to develop preeclampsia. Pregnancy Hypertens 2012 Jul;2(3):227. PMID: 26105305. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.26105305
107 Franceschini N, Savitz DA, Kaufman JS, . Maternal urine albumin excretion and pregnancy outcome. Am J Kidney Dis 2005 Jun;45(6):1010-8. PMID: 15957129. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E4.15957129
108 Franx A, van der Post JA, Elfering IM, . Validation of automated blood pressure recording in pregnancy. Br J Obstet Gynaecol 1994 Jan;101(1):66-9. PMID: 8297873. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.8297873
109 Gaillard R, Bakker R, Willemsen SP, . Blood pressure tracking during pregnancy and the risk of gestational hypertensive disorders: the Generation R Study. Eur Heart J 2011 Dec;32(24):3088-97. PMID: 21821845. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.21821845
110 Gallo DM, Poon LC, Akolekar R, . Prediction of preeclampsia by uterine artery Doppler at 20-24 weeks' gestation. Fetal Diagn Ther 2013;34(4):241-7. PMID: 24192614. KQ1E12, KQ1aE12, KQ2E3, KQ3E3, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.24192614
111 Gangaram R, Naicker M, Moodley J. Comparison of pregnancy outcomes in women with hypertensive disorders of pregnancy using 24-hour urinary protein and urinary microalbumin to creatinine ratio. Int J Gynaecol Obstet 2009 Oct;107(1):19-22. PMID: 19666171. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.19666171
112 Gangaram R, Naicker M, Moodley J. Accuracy of the spot urinary microalbumin:creatinine ratio and visual dipsticks in hypertensive pregnant women. Eur J Obstet Gynecol Reprod Biol 2009 Jun;144(2):146-8. PMID: 19371998. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.19371998
113 Garcia-Tizon LS, Tayyar A, Poon LC, . Competing risks model in screening for preeclampsia by biophysical and biochemical markers at 30-33 weeks' gestation. Fetal Diagn Ther 2014;36(1):9-17. PMID: 24902880. KQ1E3, KQ1aE3, KQ2E3, KQ3E3, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.24902880
114 Giguere Y, Masse J, Theriault S, . Screening for pre-eclampsia early in pregnancy: performance of a multivariable model combining clinical characteristics and biochemical markers. BJOG 2015 Feb;122(3):402-10. PMID: 25175335. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25175335
115 Ginsberg JM, Chang BS, Matarese RA, . Use of single voided urine samples to estimate quantitative proteinuria. N Engl J Med 1983 Dec 22;309(25):1543-6. PMID: 6656849. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.6656849
116 Giurgescu C, Sanguanklin N, Engeland CG, . Relationships among psychosocial factors, biomarkers, preeclampsia, and preterm birth in African American women: a pilot. Appl Nurs Res 2015 Feb;28(1):e1-e6. PMID: 25282477. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25282477
117 Goetzinger KR, Singla A, Gerkowicz S, . Predicting the risk of pre-eclampsia between 11 and 13 weeks' gestation by combining maternal characteristics and serum analytes, PAPP-A and free beta-hCG. Prenat Diagn 2010 Dec;30(12-13):1138-42. PMID: 20936638. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.20936638
118 Goetzinger KR, Tuuli MG, Cahill AG, . Development and Validation of a Risk Factor Scoring System for First-Trimester Prediction of Preeclampsia. Am J Perinatol 2014 Apr 4;31(12):1049-56. PMID: 24705967. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.24705967
119 Golara M, Benedict A, Jones C, . Inflationary oscillometry provides accurate measurement of blood pressure in pre-eclampsia. BJOG 2002 Oct;109(10):1143-7. PMID: 12387468. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.12387468
120 Greeley ET, Terry KL, Spencer JV. [257-POS]: Risk of gestational hypertension in relation to number of prenatal visits. Pregnancy Hypertens 2015 Jan;5(1):129. PMID: 25787606. KQ1E11, KQ1aE11, KQ2E11, KQ3E11, KQ4E11, KQ4aE11, KQ4bE11, KQ4cE11, KQ5E11.
121 Greeley ET, Terry KL, Spencer JV. [251-POS]: Risk of eclampsia compared to number of prenatal visits. Pregnancy Hypertens 2015 Jan;5(1):126-7. PMID: 25787601. KQ1E11, KQ1aE11, KQ2E11, KQ3E11, KQ4E11, KQ4aE11, KQ4bE11, KQ4cE11, KQ5E11.
122 Green LA, Froman RD. Blood pressure measurement during pregnancy: auscultatory versus oscillatory methods. J Obstet Gynecol Neonatal Nurs 1996 Feb;25(2):155-9. PMID: 8656306. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.8656306
123 Gribble RK, Fee SC, Berg RL. The value of routine urine dipstick screening for protein at each prenatal visit. Am J Obstet Gynecol 1995 Jul;173(1):214-7. PMID: 7631685. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E3, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.7631685
124 Grobman WA, Bailit J.L., Rice M.M . Frequency of and factors associated with severe maternal morbidity. Obstet Gynecol 2014;123(4):804-10. PMID: None. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.24785608
125 Gupta M, Shennan AH, Halligan A, . Accuracy of oscillometric blood pressure monitoring in pregnancy and pre-eclampsia. Br J Obstet Gynaecol 1997 Mar;104(3):350-5. PMID: 9091015. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.9091015
126 Gurgel Alves JA, Praciano de Sousa PC, Bezerra Maia E Holanda Moura, . First-trimester maternal ophthalmic artery Doppler analysis for prediction of pre-eclampsia. Ultrasound Obstet Gynecol 2014 Oct;44(4):411-8. PMID: 24585555. KQ1E1, KQ1aE1, KQ2E1, KQ3E1, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.24585555
127 Haas DM, Sabi F, McNamara M, . Comparing ambulatory spot urine protein/creatinine ratios and 24-h urine protein measurements in normal pregnancies. J Matern Fetal Neonatal Med 2003 Oct;14(4):233-6. PMID: 14738168. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE3, KQ4cE4, KQ5E4.14738168
128 Haas DM, Parker CB, Wing DA, . A description of the methods of the Nulliparous Pregnancy Outcomes Study: monitoring mothers-to-be (nuMoM2b). Am J Obstet Gynecol 2015 Apr;212(4):539. PMID: 25648779. KQ1E12, KQ1aE12, KQ2E3, KQ3E3, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25648779
129 Hallak M, Bottoms SF, Knudson K, . Determining blood pressure in pregnancy. Positional hydrostatic effects. J Reprod Med 1997 Jun;42(6):333-6. PMID: 9219119. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.9219119
130 Harris JM, Franck L, Green B, . The psychological impact of providing women with risk information for pre-eclampsia: A qualitative study. Midwifery 2014 Apr 30;30(12):1187-95. PMID: 24917032. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.24917032
131 Hasslacher C. Clinical significance of microalbuminuria and evaluation of the Micral-Test. Clin Biochem 1993 Aug;26(4):283-7. PMID: 8242889. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.8242889
132 Hedderson MM, Darbinian JA, Sridhar SB, . Prepregnancy cardiometabolic and inflammatory risk factors and subsequent risk of hypertensive disorders of pregnancy. Am J Obstet Gynecol 2012 Jul;207(1):68-9. PMID: 22727352. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.22727352
133 Hermida RC, Ayala DE, Mojon A, . High sensitivity test for the early diagnosis of gestational hypertension and preeclampsia. II. Circadian blood pressure variability in health and hypertensive pregnant women. J Perinat Med 1997;25(2):153-67. PMID: 9189835. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.9189835
134 Hermida RC, Ayala DE, Mojon A, . High sensitivity test for the early diagnosis of gestational hypertension and preeclampsia. I. Predictable variability of cardiovascular characteristics during gestation in healthy and hypertensive pregnant women. J Perinat Med 1997;25(1):101-9. PMID: 9085211. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.9085211
135 Hermida RC, Ayala DE. Diagnosing gestational hypertension and preeclampsia with the 24-hour mean of blood pressure. Hypertension 1997 Dec;30(6):1531-7. PMID: 9403578. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.9403578
136 Hermida RC, Ayala DE, Mojon A, . Blood pressure excess for the early identification of gestational hypertension and preeclampsia. Hypertension 1998 Jan;31(1):83-9. PMID: 9449396. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.9449396
137 Hermida RC, Ayala DE, Mojon A, . Blood pressure patterns in normal pregnancy, gestational hypertension, and preeclampsia. Hypertension 2000 Aug;36(2):149-58. PMID: 10948070. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.10948070
138 Hermida RC, Ayala DE, Iglesias M. Predictable blood pressure variability in healthy and complicated pregnancies. Hypertension 2001 Sep;38(3:Pt 2):t-41. PMID: 11566967. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.11566967
139 Hermida RC, Ayala DE. Evaluation of the blood pressure load in the diagnosis of hypertension in pregnancy. Hypertension 2001 Sep;38(3:Pt 2):t-9. PMID: 11566965. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.11566965
140 Hermida RC, Ayala DE. Prognostic value of office and ambulatory blood pressure measurements in pregnancy. Hypertension 2002 Sep;40(3):298-303. PMID: 12215470. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.12215470
141 Hermida RC, Ayala DE. Sampling requirements for ambulatory blood pressure monitoring in the diagnosis of hypertension in pregnancy. Hypertension 2003 Oct;42(4):619-24. PMID: 12939237. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.12939237
142 Hermida RC, Ayala DE, Mojon A, . Differences in circadian blood pressure variability during gestation between healthy and complicated pregnancies. Am J Hypertens 2003 Mar;16(3):200-8. PMID: 12620698. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.12620698
143 Hermida RC, Ayala DE, Iglesias M. Circadian rhythm of blood pressure challenges office values as the “gold standard” in the diagnosis of gestational hypertension. Chronobiol Int 2003 Jan;20(1):135-56. PMID: 12638696. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.12638696
144 Hermida RC, Ayala DE, Iglesias M. Differences in circadian pattern of ambulatory pulse pressure between healthy and complicated pregnancies. Hypertension 2004 Sep;44(3):316-21. PMID: 15289468. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.15289468
145 Hermida RC, Ayala DE. Reference thresholds for 24-h, diurnal, and nocturnal ambulatory blood pressure mean values in pregnancy. Blood Press Monit 2005 Feb;10(1):33-41. PMID: 15687872. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.15687872
146 Herraiz I, Arbues J, Camano I, . Application of a first-trimester prediction model for pre-eclampsia based on uterine arteries and maternal history in high-risk pregnancies. Prenat Diagn 2009 Dec;29(12):1123-9. PMID: 19813221. KQ1E12, KQ1aE12, KQ2E2, KQ3E2, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.19813221
147 Higgins JR, Walshe JJ, Halligan A, . Can 24-hour ambulatory blood pressure measurement predict the development of hypertension in primigravidae? Br J Obstet Gynaecol 1997 Mar;104(3):356-62. PMID: 9091016. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E3, KQ4aE4, KQ4bE3, KQ4cE4, KQ5E4.9091016
148 Hirashima C, Ohkuchi A, Takahashi K, . A novel three-step approach for predicting the imminent onset of preeclampsia within 4 weeks after blood sampling at 19-31 weeks of gestation. Hypertens Res 2014 Jun;37(6):519-25. PMID: 24599015. KQ1E3, KQ1aE3, KQ2E3, KQ3E3, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.24599015
149 Hirshberg A, Draper J, Curley C, . A random protein-creatinine ratio accurately predicts baseline proteinuria in early pregnancy. J Matern Fetal Investig 2014 Dec;27(18):1834-8. PMID: 24660896. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE10, KQ4bE4, KQ4cE4, KQ5E12.24660896
150 Homer CS, Brown MA, Mangos G, . Non-proteinuric pre-eclampsia: a novel risk indicator in women with gestational hypertension. J Hypertens 2008 Feb;26(2):295-302. PMID: 18192844. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.18192844
151 Hooper DE. Detecting GD and preeclampsia. Effectiveness of routine urine screening for glucose and protein. J Reprod Med 1996 Dec;41(12):885-8. PMID: 8979200. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE7, KQ4bE4, KQ4cE4, KQ5E4.8979200
152 Hossain N, Khan N, Shah N, . Spot urine protein-creatinine ratio and 24-h urine protein excretion: Diagnostic accuracy in women with pre-eclampsia. Pregnancy Hypertens 2014 Jan;4(1):87-90. PMID: 26104260. KQ1E1, KQ1aE1, KQ2E1, KQ3E1, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.26104260
153 Huang Q, Gao Y, Yu Y, . Urinary spot albumin:creatinine ratio for documenting proteinuria in women with preeclampsia. Rev Obstet Gynecol 2012;5(1):9-15. PMID: 22582122. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.22582122
154 Irgens-Moller L, Hemmingsen L, Holm J. Diagnostic value of microalbuminuria in pre-eclampsia. Clin Chim Acta 1986 Jun 30;157(3):295-8. PMID: 3731490. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.3731490
155 Ishikuro M, Obara T, Metoki H, . Blood pressure measured in the clinic and at home during pregnancy among nulliparous and multiparous women: the BOSHI study. Am J Hypertens 2013 Jan;26(1):141-8. PMID: 23382338. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.23382338
156 Izumi A, Minakami H, Kuwata T, . Calcium-to-creatinine ratio in spot urine samples in early pregnancy and its relation to the development of preeclampsia. Metabolism 1997 Oct;46(10):1107-8. PMID: 9322789. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE4, KQ4cE4, KQ5E4.9322789
157 Jacobs DJ, Vreeburg SA, Dekker GA, . Risk factors for hypertension during pregnancy in South Australia. Aust N Z J Obstet Gynaecol 2003 Dec;43(6):421-8. PMID: 14712944. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.14712944
158 Jain L. Effect of pregnancy-induced and chronic hypertension on pregnancy outcome. J Perinatol 1997 Nov;17(6):425-7. PMID: 9447526. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.9447526
159 Jaschevatzky OE, Rosenberg RP, Shalit A, . Protein/creatinine ratio in random urine specimens for quantitation of proteinuria in preeclampsia. Obstet Gynecol 1990 Apr;75(4):604-6. PMID: 2314778. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.2314778
160 Juarez SP, Wagner P, Merlo J. Applying measures of discriminatory accuracy to revisit traditional risk factors for being small for gestational age in Sweden: a national cross-sectional study. BMJ Open 2014;4(7):e005388. PMID: 25079936. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25079936
161 Jwa SC, Arata N, Sakamoto N, . Prediction of pregnancy-induced hypertension by a shift of blood pressure class according to the JSH 2009 guidelines. Hypertens Res 2011 Nov;34(11):1203-8. PMID: 21796130. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.21796130
162 Kayatas S, Erdogdu E, Cakar E, . Comparison of 24-hour urinary protein and protein-to-creatinine ratio in women with preeclampsia. Eur J Obstet Gynecol Reprod Biol 2013 Oct;170(2):368-71. PMID: 23928475. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.23928475
163 Kenny LC, Black MA, Poston L, . Early pregnancy prediction of preeclampsia in nulliparous women, combining clinical risk and biomarkers: The Screening for Pregnancy Endpoints (SCOPE) international cohort study. Hypertension 2014;64:644-52. PMID: 25122928. KQ1E12, KQ1aE12, KQ2E3, KQ3E3, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25122928
164 Kieler H, Zettergren T, Svensson H, . Assessing urinary albumin excretion in pre-eclamptic women: which sample to use? BJOG 2003 Jan;110(1):12-7. PMID: 12504929. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.12504929
165 Kitzman H, Olds DL, Henderson CR, Jr. . Effect of prenatal and infancy home visitation by nurses on pregnancy outcomes, childhood injuries, and repeated childbearing. A randomized controlled trial. JAMA 1997 Aug 27;278(8):644-52. PMID: 9272896. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.9272896
166 Kleinrouweler CE, Mol BW. Clinical prediction models for pre-eclampsia: time to take the next step. Ultrasound Obstet Gynecol 2014 Sep;44(3):249-51. PMID: 25154485. KQ1E3, KQ1aE3, KQ2E3, KQ3E3, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.25154485
167 Klungsoyr K, Morken NH, Irgens L, . Secular trends in the epidemiology of pre-eclampsia throughout 40 years in Norway: prevalence, risk factors and perinatal survival. Paediatr Perinat Epidemiol 2012 May;26(3):190-8. PMID: 22471678. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.22471678
168 Knuist M, Bonsel GJ, Zondervan HA, . Intensification of fetal and maternal surveillance in pregnant women with hypertensive disorders. Int J Gynaecol Obstet 1998 May;61(2):127-33. PMID: 9639216. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.9639216
169 Koenen SV, Franx A, Oosting H, . Within-subject variability of differences between conventional and automated blood pressure measurements in pregnancy. Eur J Obstet Gynecol Reprod Biol 1998 Sep;80(1):79-84. PMID: 9758265. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.9758265
170 Kolialexi A, Gourgiotis D, Daskalakis G, . Validation of serum biomarkers derived from proteomic analysis for the early screening of preeclampsia. Dis Markers 2015;2015:121848. PMID: 25628472. KQ1E12, KQ1aE12, KQ2E3, KQ3E3, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25628472
171 Konstantin-Hansen KF, Hesseldahl H, Pedersen SM. Microalbuminuria as a predictor of preeclampsia. Acta Obstet Gynecol Scand 1992 Jul;71(5):343-6. PMID: 1326208. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.1326208
172 Kraus M, Nicolaides K. Identifying risks for early onset pre-eclampsia. Women's health 2015 Jan;11(1):15-7. PMID: 25581051. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.25581051
173 Kuc S, Koster MP, Franx A, . Maternal characteristics, mean arterial pressure and serum markers in early prediction of preeclampsia. PLoS One 2013;8(5):e63546. PMID: 23717445. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.23717445
174 Kuo VS, Koumantakis G, Gallery ED. Proteinuria and its assessment in normal and hypertensive pregnancy. Am J Obstet Gynecol 1992 Sep;167(3):723-8. PMID: 1530030. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.1530030
175 Kuromoto K, Watanabe M, Adachi K, . Increases in urinary creatinine and blood pressure during early pregnancy in pre-eclampsia. Ann Clin Biochem 2010 Jul;47(Pt:4):4-42. PMID: 20511374. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.20040796
176 Kwek K, Chan YG, Tan KH, . Validation of an oscillometric electronic sphygmomanometer in an obstetric population. Am J Hypertens 1998 Aug;11(8:Pt 1):t-82. PMID: 9715791. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.9715791
177 Kyle PM, Clark SJ, Buckley D, . Second trimester ambulatory blood pressure in nulliparous pregnancy: a useful screening test for pre-eclampsia? Br J Obstet Gynaecol 1993 Oct;100(10):914-9. PMID: 8217973. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.8217973
178 Kyle PM, Fielder JN, Pullar B, . Comparison of methods to identify significant proteinuria in pregnancy in the outpatient setting. BJOG 2008 Mar;115(4):523-7. PMID: 18201282. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4bE4, KQ4cE3, KQ5E4.18201282
179 LA BM, Okido MM, Barbieri MA, . [240-POS]: Risk factors influencing the development of hypertension in pregnancy in a convenience cohort. Pregnancy Hypertens 2015 Jan;5(1):121. PMID: 25787590. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.
180 Lai J, Poon LC, Bakalis S, . Systolic, diastolic and mean arterial pressure at 30-33 weeks in the prediction of preeclampsia. Fetal Diagn Ther 2013;33(3):173-81. PMID: 23328077. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E3, KQ4aE4, KQ4bE3, KQ4cE4, KQ5E4.23328077
181 Lamontagne A, Cote AM, Rey E. The urinary protein-to-creatinine ratio in Canadian women at risk of preeclampsia: does the time of day of testing matter? J Obstet Gynaecol Can 2014 Apr;36(4):303-8. PMID: 24798667. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4bE2, KQ4cE2, KQ5E2.24798667
182 Lan PG, Clayton PA, Hyett J, . Measuring blood pressure in pregnancy and postpartum: assessing the reliability of automated measuring devices. Hypertens Pregnancy 2013 Dec 4;33(2):168-76. PMID: 24304096. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.24304096
183 Lauszus FF, Rasmussen OW, Lousen T, . Ambulatory blood pressure as predictor of preeclampsia in diabetic pregnancies with respect to urinary albumin excretion rate and glycemic regulation. Acta Obstet Gynecol Scand 2001 Dec;80(12):1096-103. PMID: 11846705. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.11846705
184 Lauszus FF, Rosgaard A, Lousen T, . Precision, consistency, and reproducibility of blood pressure in diabetic and non-diabetic pregnancy: the appraisal of repeated measurements. Acta Obstet Gynecol Scand 2007;86(9):1063-70. PMID: 17712646. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.17712646
185 Lauszus FF, Rosgaard A, Lousen T, . Night/day ratio as predictor of preeclampsia in normoalbuminuric, diabetic women: early signs of blood pressure disorders. Arch Gynecol Obstet 2009 Jun;279(6):829-34. PMID: 19018544. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E12, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E4.19018544
186 Leanos-Miranda A, Marquez-Acosta J, Romero-Arauz F, . Protein:creatinine ratio in random urine samples is a reliable marker of increased 24-hour protein excretion in hospitalized women with hypertensive disorders of pregnancy. Clin Chem 2007 Sep;53(9):1623-8. PMID: 17660273. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.17660273
187 Lee AM, Briandet BM, Zelig CM. Adverse pregnancy outcomes in hypertensive patients: predictive value of protein concentration versus total protein. J Matern Fetal Neonatal Med 2014 Feb 3;27(16):1643-5. PMID: 24484078. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E4.24484078
188 Lee LC, Sheu BC, Shau WY, . Mid-trimester beta-hCG levels incorporated in a multifactorial model for the prediction of severe pre-eclampsia. Prenat Diagn 2000 Sep;20(9):738-43. PMID: 11015703. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.11015703
189 Leeners B, Stiller R, Neumaier-Wagner P, . Psychosocial distress associated with treatment of hypertensive diseases in pregnancy. Psychosomatics 2008 Sep;49(5):413-9. PMID: 18794510. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.18794510
190 Leung C, Saaid R, Pedersen L, . Demographic factors that can be used to predict early-onset pre-eclampsia. J Matern Fetal Neonatal Med 2014 Jun 5;28(5):535-9. PMID: 24827601. KQ1E4, KQ1aE4, KQ2E13, KQ3E4, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.24827601
191 Levine RJ, Ewell MG, Hauth JC, . Should the definition of preeclampsia include a rise in diastolic blood pressure of >/=15 mm Hg to a level <90 mm Hg in association with proteinuria? Am J Obstet Gynecol 2000 Oct;183(4):787-92. PMID: 11035314. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.11035314
192 Li N, Ghosh G, Gudmundsson S. Uterine artery Doppler in high-risk pregnancies at 23-24 gestational weeks is of value in predicting adverse outcome of pregnancy and selecting cases for more intense surveillance. Acta Obstet Gynecol Scand 2014 Dec;93(12):1276-81. PMID: 25155650. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25155650
193 Liro M, Gasowski J, Wydra D, . Twenty-four-hour and conventional blood pressure components and risk of preterm delivery or neonatal complications in gestational hypertension. Blood Press 2009;18(1-2):36-43. PMID: 19353410. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.19353410
194 Lisonkova S, Joseph KS. Incidence of preeclampsia: risk factors and outcomes associated with early- versus late-onset disease. Am J Obstet Gynecol 2013 Dec;209(6):544. PMID: 23973398. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.23973398
195 Liu CM, Cheng PJ, Chang SD. Maternal complications and perinatal outcomes associated with gestational hypertension and severe preeclampsia in Taiwanese women. J Formos Med Assoc 2008 Feb;107(2):129-38. PMID: 18285245. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.18285245
196 Liu S, Joseph KS, Liston RM, . Incidence, risk factors, and associated complications of eclampsia. Obstet Gynecol 2011 Nov;118(5):987-94. PMID: 22015865. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.22015865
197 Llurba E, Carreras E, Gratacos E, . Maternal history and uterine artery Doppler in the assessment of risk for development of early- and late-onset preeclampsia and intrauterine growth restriction. Obstet Gynecol Int 2009;2009:275613. PMID: 19936122. KQ1E3, KQ1aE3, KQ2E3, KQ3E3, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.19936122
198 Lo C, Taylor RS, Gamble G, . Use of automated home blood pressure monitoring in pregnancy: is it safe? Am J Obstet Gynecol 2002 Nov;187(5):1321-8. PMID: 12439526. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.12439526
199 Loi K, Khoo CK, Tan KH, . A review of 93 cases of severe preeclampsia in Singapore: are there risk factors for complications? Singapore Med J 2007 Sep;48(9):808-12. PMID: 17728960. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.17728960
200 Lopez MC, Belizan JM, Villar J, . The measurement of diastolic blood pressure during pregnancy: which Korotkoff phase should be used? Am J Obstet Gynecol 1994 Feb;170(2):574-8. PMID: 8116715. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E3, KQ4aE4, KQ4bE3, KQ4cE4, KQ5E4.8116715
201 Magee LA, von DP, Bohun CM, . Serious perinatal complications of non-proteinuric hypertension: an international, multicentre, retrospective cohort study. J Obstet Gynaecol Can 2003 May;25(5):372-82. PMID: 12738978. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E4.12738978
202 Magnussen EB, Vatten LJ, Lund-Nilsen TI, . Prepregnancy cardiovascular risk factors as predictors of pre-eclampsia: population based cohort study. BMJ 2007 Nov 10;335(7627):978. PMID: 17975256. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.17975256
203 Mahmoudi N, Graves SW, Solomon CG, . Eclampsia: a 13-year experience at a United States tertiary care center. J Womens Health Gend Based Med 1999 May;8(4):495-500. PMID: 10839704. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.10839704
204 Makihara N, Yamasaki M, Morita H, . A dipstick test combined with urine specific gravity improved the accuracy of proteinuria determination in pregnancy screening. Kobe J Med Sci 2011;56(4):E165-E172. PMID: 21937864. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.21937864
205 Martins-Costa SH, Vettorazzi J, Valerio E, . Protein creatinine ratio in random urine sample of hypertensive pregnant women: maternal and perinatal outcomes. Hypertens Pregnancy 2011;30(3):331-7. PMID: 21174587. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.21174587
206 Mbah AK, Alio AP, Marty PJ, . Recurrent versus isolated pre-eclampsia and risk of feto-infant morbidity outcomes: racial/ethnic disparity. Eur J Obstet Gynecol Reprod Biol 2011 May;156(1):23-8. PMID: 21316142. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.21316142
207 McCowan LM, Thompson JM, Taylor RS, . Clinical prediction in early pregnancy of infants small for gestational age by customised birthweight centiles: findings from a healthy nulliparous cohort. PLoS One 2013;8(8):e70917. PMID: 23940665. KQ1E4, KQ1aE4, KQ2E4, KQ3E4, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.23940665
208 McDuffie RS Jr., Beck A, Bischoff K, . Effect of frequency of prenatal care visits on perinatal outcome among low-risk women. A randomized controlled trial. JAMA 1996 Mar 20;275(11):847-51. PMID: 8596222. KQ1E7, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4.8596222
209 Mello G, Parretti E, Cioni R, . Individual longitudinal patterns in biochemical and hematological markers for the early prediction of pre-eclampsia. J Matern Fetal Neonatal Med 2002 Feb;11(2):93-9. PMID: 12375550. KQ1E2, KQ1aE2, KQ2E3, KQ3E3, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.12375550
210 Meyer NL, Mercer BM, Friedman SA, . Urinary dipstick protein: a poor predictor of absent or severe proteinuria. Am J Obstet Gynecol 1994 Jan;170(1:Pt 1):t-41. PMID: 8296815. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE2, KQ4bE4, KQ4cE4, KQ5E4.8296815
211 Millar JG, Campbell SK, Albano JD, . Early prediction of pre-eclampsia by measurement of kallikrein and creatinine on a random urine sample. Br J Obstet Gynaecol 1996 May;103(5):421-6. PMID: 8624314. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.8624314
212 Mittendorf R, Lain KY, Williams MA, . Preeclampsia. A nested, case-control study of risk factors and their interactions. J Reprod Med 1996 Jul;41(7):491-6. PMID: 8829061. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.8829061
213 Mohseni SM, Moez N, Naghizadeh MM, . Correlation of random urinary protein to creatinine ratio in 24-hour urine samples of pregnant women with preeclampsia. J Family Reprod Health 2013 Jun;7(2):95-101. PMID: 24971109. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.24971109
214 Moon M, Odibo A. First-trimester screening for preeclampsia: impact of maternal parity on modeling and screening effectiveness. J Matern Fetal Neonatal Med 2014 Nov 11:1-6. PMID: 25330843. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25330843
215 Morikawa M, Cho K, Yamada T, . Risk factors for eclampsia in Japan between 2005 and 2009. Int J Gynaecol Obstet 2012 Apr;117(1):66-8. PMID: 22257769. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.22257769
216 Mostello D, Catlin TK, Roman L, . Preeclampsia in the parous woman: who is at risk? Am J Obstet Gynecol 2002 Aug;187(2):425-9. PMID: 12193937. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.12193937
217 Moura SB EH Park F, Murthi P, . TNF-R1 as a first trimester marker for prediction of pre-eclampsia. J Matern Fetal Neonatal Med 2015 Mar 17:1-7. PMID: 25758630. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25758630
218 Moutquin JM, Rainville C, Giroux L, . Is a threshold increase in blood pressure predictive of preeclampsia? A prospective cohort study. Clin Exp Hypertens B 1990;9(2):225-35. PMID: None. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E3, KQ4aE4, KQ4bE3, KQ4cE4, KQ5E4.
219 Murray N, Homer CS, Davis GK, . The clinical utility of routine urinalysis in pregnancy: a prospective study. Med J Aust 2002 Nov 4;177(9):477-80. PMID: 12405888. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE7, KQ4bE3, KQ4cE3, KQ5E4.12405888
220 Myatt L, Clifton RG, Roberts JM, . First-trimester prediction of preeclampsia in nulliparous women at low risk. Obstet Gynecol 2012 Jun;119(6):1234-42. PMID: 22617589. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.22617589
221 Myers J, Tuytten R, Thomas G, . OS043. Identification and validation of novel markers for the predictionof pre-eclampsia. Pregnancy Hypertens 2012 Jul;2(3):200. PMID: 26105257. KQ1E12, KQ1aE12, KQ2E3, KQ3E3, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.26105257
222 Myers JE, Kenny LC, McCowan LM, . P30. Angiogenic factors combined with clinical risk factors to predict preterm preeclampsia in nulliparous women. Pregnancy Hypertens 2011 Jul;1(3-4):286-7. PMID: 26009120. KQ1E1, KQ1aE1, KQ2E1, KQ3E1, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.26009120
223 Myers JE, Kenny LC, McCowan LM, . Angiogenic factors combined with clinical risk factors to predict preterm pre-eclampsia in nulliparous women: a predictive test accuracy study. BJOG 2013 Sep;120(10):1215-23. PMID: 23906160. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.23906160
224 Nakamura T, Ito M, Yoshimura T, . Usefulness of the urinary microalbumin/creatinine ratio in predicting pregnancy-induced hypertension. Int J Gynaecol Obstet 1992 Feb;37(2):99-103. PMID: 1348709. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE6, KQ4bE4, KQ4cE4, KQ5E4.1348709
225 Natarajan P, Shennan AH, Penny J, . Comparison of auscultatory and oscillometric automated blood pressure monitors in the setting of preeclampsia. Am J Obstet Gynecol 1999 Nov;181(5:Pt 1):t-10. PMID: 10561646. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.10561646
226 Neithardt AB, Dooley SL, Borensztajn J. Prediction of 24-hour protein excretion in pregnancy with a single voided urine protein-to-creatinine ratio. Am J Obstet Gynecol 2002 May;186(5):883-6. PMID: 12015502. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E2.12015502
227 Nijdam ME, Janssen KJ, Moons KG, . Prediction model for hypertension in pregnancy in nulliparous women using information obtained at the first antenatal visit. J Hypertens 2010 Jan;28(1):119-26. PMID: 19907344. KQ1E12, KQ1aE12, KQ2E4, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.19907344
228 Nisell H, Trygg M, Back R. Urine albumin/creatinine ratio for the assessment of albuminuria in pregnancy hypertension. Acta Obstet Gynecol Scand 2006;85(11):1327-30. PMID: 17091412. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.17091412
229 North RA, McCowan LM, Dekker GA, . Clinical risk prediction for pre-eclampsia in nulliparous women: development of model in international prospective cohort. BMJ 2011;342:d1875. PMID: 21474517. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.21474517
230 O'Gorman N, Wright D, Syngelaki A, . Competing risks model in screening for preeclampsia by maternal factors and biomarkers at 11-13 weeks' gestation. Am J Obstet Gynecol 2015 Aug 18 PMID: 26297382. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.26297382
231 Odegard RA, Vatten LJ, Nilsen ST, . Risk factors and clinical manifestations of pre-eclampsia. BJOG 2000 Nov;107(11):1410-6. PMID: 11117771. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.11117771
232 Odibo AO, Zhong Y, Goetzinger KR, . First-trimester placental protein 13, PAPP-A, uterine artery Doppler and maternal characteristics in the prediction of pre-eclampsia. Placenta 2011 Aug;32(8):598-602. PMID: 21652068. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.21652068
233 Ohkuchi A, Iwasaki R, Ojima T, . Increase in systolic blood pressure of > or = 30 mm Hg and/or diastolic blood pressure of > or = 15 mm Hg during pregnancy: is it pathologic? Hypertens Pregnancy 2003;22(3):275-85. PMID: 14572364. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.14572364
234 Oliveira N, Magder LS, Blitzer MG, . First Trimester Prediction of Preeclampsia: External validity of algorithms in a prospectively enrolled cohort. Ultrasound Obstet Gynecol 2014 Jun 10;44(3):279-85. PMID: 24913190. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.24913190
235 Oliveira N, Doyle LE, Atlas RO, . External validity of first trimester algorithms in the prediction of pre-eclampsia disease severity. Ultrasound Obstet Gynecol 2014 Jun 10;44(3):286-92. PMID: 24912952. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.24912952
236 Oliveira SM, Arcuri EA, Santos JL. Cuff width influence on blood pressure measurement during the pregnant-puerperal cycle. J Adv Nurs 2002 Apr;38(2):180-9. PMID: 11940131. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.11940131
237 Oloyede OA, Iketubosin F. Uterine artery Doppler study in second trimester of pregnancy. Pan Afr Med J 2013;15:87. PMID: None. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.24198883
238 Onwudiwe N, Yu CK, Poon LC, . Prediction of pre-eclampsia by a combination of maternal history, uterine artery Doppler and mean arterial pressure. Ultrasound Obstet Gynecol 2008 Dec;32(7):877-83. PMID: 18991324. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.18991324
239 Osman O, Bakare AO, Elamin S. The prevalence of proteinuria among pregnant women as detected by a semi-quantitative method: a single center experience. Arab J Nephrol Transplant 2011 May;4(2):77-82. PMID: 21999855. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.21999855
240 Osmundson SS, Lafayette RA, Bowen RA, . Maternal proteinuria in twin compared with singleton pregnancies. Obstet Gynecol 2014 Aug;124(2:Pt 1):t-7. PMID: 25004349. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25004349
241 Ozcan T, Kaleli B, Ozeren M, . Urinary calcium to creatinine ratio for predicting preeclampsia. Am J Perinatol 1995 Sep;12(5):349-51. PMID: 8540941. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.8540941
242 Palomaki GE, Haddow JE, Haddow HR, . Modeling risk for severe adverse outcomes using angiogenic factor measurements in women with suspected preterm preeclampsia. Prenat Diagn 2015 Jan 6;35(4):386-93. PMID: 25641027. KQ1E12, KQ1aE12, KQ2E3, KQ3E3, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25641027
243 Palomaki GE, Haddow JE, Haddow H, . [24-OR]: Modeling risk for adverse outcomes in women with suspected preterm preeclampsia using angiogenic factor measurements. Pregnancy Hypertens 2015 Jan;5(1):12. PMID: 25787375. KQ1E12, KQ1aE12, KQ2E6, KQ3E6, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.
244 Panella M, Rocchi MC, Landolina C, . Blood pressure peaks correlated with plasma fibronectin levels and microalbuminuria in hypertensive pregnancies. Clin Exp Obstet Gynecol 1997;24(2):82-5. PMID: 9342469. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.9342469
245 Papageorghiou AT, Yu CK, Erasmus IE, . Assessment of risk for the development of pre-eclampsia by maternal characteristics and uterine artery Doppler. BJOG 2005 Jun;112(6):703-9. PMID: 15924523. KQ1E3, KQ1aE3, KQ2E3, KQ3E3, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.15924523
246 Parazzini F, Bortolus R, Chatenoud L, . Risk factors for pregnancy-induced hypertension in women at high risk for the condition. Italian Study of Aspirin in Pregnancy Group. Epidemiology 1996 May;7(3):306-8. PMID: 8728447. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.8728447
247 Park F, Russo K, Williams P, . Prediction and prevention of early onset pre-eclampsia: The impact of aspirin after first trimester screening. Ultrasound Obstet Gynecol 2015 Feb 11 PMID: 25678383. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25678383
248 Park FJ, Leung CH, Poon LC, . Clinical evaluation of a first trimester algorithm predicting the risk of hypertensive disease of pregnancy. Aust N Z J Obstet Gynaecol 2013 Dec;53(6):532-9. PMID: 23919594. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.23919594
249 Park JH, Chung D, Cho HY, . Random urine protein/creatinine ratio readily predicts proteinuria in preeclampsia. Obstet Gynecol Sci 2013 Jan;56(1):8-14. PMID: 24327974. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.24327974
250 Parra-Cordero M, Rodrigo R, Barja P, . Prediction of early and late pre-eclampsia from maternal characteristics, uterine artery Doppler and markers of vasculogenesis during first trimester of pregnancy. Ultrasound Obstet Gynecol 2013 May;41(5):538-44. PMID: 22807133. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.22807133
251 Parra-Cordero M, Sepulveda-Martinez A, Preisler J, . Role of the Glucose Tolerance Test as a Predictor of Preeclampsia. Gynecol Obstet Invest 2014 Jun 5 PMID: 24903217. KQ1E3, KQ1aE3, KQ2E3, KQ3E3, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.24903217
252 Paruk F, Moodley J, Daya PK, . Screening for proteinuria in hypertensive disorders of pregnancy. J Obstet Gynaecol 1997 Nov;17(6):528-30. PMID: 15511949. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.15511949
253 Paternoster DM, Stella A, Mussap M, . Predictive markers of pre-eclampsia in hypertensive disorders of pregnancy. Int J Gynaecol Obstet 1999 Sep;66(3):237-43. PMID: 10580670. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E6, KQ4aE7, KQ4bE6, KQ4cE4, KQ5E4.10580670
254 Payne B, Magee LA, Cote AM, . PIERS proteinuria: relationship with adverse maternal and perinatal outcome. J Obstet Gynaecol Can 2011 Jun;33(6):588-97. PMID: 21846448. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E4, KQ4aE2, KQ4bE4, KQ4cE4, KQ5E6.21846448
255 Peek M, Shennan A, Halligan A, . Hypertension in pregnancy: which method of blood pressure measurement is most predictive of outcome? Obstet Gynecol 1996 Dec;88(6):1030-3. PMID: 8942848. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.8942848
256 Penny JA, Halligan AW, Shennan AH, . Automated, ambulatory, or conventional blood pressure measurement in pregnancy: which is the better predictor of severe hypertension? Am J Obstet Gynecol 1998 Mar;178(3):521-6. PMID: 9539520. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE4, KQ4bE3, KQ4cE4, KQ5E4.9539520
257 Phaloprakarn C, Tangjitgamol S. Risk assessment for preeclampsia in women with gestational diabetes mellitus. J Perinat Med 2009;37(6):617-21. PMID: 19591558. KQ1E1, KQ1aE1, KQ2E1, KQ3E1, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.19591558
258 Phelan LK, Brown MA, Davis GK, . A prospective study of the impact of automated dipstick urinalysis on the diagnosis of preeclampsia. Hypertens Pregnancy 2004;23(2):135-42. PMID: 15369647. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE7, KQ4bE3, KQ4cE3, KQ5E3.15369647
259 Phuapradit W, Manusook S, Lolekha P. Urinary calcium/creatinine ratio in the prediction of preeclampsia. Aust N Z J Obstet Gynaecol 1993 Aug;33(3):280-1. PMID: 8304893. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.8304893
260 Plasencia W, Maiz N, Bonino S, . Uterine artery Doppler at 11 + 0 to 13 + 6 weeks in the prediction of pre-eclampsia. Ultrasound Obstet Gynecol 2007 Oct;30(5):742-9. PMID: 17899573. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.17899573
261 Plasencia W, Maiz N, Poon L, . Uterine artery Doppler at 11 + 0 to 13 + 6 weeks and 21 + 0 to 24 + 6 weeks in the prediction of pre-eclampsia. Ultrasound Obstet Gynecol 2008 Aug;32(2):138-46. PMID: 18634131. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.18634131
262 Pomini F, Scavo M, Ferrazzani S, . There is poor agreement between manual auscultatory and automated oscillometric methods for the measurement of blood pressure in normotensive pregnant women. J Matern Fetal Med 2001 Dec;10(6):398-403. PMID: 11798450. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.11798450
263 Poon LC, Kametas N, Bonino S, . Urine albumin concentration and albumin-to-creatinine ratio at 11(+0) to 13(+6) weeks in the prediction of pre-eclampsia. BJOG 2008 Jun;115(7):866-73. PMID: 18485165. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.18485165
264 Poon LC, Karagiannis G, Leal A, . Hypertensive disorders in pregnancy: screening by uterine artery Doppler imaging and blood pressure at 11-13 weeks. Ultrasound Obstet Gynecol 2009 Nov;34(5):497-502. PMID: 19827052. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.19827052
265 Poon LC, Kametas NA, Maiz N, . First-trimester prediction of hypertensive disorders in pregnancy. Hypertension 2009 May;53(5):812-8. PMID: 19273739. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.19273739
266 Poon LC, Kametas NA, Chelemen T, . Maternal risk factors for hypertensive disorders in pregnancy: a multivariate approach. J Hum Hypertens 2010 Feb;24(2):104-10. PMID: 19516271. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.19516271
267 Poon LC, Stratieva V, Piras S, . Hypertensive disorders in pregnancy: combined screening by uterine artery Doppler, blood pressure and serum PAPP-A at 11-13 weeks. Prenat Diagn 2010 Mar;30(3):216-23. PMID: 20108221. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.20108221
268 Poon LC, Kametas NA, Valencia C, . Hypertensive disorders in pregnancy: screening by systolic diastolic and mean arterial pressure at 11-13 weeks. Hypertens Pregnancy 2011;30(1):93-107. PMID: 20818956. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.20818956
269 Poon LC, Syngelaki A, Akolekar R, . Combined screening for preeclampsia and small for gestational age at 11-13 weeks. Fetal Diagn Ther 2013;33(1):16-27. PMID: 22986844. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.22986844
270 Poon LC, Nicolaides KH. Early prediction of preeclampsia. Obstet Gynecol Int 2014;2014:297397. PMID: 25136369. KQ1E3, KQ1aE3, KQ2E3, KQ3E3, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.25136369
271 Poon LCY, Maiz N, Valencia C, . First-trimester maternal serum pregnancy-associated plasma protein-A and pre-eclampsia. Ultrasound Obstet Gynecol 2009;33(1):23-33. PMID: 19090499. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.19090499
272 Porter KB, O'Brien WF, Kiefert V, . Finapres: a noninvasive device to monitor blood pressure. Obstet Gynecol 1991 Sep;78(3:Pt 1):t-3. PMID: 1876379. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.1876379
273 Quinn M. Automated blood pressure measurement devices: a potential source of morbidity in preeclampsia? Am J Obstet Gynecol 1994 May;170(5:Pt 1):t-7. PMID: 8178857. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.8178857
274 Ramirez Avila GM, Gapelyuk A, Marwan N, . Classification of cardiovascular time series based on different coupling structures using recurrence networks analysis. Philos Transact Ser A Math Phys Eng Sci 2013 Aug 28;371(1997):20110623. PMID: 23858486. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.23858486
275 Rang S, Wolf H, van Montfrans GA, . Serial assessment of cardiovascular control shows early signs of developing pre-eclampsia. J Hypertens 2004 Feb;22(2):369-76. PMID: 15076196. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.15076196
276 Rang S, van Montfrans GA, Wolf H. Serial hemodynamic measurement in normal pregnancy, preeclampsia, and intrauterine growth restriction. Am J Obstet Gynecol 2008 May;198(5):519. PMID: 18279824. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.18279824
277 Rani SS, Ghalaut V, Lata S, . Correlation of 2 hour, 4 hour, 8 hour and 12 hour urine protein with 24 hour urinary protein in preeclampsia. J Family Reprod Health 2014 Sep;8(3):131-4. PMID: 25628723. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.25628723
278 Raniolo E, Phillipou G. Prediction of pregnancy-induced hypertension by means of the urinary calcium:creatinine ratio. Med J Aust 1993 Jan 18;158(2):98-100. PMID: 8419785. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.8419785
279 Reinders A, Cuckson AC, Jones CR, . Validation of the Welch Allyn ‘Vital Signs’ blood pressure measurement device in pregnancy and pre-eclampsia. BJOG 2003 Feb;110(2):134-8. PMID: 12618156. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.12618156
280 Reinders A, Cuckson AC, Lee JT, . An accurate automated blood pressure device for use in pregnancy and pre-eclampsia: the Microlife 3BTO-A. BJOG 2005 Jul;112(7):915-20. PMID: 15957992. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.15957992
281 Reinders LW, Mos CN, Thornton C, . Time poor: rushing decreases the accuracy and reliability of blood pressure measurement technique in pregnancy. Hypertens Pregnancy 2006;25(2):81-91. PMID: 16867915. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.16867915
282 Rey E, Pilon F, Boudreault J. Home blood pressure levels in pregnant women with chronic hypertension. Hypertens Pregnancy 2007;26(4):403-14. PMID: 18066959. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.18066959
283 Rey E, Morin F, Boudreault J, . Blood pressure assessments in different subtypes of hypertensive pregnant women: office versus home patient- or nurse-measured blood pressure. Hypertens Pregnancy 2009 May;28(2):168-77. PMID: 19437227. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.19437227
284 Rhode MA, Shapiro H, Jones OW, III. Indicated vs. routine prenatal urine chemical reagent strip testing. J Reprod Med 2007 Mar;52(3):214-9. PMID: 17465289. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4.17465289
285 Risberg A, Larsson A, Olsson K, . Relationship between urinary albumin and albumin/creatinine ratio during normal pregnancy and pre-eclampsia. Scan J Clin Lab Invest 2004;64(1):17-23. PMID: 15025425. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE6, KQ4bE6, KQ4cE4, KQ5E4.15025425
286 Rizk DE, Agarwal MM, Pathan JY, . Predicting proteinuria in hypertensive pregnancies with urinary protein-creatinine or calcium-creatinine ratio. J Perinatol 2007 May;27(5):272-7. PMID: 17453039. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.17453039
287 Robert M, Sepandj F, Liston RM, . Random protein-creatinine ratio for the quantitation of proteinuria in pregnancy. Obstet Gynecol 1997 Dec;90(6):893-5. PMID: 9397097. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE10, KQ4bE2, KQ4cE2, KQ5E2.9397097
288 Rodrigue CZ, Jr., Weyer KL, Dornelles A, . Comparison of timed urine collection to protein-creatinine ratio for the diagnosis of preeclampsia. Obstet Gynecol 2014 May;123(Suppl):76s-7S. PMID: 24770270. KQ1E11, KQ1aE11, KQ2E11, KQ3E11, KQ4E11, KQ4aE11, KQ4bE11, KQ4cE11, KQ5E11.
289 Rodriguez-Thompson D, Lieberman ES. Use of a random urinary protein-to-creatinine ratio for the diagnosis of significant proteinuria during pregnancy. Am J Obstet Gynecol 2001 Oct;185(4):808-11. PMID: 11641656. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE6, KQ4bE4, KQ4cE4, KQ5E4.11641656
290 Rogers CJ, Hewison J, Tsigas E. [236-POS]: Patient perspectives on screening/diagnostic tests, clinical trials, and expectant management for preeclampsia. Pregnancy Hypertens 2015 Jan;5(1):119. PMID: 25787586. KQ1E11, KQ1aE11, KQ2E11, KQ3E11, KQ4E11, KQ4aE11, KQ4bE11, KQ4cE11, KQ5E11.
291 Ros HS, Cnattingius S, Lipworth L. Comparison of risk factors for preeclampsia and gestational hypertension in a population-based cohort study. Am J Epidemiol 1998 Jun 1;147(11):1062-70. PMID: 9620050. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.9620050
292 Ross-McGill H, Hewison J, Hirst J, . Antenatal home blood pressure monitoring: a pilot randomised controlled trial. BJOG 2000 Feb 1;107(2):217-21. PMID: 10688505. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.10688505
293 Rylander R, Bullarbo M. [162-POS] : Blood pressure criteria for the detection of pre-eclampsia. Pregnancy Hypertens 2015 Jan;5(1):84. PMID: 25787513. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.
294 Saftlas AF, Olson DR, Franks AL, . Epidemiology of preeclampsia and eclampsia in the United States, 1979-1986. Am J Obstet Gynecol 1990 Aug;163(2):460-5. PMID: 2386132. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.2386132
295 Sarno L, Maruotti GM, Saccone G, . Pregnancy outcome in proteinuria-onset and hypertension-onset preeclampsia. Hypertens Pregnancy 2015 Mar 23;34(3):284-90. PMID: 25799185. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.25799185
296 Saudan PJ, Brown MA, Farrell T, . Improved methods of assessing proteinuria in hypertensive pregnancy. Br J Obstet Gynaecol 1997 Oct;104(10):1159-64. PMID: 9332994. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE10, KQ4bE2, KQ4cE4, KQ5E4.9332994
297 Saudan PJ, Farrell TJ, Brown MA. Beta2-microglobulin in hypertensive pregnancies. Am J Kidney Dis 1998 Feb;31(2):308-12. PMID: 9469502. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.9469502
298 Savitz DA, Zhang J. Pregnancy-induced hypertension in North Carolina, 1988 and 1989. Am J Public Health 1992 May;82(5):675-9. PMID: 1566945. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.1566945
299 Saxena I, Kapoor S, Gupta RC. Detection of proteinuria in pregnancy: comparison of qualitative tests for proteins and dipsticks with urinary protein creatinine index. J Clin Diagn Res 2013 Sep;7(9):1846-8. PMID: 24179878. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.24179878
300 Scazzocchio E, Figueras F, Crispi F, . Performance of a first-trimester screening of preeclampsia in a routine care low-risk setting. Am J Obstet Gynecol 2013 Mar;208(3):203. PMID: 23246313. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.23246313
301 Schenone MH, Miller D, Samson JE, . Eclampsia characteristics and outcomes: a comparison of two eras. J Pregnancy 2013;2013:826045. PMID: 23691323. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.23691323
302 Schneider S, Freerksen N, Maul H, . Risk groups and maternal-neonatal complications of preeclampsia--current results from the national German Perinatal Quality Registry. J Perinat Med 2011 May;39(3):257-65. PMID: 21309631. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.21309631
303 Schubert FP, Abernathy MP. Alternate evaluations of proteinuria in the gravid hypertensive patient. J Reprod Med 2006 Sep;51(9):709-14. PMID: 17039700. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE10, KQ4bE2, KQ4cE2, KQ5E2.17039700
304 Schwartz WJ, III, Rayburn WF, Turnbull GL, . Blood pressure monitoring during pregnancy. Accuracy of portable devices designed for obese patients. J Reprod Med 1996 Aug;41(8):581-5. PMID: 8866385. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.8866385
305 Seed PT, Chappell LC, Black MA, . Prediction of preeclampsia and delivery of small for gestational age babies based on a combination of clinical risk factors in high-risk women. Hypertens Pregnancy 2011;30(1):58-73. PMID: 20795821. KQ1E12, KQ1aE12, KQ2E2, KQ3E2, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.20795821
306 Seong WJ, Chong GO, Hong DG, . Clinical significance of serum albumin level in pregnancy-related hypertension. J Obstet Gynaecol Res 2010 Dec;36(6):1165-73. PMID: 21040199. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.21040199
307 Seow KM, Tang MH, Chuang J, . The correlation between renal function and systolic or diastolic blood pressure in severe preeclamptic women. Hypertens Pregnancy 2005;24(3):247-57. PMID: 16263597. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.16263597
308 Sep SJ, Smits LJ, Prins MH, . Simple prepregnant prediction rule for recurrent early-onset hypertensive disease in pregnancy. Reprod Sci 2009 Jan;16(1):80-7. PMID: 19144890. KQ1E2, KQ1aE2, KQ2E2, KQ3E2, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.19144890
309 Sethuram R, Kiran TS, Weerakkody AN. Is the urine spot protein/creatinine ratio a valid diagnostic test for pre-eclampsia? J Obstet Gynaecol 2011;31(2):128-30. PMID: 21281026. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4bE4, KQ4cE4, KQ5E4.21281026
310 Shaarawy M, Salem ME. The clinical value of microtransferrinuria and microalbuminuria in the prediction of pre-eclampsia. Clin Chem Lab Med 2001 Jan;39(1):29-34. PMID: 11256797. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.11256797
311 Shennan A, Halligan A, Gupta M, . Oscillometric blood pressure measurements in severe pre-eclampsia: validation of the SpaceLabs 90207. Br J Obstet Gynaecol 1996 Feb;103(2):171-3. PMID: 8616136. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.8616136
312 Shennan A, Gupta M, Halligan A, . Lack of reproducibility in pregnancy of Korotkoff phase IV as measured by mercury sphygmomanometry. Lancet 1996 Jan 20;347(8995):139-42. PMID: 8544546. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.8544546
313 Shennan AH, Kissane J, de SM. Validation of the SpaceLabs 90207 ambulatory blood pressure monitor for use in pregnancy. Br J Obstet Gynaecol 1993 Oct;100(10):904-8. PMID: 8217971. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.8217971
314 Sibai BM, Gordon T, Thom E, . Risk factors for preeclampsia in healthy nulliparous women: a prospective multicenter study. The National Institute of Child Health and Human Development Network of Maternal-Fetal Medicine Units. Am J Obstet Gynecol 1995 Feb;172(2 Pt 1):642-8. PMID: 7856699. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.7856699
315 Sibai BM, Ewell M, Levine RJ, . Risk factors associated with preeclampsia in healthy nulliparous women. The Calcium for Preeclampsia Prevention (CPEP) Study Group. Am J Obstet Gynecol 1997 Nov;177(5):1003-10. PMID: 9396883. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.9396883
316 Sikorski J, Wilson J, Clement S, . A randomised controlled trial comparing two schedules of antenatal visits: the antenatal care project. BMJ 1996 Mar 2;312(7030):546-53. PMID: 8595286. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.8595286
317 Simeone S, Lojo C, Garcia-Esteve L, . Psychological impact of first-trimester prevention for preeclampsia on anxiety. Prenat Diagn 2015 Jan;35(1):60-4. PMID: 25156501. KQ1E12, KQ1aE12, KQ2E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25156501
318 Simonazzi G, Vicenzi C, Rizzo MA, . Prospective evaluation of the risk of pre-eclampsia using logistic regression analysis. Ultrasound Obstet Gynecol 2007 Sep;30(3):312-7. PMID: 17688308. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.17688308
319 Singh R, Tandon I, Deo S, . Does microalbuminuria at mid-pregnancy predict development of subsequent pre-eclampsia? J Obstet Gynaecol Res 2013 Feb;39(2):478-83. PMID: 22925380. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.22925380
320 Sirohiwal D, Dahiya K, Khaneja N. Use of 24-hour urinary protein and calcium for prediction of preeclampsia. Taiwan J Obstet Gynecol 2009 Jun;48(2):113-5. PMID: 19574169. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.19574169
321 Skrastad R, Hov G, Blaas HG, . Risk assessment for preeclampsia in nulliparous women at 11-13 weeks gestational age: prospective evaluation of two algorithms. BJOG 2014 Dec 4 PMID: 25471057. KQ1E12, KQ1aE12, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25471057
322 Skrastad RB, Hov GG, Blaas HG, . A prospective study of screening for hypertensive disorders of pregnancy at 11-13 weeks in a Scandinavian population. Acta Obstet Gynecol Scand 2014 Dec;93(12):1238-47. PMID: 25146367. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25146367
323 Smith CV, Selig CL, Rayburn WF, . Reliability of compact electronic blood pressure monitors for hypertensive pregnant women. J Reprod Med 1990 Apr;35(4):399-401. PMID: 2352232. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.2352232
324 Somanathan N, Farrell T, Galimberti A. A comparison between 24-hour and 2-hour urine collection for the determination of proteinuria. J Obstet Gynaecol 2003 Jul;23(4):378-80. PMID: 12881076. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.12881076
325 Stamilio DM, Sehdev HM, Morgan MA, . Can antenatal clinical and biochemical markers predict the development of severe preeclampsia? Am J Obstet Gynecol 2000 Mar;182(3):589-94. PMID: 10739512. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.10739512
326 Stone JL, Lockwood CJ, Berkowitz GS, . Risk factors for severe preeclampsia. Obstet Gynecol 1994 Mar;83(3):357-61. PMID: 8127525. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.8127525
327 Stout MJ, Scifres CM, Stamilio DM. Diagnostic utility of urine protein-to-creatinine ratio for identifying proteinuria in pregnancy. J Matern Fetal Neonatal Med 2013 Jan;26(1):66-70. PMID: 23020712. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4bE4, KQ4cE4, KQ5E4.23020712
328 Sukur YE, Yalcin I, Kahraman K, . Predictive value of 3+ spot urinary protein value measured by dipstick in hypertensive pregnant patients. Hypertens Pregnancy 2013 May;32(2):139-45. PMID: 23725079. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.23725079
329 Taherian AA, Dehbashi S, Baghban M. The relationship between random urinary protein-to-creatinine ratio and 24-hour urine protein in diagnosis of proteinuria in mild preeclampsia. J Res Med Sci 2006;11(1):6-12. PMID: None. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.
330 Takahashi K, Ohkuchi A, Suzuki H, . Biophysical interaction between blood pressure and uterine artery Doppler for the occurrence of early-onset preeclampsia: A prospective cohort study. Pregnancy Hypertens 2013 Oct;3(4):270-7. PMID: 26103807. KQ1E12, KQ1aE12, KQ2E3, KQ3E3, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.26103807
331 Tape TG, Rayburn WF, Bremer KD, . Ambulatory blood pressure monitoring during pregnancy with a new, small, easily concealed monitor. J Reprod Med 1994 Dec;39(12):968-72. PMID: 7884755. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.7884755
332 Taylor RS, Gamble G, McCowan L, . Sleep effects on ambulatory blood pressure measurements in pregnant women. Am J Hypertens 2001 Jan;14(1):38-43. PMID: 11206677. KQ1E6, KQ1aE6, KQ2E12, KQ3E12, KQ4E6, KQ4aE6, KQ4bE6, KQ4cE6, KQ5E6.11206677
333 Thornton CE, Makris A, Ogle RF, . Role of proteinuria in defining pre-eclampsia: clinical outcomes for women and babies. Clin Exp Pharmacol Physiol 2010 Apr;37(4):466-70. PMID: 19930427. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.19930427
334 Tomoda S, Tamura T, Kitanaka T, . First trimester biological markers for the prediction of pregnancy-induced hypertension. Am J Perinatol 1996 Feb;13(2):89-93. PMID: 8672192. KQ1E12, KQ1aE12, KQ2E4, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.8672192
335 Tranquilli AL, Giannubilo SR, Dell'Uomo B, . Prediction of gestational hypertension or intrauterine fetal growth restriction by mid-trimester 24-h ambulatory blood pressure monitoring. Int J Gynaecol Obstet 2004 May;85(2):126-31. PMID: 15099773. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.15099773
336 Tucker JS, Hall MH, Howie PW, . Should obstetricians see women with normal pregnancies? A multicentre randomised controlled trial of routine antenatal care by general practitioners and midwives compared with shared care led by obstetricians. BMJ 1996;312:554-9. PMID: 8595287. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.8595287
337 Tun C, Quinones JN, Kurt A, . Comparison of 12-hour urine protein and protein:creatinine ratio with 24-hour urine protein for the diagnosis of preeclampsia. Am J Obstet Gynecol 2012 Sep;207(3):233-8. PMID: 22939731. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4bE2, KQ4cE2, KQ5E2.22939731
338 Ukah UV. [247-POS]: Preliminary external validation of the fullPIERS risk prediction model for women with pre-eclampsia using the miniPIERS dataset. Pregnancy Hypertens 2015 Jan;5(1):124-5. PMID: 25787597. KQ1E12, KQ1aE12, KQ2E6, KQ3E6, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.
339 Uyar I, Kurt S, Demirtas O, . The value of uterine artery Doppler and NT-proBNP levels in the second trimester to predict preeclampsia. Arch Gynecol Obstet 2014 Dec 6;291(6):1253-8. PMID: 25480410. KQ1E12, KQ1aE12, KQ2E3, KQ3E3, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25480410
340 Vahdat M, Kashanian M, Sariri E, . Evaluation of the value of calcium to creatinine ratio for predicting of pre-eclampsia. J Matern Fetal Neonatal Med 2012 Dec;25(12):2793-4. PMID: 22866874. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.22866874
341 Valdes E, Sepulveda-Martinez A, Tong A, . Assessment of protein:creatinine ratio versus 24-hour urine protein in the diagnosis of preeclampsia. Gynecol Obstet Invest 2015 Jun 3 PMID: 26045043. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4bE4, KQ4cE4, KQ5E12.26045043
342 van Kuijk SM, Nijdam ME, Janssen KJ, . A model for preconceptional prediction of recurrent early-onset preeclampsia: derivation and internal validation. Reprod Sci 2011 Nov;18(11):1154-9. PMID: 21673281. KQ1E3, KQ1aE3, KQ2E2, KQ3E2, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.21673281
343 Verdonk K, Niemeijer I, Hop W, . Variation of urinary protein to creatinine ratio during the day in women with suspected pre-eclampsia. BJOG 2014 Apr 25;121(13):1660-5. PMID: 24762212. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4bE4, KQ4cE2, KQ5E2.24762212
344 Verghese L, Alam S, Beski S, . Antenatal screening for pre-eclampsia: evaluation of the NICE and pre-eclampsia community guidelines. J Obstet Gynaecol 2012 Feb;32(2):128-31. PMID: 22296420. KQ1E3, KQ1aE3, KQ2E3, KQ3E3, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.22296420
345 Verlohren S. Re: Longitudinal changes in maternal soluble endoglin and angiopoietin-2 in women at risk for pre-eclampsia. A. Khalil, N. Maiz, R. Garcia-Mandujano, M. Elkhouli and K. H. Nicolaides. Ultrasound Obstet Gynecol 2014; 44: 402-410. Ultrasound Obstet Gynecol 2014 Oct;44(4):386. PMID: 25274543. KQ1E3, KQ1aE3, KQ2E3, KQ3E3, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.25274543
346 Villar J, Ba'aqeel H, Piaggio G, . Who antenatal care randomised trial for the evaluation of a new model of routine antenatal care. Lancet 2001;357(9268):1551-64. PMID: 11377642. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.11377642
347 Villar J, Carroli G, Wojdyla D, . Preeclampsia, gestational hypertension and intrauterine growth restriction, related or independent conditions? Am J Obstet Gynecol 2006 Apr;194(4):921-31. PMID: 16580277. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.16580277
348 Vollebregt KC, Gisolf J, Guelen I, . Limited accuracy of the hyperbaric index, ambulatory blood pressure and sphygmomanometry measurements in predicting gestational hypertension and preeclampsia. J Hypertens 2010 Jan;28(1):127-34. PMID: 19770679. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.19770679
349 Vollebregt KC, Boer K, van der Post JA, . Association of three different techniques to measure blood pressure in the first trimester with the development of hypertensive disorders of pregnancy. Acta Obstet Gynecol Scand 2013 Jan;92(1):53-60. PMID: 22881432. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.22881432
350 Vreeburg SA, Jacobs DJ, Dekker GA, . Hypertension during pregnancy in South Australia, part 2: risk factors for adverse maternal and/or perinatal outcome - results of multivariable analysis. Aust N Z J Obstet Gynaecol 2004 Oct;44(5):410-8. PMID: 15387861. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.15387861
351 Walker SP, Permezel M, Brennecke SP, . Blood pressure in late pregnancy and work outside the home. Obstet Gynecol 2001 Mar;97(3):361-5. PMID: 11239637. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.11239637
352 Wang T, Zhou R, Gao L, . Elevation of Urinary Adipsin in Preeclampsia: Correlation With Urine Protein Concentration and the Potential Use for a Rapid Diagnostic Test. Hypertension 2014 Jun 23;64(4):846-51. PMID: 24958499. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.24958499
353 Waterstone M, Bewley S, Wolfe C. Incidence and predictors of severe obstetric morbidity: case-control study. BMJ 2001 May 5;322(7294):1089-93. PMID: 11337436. KQ1E12, KQ1aE12, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.11337436
354 Waugh J, Bell SC, Kilby M, . Effect of concentration and biochemical assay on the accuracy of urine dipsticks in hypertensive pregnancies. Hypertens Pregnancy 2001;20(2):205-17. PMID: 12044331. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4bE4, KQ4cE4, KQ5E4.12044331
355 Waugh J, Kilby M, Lambert P, . Validation of the DCA 2000 microalbumin:creatinine ratio urinanalyzer for its use in pregnancy and preeclampsia. Hypertens Pregnancy 2003;22(1):77-92. PMID: 12648445. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE3, KQ4bE2, KQ4cE2, KQ5E2.12648445
356 Waugh J, Bell SC, Kilby MD, . Urinary microalbumin/creatinine ratios: reference range in uncomplicated pregnancy. Clin Sci (Lond) 2003 Feb;104(2):103-7. PMID: 12546632. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.12546632
357 Waugh J, Habiba MA, Bosio P, . Patient initiated home blood pressure recordings are accurate in hypertensive pregnant women. Hypertens Pregnancy 2003;22(1):93-7. PMID: 12648446. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.12648446
358 Waugh J, Bell SC, Kilby MD, . Urine protein estimation in hypertensive pregnancy: which thresholds and laboratory assay best predict clinical outcome? Hypertens Pregnancy 2005;24(3):291-302. PMID: 16263601. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.16263601
359 Waugh JJ, Halligan AW, Shennan AH. Ambulatory monitoring and self-monitoring of blood pressure during pregnancy. Blood Press Monit 2000 Feb;5(1):3-10. PMID: 10804445. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.10804445
360 Waugh JJ, Bell SC, Kilby MD, . Optimal bedside urinalysis for the detection of proteinuria in hypertensive pregnancy: a study of diagnostic accuracy. BJOG 2005 Apr;112(4):412-7. PMID: 15777437. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E4, KQ4bE4, KQ4cE4, KQ5E4.15777437
361 Wen SW, Kramer MS, Hoey J, . Terminal digit preference, random error, and bias in routine clinical measurement of blood pressure. J Clin Epidemiol 1993 Oct;46(10):1187-93. PMID: 8410103. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.8410103
362 Wheeler TL, Blackhurst DW, Dellinger EH, . Usage of spot urine protein to creatinine ratios in the evaluation of preeclampsia. Am J Obstet Gynecol 2007 May;196(5):465-4. PMID: 17466704. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4bE2, KQ4cE2, KQ5E2.17466704
363 Widmer M, Cuesta CB, Khan K, . [93-OR]: Accuracy of angiogenic biomarkers for predicting preeclampsia: An observational study. Pregnancy Hypertens 2015 Jan;5(1):50. PMID: 25787319. KQ1E12, KQ1aE12, KQ2E6, KQ3E6, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25787319
364 Witlin AG, Saade GR, Mattar F, . Risk factors for abruptio placentae and eclampsia: analysis of 445 consecutively managed women with severe preeclampsia and eclampsia. Am J Obstet Gynecol 1999 Jun;180(6:Pt 1):t-9. PMID: 10368466. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.10368466
365 Wiwanitkit V. Periodic urinary protein creatinine ratio for predicting significant proteinuria in preeclampsia in different alternatives: time effectiveness analysis. Arch Gynecol Obstet 2010 Mar;281(3):571-3. PMID: 19568760. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.19568760
366 Woelkers D, Barton J, von DP, . [73-OR]: Rates of adverse outcomes are elevated in preterm patients with suspected hypertensive disorders without diagnostic criteria for preeclampsia. Pregnancy Hypertens 2015 Jan;5(1):39. PMID: 25787423. KQ1E3, KQ1aE3, KQ2E12, KQ3E12, KQ4E3, KQ4aE3, KQ4bE3, KQ4cE3, KQ5E3.
367 Woelkers D, Barton J, Dadelszen P, . [71-OR]: The revised 2013 ACOG definitions of hypertensive disorders of pregnancy significantly increase the diagnostic prevalence of preeclampsia. Pregnancy Hypertens 2015 Jan;5(1):38. PMID: 25787421. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.
368 Wright D, Akolekar R, Syngelaki A, . A competing risks model in early screening for preeclampsia. Fetal Diagn Ther 2012;32(3):171-8. PMID: 22846473. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.22846473
369 Wright D, Syngelaki A, Akolekar R, . Competing risks model in screening for preeclampsia by maternal characteristics and medical history. Am J Obstet Gynecol 2015 Feb 25;213(1):62. PMID: 25724400. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25724400
370 Yamada T, Kojima T, Akaishi R, . Problems in methods for the detection of significant proteinuria in pregnancy. J Obstet Gynaecol Res 2014 Jan;40(1):161-6. PMID: 24102664. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE10, KQ4bE6, KQ4cE6, KQ5E4.24102664
371 Yliniemi A, Nurkkala MM, Kopman S, . First Trimester Placental Retinol-Binding Protein 4 (RBP4) and Pregnancy-Associated Placental Protein A (PAPP-A) in the Prediction of Early-Onset Severe Pre-Eclampsia. Metabolism 2015 Apr;64(4):521-6. PMID: 25633269. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.25633269
372 Yliniemi A, Makikallio K, Korpimaki T, . Combination of PAPPA, fhCGbeta, AFP, PlGF, sTNFR1, and maternal characteristics in prediction of early-onset preeclampsia. Clin Med Insights Reprod Health 2015;9:13-20. PMID: 26106266. KQ1E12, KQ1aE12, KQ2E3, KQ3E3, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.26106266
373 Yogev Y, Langer O, Brustman L, . Pre-eclampsia and gestational diabetes mellitus: does a correlation exist early in pregnancy? J Matern Fetal Neonatal Med 2004 Jan;15(1):39-43. PMID: 15101610. KQ1E4, KQ1aE4, KQ2E12, KQ3E12, KQ4E4, KQ4aE4, KQ4bE4, KQ4cE4, KQ5E4.15101610
374 Young RA, Buchanan RJ, Kinch RA. Use of the protein/creatinine ratio of a single voided urine specimen in the evaluation of suspected pregnancy-induced hypertension. J Fam Pract 1996 Apr;42(4):385-9. PMID: 8627207. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4bE2, KQ4cE2, KQ5E2.8627207
375 Yu CK, Smith GC, Papageorghiou AT, . An integrated model for the prediction of preeclampsia using maternal factors and uterine artery Doppler velocimetry in unselected low-risk women. Am J Obstet Gynecol 2005 Aug;193(2):429-36. PMID: 16098866. KQ1E12, KQ1aE12, KQ2E13, KQ3E4, KQ4E12, KQ4aE12, KQ4bE12, KQ4cE12, KQ5E12.16098866
376 Zadehmodarres S, Razzaghi MR, Habibi G, . Random urine protein to creatinine ratio as a diagnostic method of significant proteinuria in pre-eclampsia. Aust N Z J Obstet Gynaecol 2006 Dec;46(6):501-4. PMID: 17116054. KQ1E1, KQ1aE1, KQ2E12, KQ3E12, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.17116054
377 Zanello M, Sekizawa A, Purwosunu Y, . Circulating mRNA for the PLAC1 gene as a second trimester marker (14-18 weeks' gestation) in the screening for late preeclampsia. Fetal Diagn Ther 2014;36(3):196-201. PMID: 25138310. KQ1E1, KQ1aE1, KQ2E1, KQ3E1, KQ4E1, KQ4aE1, KQ4bE1, KQ4cE1, KQ5E1.25138310
378 Zhang J, Klebanoff MA, Roberts JM. Prediction of adverse outcomes by common definitions of hypertension in pregnancy. Obstet Gynecol 2001 Feb;97(2):261-7. PMID: 11165592. KQ1E2, KQ1aE2, KQ2E12, KQ3E12, KQ4E2, KQ4aE2, KQ4bE2, KQ4cE2, KQ5E2.11165592