# Appendix C Preeclampsia Diagnostic Criteria Included in Major Guidelines and Recommendations, 1972–2013

Organization | Hypertension | Proteinuria | Other Diagnostic Indicators (Symptoms, Blood Test Results, or Health Outcomes)
United States
American College of Obstetricians and Gynecologists (ACOG) 2013, U.S.^1^ | Preeclampsia [underlined: must] include 1 of the following: SBP ≥140 mm Hg or DBP ≥90 mm Hg on 2 occasions >4 hours apart after 20 weeks' gestation in a previously normotensive woman If SBP ≥160 mm Hg or DBP ≥110 mm Hg, hypertension can be confirmed within a short interval to facilitate timely delivery of antihypertensive therapy Severe preeclampsia [underlined: may] include: SBP ≥160 mm Hg or DBP ≥110 mm Hg on 2 occasions >4 hours apart while the patient is on bed rest (unless antihypertensive therapy is initiated before this time) | Preeclampsia [underlined: may] include 1 of the following: ≥300 mg protein per 24-hour urine collection Protein:creatinine ratio ≥0.3 mg/dL Dipstick reading of 1+ (used only if other quantitative methods not available) Severe preeclampsia [underlined: may] include: Serum creatinine concentration >1.1 mg/dL or a doubling of the serum creatinine concentration in the absence of other renal disease | In the [underlined: absence of proteinuria], preeclampsia can be confirmed by new-onset hypertension [underlined: and] 1 of the following: Thrombocytopenia Renal insufficiency Impaired liver function Pulmonary edema Cerebral or visual symptoms Severe preeclampsia [underlined: may] include: Thrombocytopenia Progressive renal insufficiency Impaired liver function Pulmonary edema Cerebral or visual disturbances
American College of Obstetricians and Gynecologists (ACOG) 2002, U.S.^79^ Based on NHLBI Working Group 2000 | Preeclampsia [underlined: must] include: SBP ≥140 mm Hg or DBP ≥90 mm Hg presenting after 20 weeks' gestation in a previously normotensive woman Severe preeclampsia [underlined: may] include: SBP ≥160 mm Hg or DBP ≥110 mm Hg on 2 occasions ≥6 hours apart while on bed rest | Preeclampsia [underlined: must] include: ≥0.3 g protein per 24-hour urine collection (correlates with ≥1+ reading on dipstick but should be confirmed using a random urine evaluation) Severe preeclampsia [underlined: may] include: ≥5 g protein per 24-hour urine collection or dipstick ≥3+ on 2 random urine samples collected ≥4 hours apart | Preeclampsia [underlined: may] include: Edema Visual disturbances Headache Epigastric pain Hemolysis Elevated liver enzymes Low platelet counts (HELLP syndrome) Severe preeclampsia [underlined: may] include 1 of the following: Oliguria of <500 mL in 24 hours Cerebral or visual disturbances Pulmonary edema or cyanosis Epigastric or right upper-quadrant pain Impaired liver function Thrombocytopenia Fetal growth restriction
National Heart, Lung, and Blood Institute (NHLBI) Working Group 2000, U.S.^193^ Update of NHLBI Working Group 1990 | Preeclampsia [underlined: must] include: SBP >140 mm Hg or DBP >90 mm Hg presenting after 20 weeks' gestation in a previously normotensive woman | Preeclampsia [underlined: must] include: ≥0.3 g protein per 24-hour urine collection (correlates with ≥30 mg/dL in a random urine determination or ≥1+ reading on dipstick) | In the [underlined: absence of proteinuria], preeclampsia is highly suspected when hypertension appears with the following: Headache Blurred vision Abdominal pain Low platelet counts Abnormal liver enzyme values Edema occurs in too many women with normal pregnancies and has been removed as a marker in the classification of preeclampsia
National Heart, Lung, and Blood Institute (NHLBI) Working Group 1990, U.S.^194^ Minimally updated from ACOG 1972 | Preeclampsia [underlined: must] include 1 of the following: SBP ≥140 mm Hg or DBP ≥90 mm Hg presenting after 20 weeks' gestation in a previously normotensive woman SBP increases of ≥30 mm Hg or DBP increases of ≥15 mm Hg from early values before 20 weeks' gestation | Preeclampsia [underlined: may] include: ≥0.3 g protein per 24-hour urine collection (correlates with ≥30 mg/dL in a random urine determination or ≥1+ reading on dipstick) | Preeclampsia [underlined: may] include: Edema
United Kingdom
National Institute for Health and Care Excellence (NICE) 2010, U.K.^47^ Decision made on March 2015 that the guidelines should not be updated at this time | Preeclampsia [underlined: must] include: SBP ≥140 mm Hg or DBP ≥90 mm Hg presenting after 20 weeks' gestation in a previously normotensive woman Severe preeclampsia [underlined: must] include 1 of the following: SBP ≥160 mm Hg or DBP ≥110 mm Hg SBP ≥140 mm Hg or DBP ≥90 mm Hg (mild hypertension) or SBP ≥150 mm Hg or DBP ≥100 mm Hg (moderate hypertension) with other diagnostic indicators | Preeclampsia [underlined: must] include 1 of the following: >300 mg protein per 24-hour urine collection Protein:creatinine ratio >30 mg/mmol Severe preeclampsia [underlined: must] include 1 of the following: >300 mg protein per 24-hour urine collection Protein:creatinine ratio >30 mg/mmol | In the [underlined: absence of severe hypertension], features of severe preeclampsia include mild/moderate hypertension [underlined: and] proteinuria with ≥1 of the following: Severe headache Problems with vision such as blurring or flashing Severe pain just below ribs or vomiting Papilloedema Signs of clonus (≥3 beats) Liver tenderness HELLP syndrome Platelet count falls to <100 × 10^9^/L Abnormal liver enzymes
Canada
Society of Obstetricians and Gynecologists of Canada (SOGC) 2014, Canada^143^ | Preeclampsia [underlined: must] include: SBP ≥140 mm Hg or DBP ≥90 mm Hg (based on the average of ≥2 measurements taken ≥15 minutes apart) after 20 weeks' gestation in a previously normotensive woman | Preeclampsia [underlined: may] include 1 of the following: ≥0.3 g protein per 24-hour urine collection ≥30 mg/mmol urinary creatinine in a spot (random) urine sample | In the [underlined: absence of proteinuria], preeclampsia can be confirmed by new-onset hypertension [underlined: and] 1 of the following: Adverse condition (headache, visual symptoms, chest pain, low platelet count, nausea or vomiting, epigastric pain) Severe complication (eclampsia, stroke, uncontrolled severe hypertension, platelet count <50 × 10^9^/L, acute kidney injury, hepatic dysfunction, abruption with evidence of maternal fetal compromise)

Abbreviations: DBP=diastolic blood pressure; HELLP=hemolysis, elevated liver enzymes, low platelet count; SBP=systolic blood pressure.