# Appendix B Detailed Methods

## Literature Search Strategies – Systematic Reviews

Database: Ovid MEDLINE(R) without Revisions <1996 to November Week 2 2013>, Ovid MEDLINE(R) Daily Update <November 20, 2013>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <November 20, 2013>

Search Strategy:

----------------------------------------------------------------------------------------

1. Pre-Eclampsia/ ()
2. Hypertension, Pregnancy-Induced/ ()
3. Eclampsia/ ()
4. Pregnancy/ ()
5. Hypertension/ ()
6. 4 and 5 ()
7. 1 or 2 or 3 or 6 ()
8. Mass screening/ ()
9. Biological markers/ ()
10. Ultrasonography, Doppler/ ()
11. “Predictive Value of Tests”/ ()
12. “Sensitivity and Specificity”/ ()
13. Diagnostic errors/ ()
14. Risk factors/ ()
15. Risk assessment/ ()
16. (screen$ or diagnos$ or predict$ or detect$ or risk$).ti. ()
17. 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 ()
18. 7 and 17 ()
19. Pre-Eclampsia/di ()
20. Hypertension, Pregnancy-Induced/di ()
21. Eclampsia/di ()
22. 18 or 19 or 20 or 21 ()
23. preeclamp$.ti,ab. ()
24. eclamp$.ti,ab. ()
25. gestosis.ti,ab. ()
26. ((gestational or pregnan$) adj5 (tox?emi$ or hypertens$)).ti,ab. ()
27. 23 or 24 or 25 or 26 ()
28. (screen$ or diagnos$ or predict$ or detect$ or risk$).ti,ab. ()
29. 27 and 28 ()
30. limit 29 to (“in data review” or in process or “pubmed not medline”) ()
31. 22 or 30 ()
32. limit 31 to systematic reviews ()
33. limit 32 to (english language and yr=“2009 -Current”) ()
34. remove duplicates from 33 ()

## Literature Search Strategies – Primary Literature

### MEDLINE

Database: Ovid MEDLINE(R) <1946 to March Week 4 2015>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations < April 2, 2015>, Ovid MEDLINE(R) Daily Update <April 2, 2015>

Search Strategy:

----------------------------------------------------------------------------------------

1. Pre-Eclampsia/ ()
2. Hypertension, Pregnancy-Induced/ ()
3. Eclampsia/ ()
4. Pregnancy/ ()
5. Pregnancy Trimester, First/ ()
6. Pregnancy Trimester, Second/ ()
7. Pregnancy Trimester, Third/ ()
8. Hypertension/ ()
9. (4 or 5 or 6 or 7) and 8 ()
10. (preeclamp$ or pre eclamp$).ti. ()
11. eclamp$.ti. ()
12. gestosis.ti. ()
13. ((gestational or pregnan$) and (tox?emi$ or hypertens$ or blood pressure)).ti. ()
14. 1 or 2 or 3 or 9 or 10 or 11 or 12 or 13 ()
15. Blood pressure/ ()
16. Blood pressure determination/ ()
17. Blood pressure monitoring, Ambulatory/ ()
18. Blood pressure monitors/ ()
19. Urinalysis/ ()
20. Uric acid/ ()
21. Proteinuria/ ()
22. Pregnancy Proteins/ ()
23. Uterine Artery/us ()
24. Ultrasonography, Doppler/ ()
25. Creatinine/ur ()
26. Biological Markers/ ()
27. Pregnancy-Associated Plasma Protein-A/ ()
28. ((blood or systolic or diastolic) adj pressure).ti,ab. ()
29. urinalys$.ti,ab. ()
30. (urine adj (measur$ or analy$ or test$ or collect$)).ti,ab. ()
31. uric acid.ti,ab. ()
32. (proteinuria or albuminuria or urine albumin).ti,ab. ()
33. (ultrasound or ultrasonography).ti,ab. ()
34. uterine artery doppler.ti,ab. ()
35. ((biological or serum) adj3 (marker$ or biomarker$)).ti,ab. ()
36. plasma protein a.ti,ab. ()
37. or/15-36 ()
38. Mass screening/ ()
39. screen$.ti,ab. ()
40. (detect$ or predict$ or identif$).ti. ()
41. 38 or 39 or 40 ()
42. 14 and (37 or 41) ()
43. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/ ()
44. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt. ()
45. Random$.ti,ab. ()
46. control groups/ or double-blind method/ or single-blind method/ ()
47. clinical trial$.ti,ab. ()
48. controlled trial$.ti,ab. ()
49. meta analy$.ti,ab. ()
50. epidemiologic studies/ or cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or retrospective studies/ ()
51. cohort$.ti,ab. ()
52. longitudinal.ti,ab. ()
53. incidence stud$.ti,ab. ()
54. retrospective.ti,ab. ()
55. (follow-up or followup).ti,ab. ()
56. prospective.ti,ab. ()
57. 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 ()
58. 42 and 57 ()
59. limit 58 to (english language and yr=“1990 -Current”) ()
60. remove duplicates from 59 ()
61. Risk/ ()
62. Risk factors/ ()
63. Risk assessment/ ()
64. risk$.ti,ab. ()
65. multivariable prediction.ti,ab. ()
66. 61 or 62 or 63 or 64 or 65 ()
67. 14 and 66 ()
68. limit 67 to (english language and yr=“1990 -Current”) ()
69. remove duplicates from 68 ()
70. “Sensitivity and Specificity”/ ()
71. “Predictive Value of Tests”/ ()
72. ROC Curve/ ()
73. False Negative Reactions/ ()
74. False Positive Reactions/ ()
75. Diagnostic Errors/ ()
76. “Reproducibility of Results”/ ()
77. Reference Values/ ()
78. Reference Standards/ ()
79. Observer Variation/ ()
80. Receiver operat$.ti,ab. ()
81. ROC curve$.ti,ab. ()
82. sensitivit$.ti,ab. ()
83. specificit$.ti,ab. ()
84. predictive value.ti,ab. ()
85. accuracy.ti,ab. ()
86. false positive$.ti,ab. ()
87. false negative$.ti,ab. ()
88. miss rate$.ti,ab. ()
89. error rate$.ti,ab. ()
90. 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 ()
91. 42 and 90 ()
92. limit 91 to (english language and yr=“1990 -Current”) ()
93. remove duplicates from 92 ()
94. Mortality/ ()
95. Morbidity/ ()
96. Death/ ()
97. safety.ti,ab. ()
98. harm$.ti,ab. ()
99. mortality.ti,ab. ()
100. complication$.ti,ab. ()
101. (death or deaths).ti,ab. ()
102. ((adverse or unintended or negative) adj (effect$ or event$ or reaction$ or outcome$)).ti,ab. ()
103. (adverse effects or mortality).fs. ()
104. Cesarean Section/ ()
105. Magnesium Sulfate/to ()
106. Anxiety/ ()
107. Stress, Psychological/ ()
108. Premature Birth/ ()
109. (cesarean$ or c-section$).ti,ab. ()
110. hypermagnesemi$.ti,ab. ()
111. (anxiety or anxious).ti,ab. ()
112. ((psychological or psychosocial or mental) adj (stress or distress or outcome$)).ti,ab. ()
113. ((preterm or premature$) adj (birth$ or deliver$)).ti,ab. ()
114. misdiagnos$.ti,ab. ()
115. overdiagnos$.ti,ab. ()
116. misclassification$.ti,ab. ()
117. ((unnecessary or unneeded) adj3 (treat$ or induc$ or monitor$)).ti,ab. ()
118. (increase$ adj3 monitor$).ti,ab. ()
119. or/94-118 ()
120. 42 and 119 ()
121. limit 120 to (english language and yr=“1990 -Current”) ()
122. remove duplicates from 121 ()
123. 60 or 69 or 93 or 122 ()
124. Animal/ not (Animal/ and Human/) ()
125. 123 not 124 ()

### PubMed

Query

- Search ((#24) AND publisher[sb]) AND English[Language]) AND (“1990”[Date - Publication]: “3000”[Date - Publication])
- Search (#10 AND #23)
- Search #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22
- Search “multivariable prediction”[tiab]
- Search risk*[tiab]
- Search “plasma protein a”[tiab]
- Search biological marker*[tiab] OR biological biomarker*[tiab] OR serum marker*[tiab] OR serum biomarker*[tiab]
- Search “uterine artery doppler”[tiab]
- Search (ultrasound[tiab] or ultrasonography[tiab])
- Search (proteinuria[tiab] or albuminuria[tiab] or “urine albumin”[tiab])
- Search urine[tiab] AND (measur*[tiab] OR analy*[tiab] OR test*[tiab] OR collect*[tiab])
- Search urinalys*[tiab]
- Search blood pressure[tiab] OR systolic pressure[tiab] OR diastolic pressure[tiab]
- Search (detect*[title] OR predict*[title] OR identif*[title])
- Search screen*[tiab]
- Search (#8 OR #9)
- Search (hypertens*[title] OR blood pressure[title] OR toxemi*[title] OR toxaemi*[title]) AND (gestational[title] OR pregnan*[title])
- Search pre eclampsia[title] OR preeclampsia[title] OR pre eclamptic[title] OR preeclamptic[title] or eclampsia[title] or eclamptic[title] or gestosis[title])

### Cochrane Central Register of Controlled Clinical Trials (http://www.cochranelibrary.com/) (CENTRAL)

#1 preeclamp*:ti,ab,kw
#2 (pre-eclampsia or pre-eclamptic):ti,ab,kw
#3 eclamp*:ti,ab,kw
#4 gestosis:ti,ab,kw
#5 #1 or #2 or #3 or #4
#6 hypertension:ti,ab,kw
#7 hypertensive:ti,ab,kw
#8 (toxemi*:ti,ab,kw or toxaemi*:ti,ab,kw)
#9 “blood pressure”:ti,ab,kw near/5 (high or elevated or abnormal):ti,ab,kw
#10 #6 or #7 or #8 or #9
#11 “pregnancy”:ti,ab,kw
#12 “pregnant”:ti,ab,kw
#13 gestational:ti,ab,kw
#14 #11 or #12 or #13
#15 #10 and #14
#16 #5 or #15
#17 screen*:ti,ab,kw
#18 (detect* or predict* or identif*):ti
#19 (blood or systolic or diastolic):ti,ab,kw next pressure:ti,ab,kw
#20 urinalys*:ti,ab,kw
#21 urine:ti,ab,kw next (measur* or analy* or test* or collect*):ti,ab,kw
#22 (proteinuria or albuminuria or “urine albumin”):ti,ab,kw
#23 (ultrasound or ultrasonography):ti,ab,kw
#24 “uterine artery doppler”:ti,ab,kw
#25 (biological or serum):ti,ab,kw near/3 (marker* or biomarker*):ti,ab,kw
#26 “plasma protein a”:ti,ab,kw
#27 risk*:ti,ab,kw
#28 “multivariable prediction”:ti,ab,kw
#29 #17 or #18 or #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27 or #28
#30 #16 and #29 Publication Year from 1990 to 2014, in Trials

Appendix B Figure 1 Literature Flow Diagram

^*^We included four studies (7 articles) on externally validated risk prediction models. We also identified 11 articles that represent the model development studies related to the external validation studies.

Abbreviations: KQ=key question.

This figure is a flow chart that summarizes the search and selection of articles in the review. There were 13,820 citations identified through literature databases. An additional 177 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 10,082 unique citations were screened at the title/abstract stage. The full-text of 378 citations were examined for inclusion for one or more of the Key Questions. The following number of studies were included for Key Question 1a (k=1), Key Question 2 (k=4), and Key Question 3 (k=1), Key Question 4a (k=14), and Key Question 5 (k=2). Reasons for excluding the other studies are available in Appendix D.

Appendix B Table 1 Inclusion and Exclusion Criteria

| Inclusion Criteria | Exclusion Criteria
Populations | All pregnant women without a diagnosis of preeclampsia and asymptomatic for preeclampsia including pregnant women with common chronic conditions seen in primary care (i.e., hypertension, diabetes mellitus) and at elevated risk for preeclampsia | Studies that exclusively include individuals seeking high-risk obstetric care (e.g., in-vitro fertilization); inpatients or hospitalized; other selected non-generalizable populations or populations with other preexisting health conditions (e.g., HIV, HPV, hepatitis, autoimmune disorders, polycystic ovarian syndrome, renal disease, organ transplant recipients, sickle cell trait)
Disease/Condition | KQ1, 1a: Eclampsia, maternal morbidity and mortality, perinatal/neonatal morbidity and mortality KQ2, KQ4: Preeclampsia KQ3, KQ5: Eclampsia, maternal morbidity and mortality (including psychological effects of risk assessment and screening), perinatal/neonatal morbidity and mortality
Interventions: Preeclampsia Risk Assessment and Screening | KQs 1, 4, 5: Screening occurs from 20 weeks gestation to delivery. Screening tests for preeclampsia are blood pressure measurement and urine protein tests KQ4a: Point of care urine tests (e.g., dipstick or random urine spot test) KQs 2, 3: Risk assessment occurring before 20 weeks gestation using multivariable prediction tools for the identification of women at high risk for preeclampsia | Experimental tests that are not routinely used for preeclampsia screening in clinical practice Secondary evaluations and tests used to assess preeclampsia severity or confirm diagnosis in symptomatic women Urine screening tests requiring ongoing collection of urine 24 hour ambulatory blood pressure measurements Risk assessment occurring after 20 weeks gestation Non-routine screening tests: Serum markers (e.g., angiogenic factors, activated protein C, calcium, HCG, HCy, hormones, lipids, thyroid hormone levels) Genetic susceptibility markers (e.g., fetal DNA) Ultrasound measurements (e.g., Doppler ultrasound pulsatility index or resistance index; pulse wave velocity or notching)
Comparisons | KQ 1: No screening, different screening protocols (e.g., modality, timing, rescreen interval) KQ3: Usual care; low risk KQs 4, 5: Different blood pressure and proteinuria screening protocols (e.g., instrument, procedure, timing, frequency) and screening protocols KQ4a: Reference standard is 24 hour urine collection (for proteinuria) | Reference standard other than 24 hour urine collection for protein measurement
Outcomes | KQ1 (maternal and perinatal health outcomes): Maternal mortality and serious morbidity (e.g., organ or system failure or injury, eclampsia) and perinatal or neonatal mortality and serious morbidity (e.g., intrauterine growth restriction, low birth weight, brain injury) KQs 2 (intermediate outcome): Prediction, discrimination, calibration outcomes for preeclampsia risk prediction model (e.g., AUC, Brier score) KQ 4 (intermediate outcomes): Test performance characteristics, sensitivity, specificity, for accuracy and effectiveness of screening. KQs 3, 5 (harms): Misclassification, increased monitoring, false positives, overdiagnosis, overtreatment (e.g., failed induction, Cesarean section, induced preterm birth, hypermagnesemia), and patient stress and anxiety | Nonclinical health outcomes, such as length of hospital stay (without indication), intensive care unit admission, or neonatal intensive care unit admission. KQ 4: Bivariable or multivariable regression (e.g., correlations)
Setting | Primary care outpatient settings for obstetric care (e.g., obstetrician gynecologists, family physicians, certified nurse midwives) Countries categorized as “Very High” or equivalent on the Human Development Index (as defined by the World Health Organization, 2014) | Clinics and study sites treating only high risk maternity patients Countries not categorized as “Very High” on the Human Development Index or not applicable to U.S. clinical settings or populations
Study Designs | KQ1: RCTs KQ2: Nested case-control or cohort study aiming to externally validate a multivariable clinical risk prediction tool; randomized impact studies comparing clinical risk prediction based care to usual care KQ4: RCTs, cohort studies, instrument validation studies, and test accuracy studies KQs 3, 5: RCTs or observational studies (e.g., nested case control, case series, cohort, registry, survey data) | KQ1: Case-control study, editorial, narrative review, commentary, postmarketing surveillance, and case report. KQ4: Case-control study, editorial, narrative review, commentary, postmarketing surveillance, and case reports KQs 3, 5: Editorial, narrative review, commentary, postmarketing surveillance, and case reports
Publication Dates | Studies published after January 1990, all references from the previous USPSTF review, and eligible studies identified through a bridge search | Studies published before 1990
Study Quality | Good and fair quality according to USPSTF design-specific criteria | Poor quality according to USPSTF design-specific criteria
Language | English | Non-English studies

* Settings: Included Countries: All countries listed as “very high” or equivalent on human development on the Human Development Index, 2014 (http://hdr.undp.org/en/statistics/): Andorra, Argentina, Australia, Austria, Barbados, Belgium, Brunei Darussalam, Canada, Chile, Croatia, Cyprus, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hong Kong, Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea, Latvia, Liechtenstein, Lithuania, Luxembourg, Malta, Netherlands, New Zealand, Norway, Poland, Portugal, Qatar, Seychelles, Singapore, Slovakia, Slovenia, Spain, Sweden, Switzerland, Taiwan, United Arab Emirates, United Kingdom, United States

Abbreviations: RCT=randomized, controlled trial.

Appendix B Table 2 Quality Assessment Criteria

Study Design | Adapted Quality Criteria
Randomized controlled trials, adapted from the U.S. Preventive Services Task Force methods^87^ | Was there valid random assignment? Was allocation concealed? Was eligibility criteria specified? Were groups similar at baseline? Were the outcome assessors blinded? Was there intervention fidelity? Was there adequate adherence to the intervention? Were measurements equal, valid and reliable? Was there acceptable followup? Was there a difference between those who completed the study and those who withdrew? Was the handling of missing data appropriate? Were the statistical methods acceptable? Was there evidence of selective reporting of outcomes?
Observational studies (e.g., prospective cohort studies), adapted from the Newcastle-Ottawa Scale (NOS)^89^ | Was there representativeness of the exposed cohort? Was the non-exposed systematically selected? Was the ascertainment of exposure reported? Was eligibility criteria specified? Comparability of cohorts on the basis of design or analysis? Was the outcome of interest not present at baseline? Were measurements equal, valid and reliable? Were outcome assessors blinded? Was followup long enough for the outcome to occur? Was there adequate followup of cohorts? Was there adjustment for confounders? Were the statistical methods acceptable? Was the handling of missing data appropriate?
Diagnostic accuracy studies, adapted from the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) II instrument^88^ | Could the selection of patients have introduced bias? Was a consecutive or random sample of patients enrolled? Was a case-control design avoided? Did the study avoid inappropriate exclusions? Could the conduct or interpretation of the index test have introduced bias? Was the index test interpreted without knowledge of the reference standard results? If a threshold was use, was it pre-specified? Was the fidelity of the index test monitored and/or reported? Could the conduct or interpretation of the reference standard have introduced bias? Was the reference standard interpreted without knowledge of the index test results? Was the fidelity of the reference test monitored and/or reported? Could the patient flow have introduced bias? Was there an appropriate interval between the index test and reference standard? Did all patients receive the same reference standard? Did all patient complete all tests? Were all patients completing both tests included in the analysis?
Before-After ^89^ | Is the post-intervention group representative? Is the pre-intervention group representative? Are the pre- and post-intervention groups comparable on the basis of design or analysis? Was the assessment of outcomes valid? Was the assessment of outcomes reliable? Was the method of outcome assessment the same for the pre- and post-intervention groups? Did the study report the point of time when the intervention occurred? Was the intervention clearly described? Were the data collected during a similar timeframe?