# Appendix A Evidence on Preeclampsia Interventions to Reduce Morbidity and Mortality

Induction of labor/early delivery. Upon delivery, blood pressure and laboratory readings generally return to normal range values within a few days, although some women experience persistent high blood pressure that usually resolves within six weeks.^174^ While delivery of the placenta is the only definitive treatment for preeclampsia, there are potential disadvantages including increased risk of neonatal complications^175^ and increased risk of caesarean section.^176^ Clinical decisions are based on the balance between risks of expectant management versus the risks of immediate induction of labor.^177^ In cases of severe preeclampsia before 34 weeks of gestation, the effect of early delivery on neonatal and maternal outcomes is uncertain, with the exception of a decrease in the proportion of small for gestational age infants.^178-180^ Between 34 and 37 weeks of gestation, little is known about the risks of continuing pregnancy versus immediate delivery in women with preeclampsia.^181,182^

To date, the only published prospective trials of gestational hypertension management are the HYPITAT^183^ and HYPITAT-II^177^ trials, both large multicenter open-label randomized controlled trials (RCTs) from the Netherlands evaluating the induction of labor versus expectant monitoring of hypertensive disorders at specific times during pregnancy. The first HYPITAT study found that immediate delivery reduced the risk of composite adverse maternal outcomes for women with preeclampsia after 37 weeks (RR, 0.71 [95% CI, 0.59 to 0.86]; p<0.0001), with no differences in rates of cesarean section or neonatal outcomes.^183^ Although trial evidence for assessing differences in outcomes with expectant management versus induced delivery was limited,^184^ recommendations generally favor^1,51,143^ induction of labor rather than continuing observation in women with preeclampsia at term (≥ 37 weeks) as it reduces the time the mother and fetus are at risk of injury from preeclampsia complications, such as eclampsia and placental abruption.^185^

For pregnant women diagnosed with preeclampsia without severe features at less than 37 weeks, expectant management, monitoring for disease progression rather than immediate delivery, is recommended.^1,47,51^ The HYPITAT-II trial found that for pregnant women with nonsevere hypertensive disorders (systolic blood pressure less than 170 mm Hg or diastolic blood pressure less than 110 mm Hg) between 34 to 36 weeks gestation, immediate delivery may slightly reduce the small risk of adverse maternal outcomes, but significantly increase the risk of neonatal respiratory distress syndrome.^177^ Recommendations for preeclampsia with severe features between 34 and 37 weeks gestation are varied. Both the Society of Obstetricians and Gynecologists of Canada (SOGC) and National Institute for Health and Care Excellence (NICE) recommend delivery for all women who have preeclampsia with severe hypertension after 34 weeks,^47,143^ while the World Health Organization (WHO) advises a policy of expectant management provided that uncontrolled maternal hypertension, maternal organ dysfunction or fetal distress are absent.^51^

Trial evidence on the health outcomes associated with delivery versus expectant management of severe preeclampsia occurring before 34 weeks is limited and inconclusive.^186^

Magnesium sulfate. Magnesium sulfate (MgSO_4_) has been routinely used for the prevention of eclampsia seizures since the middle of the 20^th^ century.^187^ The Magpie Trial (n=10,141), an important international randomized placebo-controlled trial of magnesium sulfate to prevent eclampsia, established clear evidence of a benefit for preventing eclampsia with magnesium sulfate among women for whom there was clinical uncertainty as to whether it should be administered.^49^ Pregnant women given magnesium sulfate (n=40) had a 58 percent lower risk of eclampsia (95% CI, 40 to 71]) than those allocated placebo (n=96).^49^ Maternal mortality was also lower in the treatment group, although there were few cases (n=11; 0.2%) and the difference was not statistically significant (RR, 0.55 [95% CI, 0.26 to 1.14]).^49^ Placental abruption was significantly lower in the treatment group, and there was no evidence of short term or longer term (up to 2 years) harms to the mother or offspring from the treatment. Following the trial, clinical management protocols have unequivocally recommended treatment of women with worsening or severe manifestations of preeclampsia to receive magnesium sulfate during delivery. A followup study of the Magpie Trial found that the use of magnesium sulfate in preeclamptic women demonstrated a 16 percent reduction in mortality and morbidity risk related to preeclampsia two to three years after delivery,^188^ and no association with any difference in mortality and morbidity risk in children (18 months) whose mothers were recruited to the trial.^189^ A recent Cochrane review of anticonvulsant management of preeclampsia found that magnesium sulfate more than halved the risk of eclampsia and likely reduced maternal death.^182^

Guideline groups strongly agree on the importance of magnesium sulfate as first-line treatment of eclampsia as well as prophylaxis against eclampsia in women with severe preeclampsia.^1,47,51,143^

Antihypertensive medications. Severe hypertension in pregnancy, regardless of the diagnosis of preeclampsia, poses a serious health risk to a pregnant woman and her fetus, and the use of antihypertensive medications is sometimes necessary to lower blood pressure to a safe range.^190,191^ Antihypertensive medications are used to prevent potential cardiovascular, renal, or cerebrovascular complications related to uncontrolled severe hypertension. The American Heart Association/American Stroke Association (AHA/ASA)^43^ along with other professional guideline groups^1,47,51,143^ strongly recommend that women with severe hypertension during pregnancy be treated with safe and effective antihypertensive medications. The benefit of antihypertensive therapy is highlighted by the results of a 2014 retrospective chart review of over 1.2 million women delivering in a U.S. hospital system.^57^ The analysis found a significant reduction in deaths from preeclampsia (15 to 3; p=0.02) following implementation of an automatic protocol for antihypertensive treatment during pregnancy.^57^ There is not consensus, however, regarding the management of nonsevere hypertension.^191^ A recent Cochrane review of 49 trials assessed the effects of antihypertensive drug treatments for pregnant women with mild to moderate hypertension and found no statistically significant difference in preeclampsia risk, and no evidence of benefit or harm to the fetus.^192^