# References

1 American College of Obstetricians and Gynecologists. ACOG Practice Bulletin no. 109: Cervical cytology screening. Obstet Gynecol. 2009;114(6):1409-20. PMID: 20134296.20134296
2 Moyer VA. Screening for cervical cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2012;156(12):880-91, w312. PMID: 22711081.22711081
3 Committee on Practice B-G. ACOG Practice Bulletin Number 131: Screening for cervical cancer. Obstetrics & Gynecology. 2012;120(5):1222-38. PMID: 23090560.23090560
4 Westhoff CL, Jones HE, Guiahi M. Do new guidelines and technology make the routine pelvic examination obsolete? J Womens Health (Larchmt). 2011;20(1):5-10. PMID: 21194307.21194307
5 Sawaya GF. Pelvic examinations in asymptomatic women: tipping a sacred cow. Arch Intern Med. 2011;171(22):2054-5. PMID: 22158577.22158577
6 Sawaya GF, Jacoby V. Screening pelvic examinations: right, wrong, or rite? Ann Intern Med. 2014;161(1):78-9. PMID: 24979453.24979453
7 Burns RB, Potter JE, Ricciotti HA, . Screening Pelvic Examinations in Adult Women: Grand Rounds Discussion From the Beth Israel Deaconess Medical Center. Ann Intern Med. 2015;163(7):537-47. PMID: 26436618.26436618
8 American College of Obstetricians and Gynecologists. Committee Opinion: Well-Woman Visit. http://www.acog.org/Resources-And-Publications/Committee-Opinions/Committee-on-Gynecologic-Practice/Well-Woman-Visit. Accessed 08/21/2014.
9 Qaseem A, Humphrey LL, Harris R, . Screening pelvic examination in adult women: a clinical practice guideline from the American College of Physicians. Ann Intern Med. 2014;161(1):67-72. PMID: 24979451.24979451
10 American College of Obstetricians and Gynecologists. ACOG Practice Advisory on Annual Pelvic Examination Recommendations. http://www.acog.org/About-ACOG/News-Room/Practice-Advisories/ACOG-Practice-Advisory-on-Annual-Pelvic-Examination-Recommendations. Accessed 11/05/2015.
11 Sirovich BE, Welch HG. The frequency of Pap smear screening in the United States. J Gen Intern Med. 2004;19(3):243-50. PMID: 15009779.15009779
12 Stormo AR, Cooper CP, Hawkins NA, . Physician characteristics and beliefs associated with use of pelvic examinations in asymptomatic women. Preventive medicine. 2012;54(6):415-21. PMID: 22484240.22484240
13 Henderson JT, Harper CC, Gutin S, . Routine bimanual pelvic examinations: practices and beliefs of US obstetrician-gynecologists. American journal of obstetrics and gynecology. 2013;208(2):109.e1-7. PMID: 23159688.23159688
14 Herman CR, Gill HK, Eng J, . Screening for preclinical disease: test and disease characteristics. AJR Am J Roentgenol. 2002;179(4):825-31. PMID: 12239019.12239019
15 Herman C. What makes a screening exam “good”? The virtual mentor : VM. 2006;8(1):34-7. PMID: 23232314.23232314
16 Buys SS, Partridge E, Greene MH, . Ovarian cancer screening in the Prostate, Lung, Colorectal and Ovarian (PLCO) cancer screening trial: findings from the initial screen of a randomized trial. Am J Obstet Gynecol. 2005;193(5):1630-9. PMID: 16260202.16260202
17 National Center for Health Statistics CfDCaP. National Ambulatory Medical Care Survey: 2012 Summary Tables. http://www.cdc.gov/nchs/data/ahcd/namcs_summary/2012_namcs_web_tables.pdf. Accessed 07/28/2016.
18 Medicare Learning Network CfMaMS, Department of Health and Human Services. Screening Pelvic Examinations. https://www.cms.gov/Outreach-and-Education/Medicare-Learning-Network-MLN/MLNProducts/Downloads/Screening-Pelvic-Examinations.pdf. Accessed 11/10/2015.
19 American Academy of Family Physicians. Clinical Practice Guideline: Screening Pelvic Examination in Adult Women. http://www.aafp.org/patient-care/clinical-recommendations/all/screeningpelvicexam.html. Accessed 11/05/2015.
20 Conry JA, Brown H. Well-Woman Task Force: Components of the Well-Woman Visit. Obstet Gynecol. 2015;126(4):697-701. PMID: 26348188.26348188
21 Doroudi M, Kramer BS, Pinsky PF. The bimanual ovarian palpation examination in the Prostate, Lung, Colorectal and Ovarian cancer screening trial: Performance and complications. J Med Screen. 2016. PMID: 27903809.27903809
22 Wallace BC, Small K, Brodley CE, . Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proceedings of the 2nd ACM SIGHIT International Health Informatics Symposium; Miami, Florida, USA. Writing: ACM; 2012. p. 819-24.
23 United Nations Development Programme. 2014 Human Development Report. http://www.undp.org/content/undp/en/home/presscenter/events/2014/july/HDR2014.html. Accessed 04/13/2016.
24 Wells GA, O'Connell, D., Peterson, J., Welch, V., Losos, M., Tugwell, P. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analysis. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed 11/09/2015.
25 Whiting P, Rutjes AW, Reitsma JB, . The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. PMID: 14606960.14606960
26 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529-36. PMID: 22007046.22007046
27 Harris RP, Helfand M, Woolf SH, . Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. PMID: 11306229.11306229
28 Jacobs I, Stabile I, Bridges J, . Multimodal approach to screening for ovarian cancer. Lancet. 1988;1(8580):268-71. PMID: 2893084.2893084
29 Adonakis GL, Paraskevaidis E, Tsiga S, . A combined approach for the early detection of ovarian cancer in asymptomatic women. European Journal of Obstetrics, Gynecology, & Reproductive Biology. 1996;65(2):221-5. PMID: 8730628.8730628
30 Grover S, Quinn MA, Weideman P, . Screening for ovarian cancer using serum CA125 and vaginal examination: report on 2550 females. International journal of gynecological cancer : official journal of the International Gynecological Cancer Society. 1995;5(4):291-5. PMID: 11578492.11578492
31 Prorok PC, Andriole GL, Bresalier RS, . Design of the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial. Control Clin Trials. 2000;21(6 Suppl):273S-309S. PMID: 11189684.11189684
32 Gutman R, Peipert J, Weitzen S, . Evaluation of clinical methods for diagnosing bacterial vaginosis. Obstet Gynecol. 2005;105(3):551-6. PMID: 15738023.15738023
33 Eschenbach DA, Hillier S, Critchlow C, . Diagnosis and clinical manifestations of bacterial vaginosis. American journal of obstetrics and gynecology. 1988;158(4):819-28. PMID: 3259075.3259075
34 Koutsky LA, Stevens CE, Holmes KK, . Underdiagnosis of genital herpes by current clinical and viral-isolation procedures. N Engl J Med. 1992;326(23):1533-9. PMID: 1315930.1315930
35 Wolner-Hanssen P, Krieger J, Stevens C, . Clinical manifestations of vaginal trichomoniasis. JAMA. 1989;261(4):571-6. PMID: 2783346.2783346
36 Tiemstra JD, Pela E. Urinary symptoms after a routine pelvic exam. J Am Board Fam Med. 2011;24(3):290-5. PMID: 21551401.21551401
37 Ebell MH, Culp M, Lastinger K, . A systematic review of the bimanual examination as a test for ovarian cancer. Am J Prev Med. 2015;48(3):350-6. PMID: 25595604.25595604
38 Bloomfield HE, Olson A, Greer N, . Screening pelvic examinations in asymptomatic, average-risk adult women: an evidence report for a clinical practice guideline from the American College of Physicians. Ann Intern Med. 2014;161(1):46-53. PMID: 24979449.24979449
39 U.S. Cancer Statistics Working Group. United States Cancer Statistics: 1999–2012 Incidence and Mortality Web-based Report. Atlanta, GA: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Cancer Institute;2015. PMID: None.
40 Hartge P, Hayes R, Reding D, . Complex ovarian cysts in postmenopausal women are not associated with ovarian cancer risk factors: preliminary data from the prostate, lung, colon, and ovarian cancer screening trial. American journal of obstetrics and gynecology. 2000;183(5):1232-7. PMID: 11084571.11084571
41 Buys SS, Partridge E, Black A, . Effect of screening on ovarian cancer mortality: the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Randomized Controlled Trial. JAMA. 2011;305(22):2295-303. PMID: 21642681.21642681
42 Padilla LA, Radosevich DM, Milad MP. Limitations of the pelvic examination for evaluation of the female pelvic organs. International journal of gynaecology and obstetrics: the official organ of the International Federation of Gynaecology and Obstetrics. 2005;88(1):84-8. PMID: 15617719.15617719
43 Padilla LA, Radosevich DM, Milad MP. Accuracy of the pelvic examination in detecting adnexal masses. Obstet Gynecol. 2000;96(4):593-8. PMID: 11004365.11004365
44 Tayal VS, Crean CA, Norton HJ, . Prospective comparative trial of endovaginal sonographic bimanual examination versus traditional digital bimanual examination in nonpregnant women with lower abdominal pain with regard to body mass index classification. J Ultrasound Med. 2008;27(8):1171-7. PMID: 18645075.18645075
45 Ueland FR, Depriest PD, Desimone CP, . The accuracy of examination under anesthesia and transvaginal sonography in evaluating ovarian size. Gynecol Oncol. 2005;99(2):400-3. PMID: 16084576.16084576
46 Armstrong L, Zabel E, Beydoun H. Evaluation of the usefulness of the ‘hormones with optional pelvic exam’ programme offered at a family planning clinic. Eur J Contracept Reprod Health Care. 2012;17(4):307-13. PMID: 22524280.22524280
47 Bourne P, Charles C, Francis C, . Perception, attitude and practices of women towards pelvic examination and Pap smear in Jamaica. N Am J Med Sci. 2010;2(10):478-86. PMID: 22558551.22558551
48 Broadmore J, Carr-Gregg M, Hutton JD. Vaginal examinations: women's experiences and preferences. N Z Med J. 1986;99(794):8-10. PMID: 3456108.3456108
49 Fiddes P, Scott A, Fletcher J, . Attitudes towards pelvic examination and chaperones: a questionnaire survey of patients and providers. Contraception. 2003;67(4):313-7. PMID: 12684154.12684154
50 Golomb D. Attitudes toward pelvic examinations in two primary care settings. R I Med J. 1983;66(7):281-4. PMID: 6577533.6577533
51 Haar E, Halitsky V, Stricker G. Patients' attitudes toward gynecologic examination and to gynecologists. Med Care. 1977;15(9):787-95. PMID: 895235.895235
52 Harper C, Balistreri E, Boggess J, . Provision of hormonal contraceptives without a mandatory pelvic examination: the first stop demonstration project. Fam Plann Perspect. 2001;33(1):13-8. PMID: 11271540.11271540
53 Hesselius I, Lisper H, Nordstrom A, . Comparison between participants and non-participants at a gynaecological mass screening. Scand J Soc Med. 1975;3(3):129-38. PMID: 1215854.1215854
54 Hoyo C, Yamall K, Skinner C, . Pain predicts non-adherence to pap smear screening among middle-aged African American women. Preventive medicine. 2005;41(2):439-45. PMID: 15917039.15917039
55 Osofsky H. Women's reactions to pelvic examination. Obstet Gynecol. 1967;30(1):146-51. PMID: 6027483.6027483
56 Petravage JB, Reynolds LJ, Gardner HJ, . Attitudes of women toward the gynecologic examination. J Fam Pract. 1979;9(6):1039-45. PMID: 521765.521765
57 Taylor V, Yasul Y, Burke N, . Pap testing adherence among Vietnamese American women. Cancer Epidemiol Biomarkers and Prev. 2004;13(4):613-9. PMID: 15066927.15066927
58 Wijma B, Gullberg M, Kjessler B. Attitudes towards pelvic examination in a random sample of Swedish women. Acta Obstet Gynecol Scand. 1998;77(4):422-8. PMID: 9598951.9598951
59 Yu C, Rymer J. Women's attitudes to and awareness of smear testing and cervical cancer. Br J Fam Plann. 1998;23(4):127-33. PMID: 9882766.9882766
60 Kahn J, Goodman E, Huang B, . Predictors of Papanicolaou smear return in a hospital-based adolescent and young adult clinic. Obstet Gynecol. 2003;101(3):490-9. PMID: 1263695212636952
61 Leeners B, Stiller R, Block E, . Effect of childhood sexual abuse on gynecologic care as an adult. Psychosomatics. 2007;48(5):385-93. PMID: 17878496.17878496
62 Swahnberg K, Wijma B, Siwe K. Strong discomfort during vaginal examination: why consider a history of abuse? European journal of obstetrics, gynecology, and reproductive biology. 2011;157(2):200-5. PMID: 21470763.21470763
63 Weitlauf JC, Finney JW, Ruzek JI, . Distress and pain during pelvic examinations: effect of sexual violence. Obstet Gynecol. 2008;112(6):1343-50. PMID: 19037045.19037045
64 Weitlauf JC, Frayne SM, Finney JW, . Sexual violence, posttraumatic stress disorder, and the pelvic examination: how do beliefs about the safety, necessity, and utility of the examination influence patient experiences? J Womens Health (Larchmt). 2010;19(7):1271-80. PMID: 20509787.20509787
65 Robohm JS, Buttenheim M. The gynecological care experience of adult survivors of childhood sexual abuse: a preliminary investigation. Women Health. 1996;24(3):59-75. PMID: 9046553.9046553
66 Boyer SC, Pukall CF. Pelvic examination experiences in women with and without chronic pain during intercourse. J Sex Med. 2014;11(12):3035-50. PMID: 25243968.25243968
67 Amy NK, Aalborg A, Lyons P, . Barriers to routine gynecological cancer screening for White and African-American obese women. Int J Obes (Lond). 2006;30(1):147-55. PMID: 16231037.16231037
68 Saraiya M. Evidence is lacking to support pelvic examinations as a screening tool for non-cervical cancers or other conditions. Evid Based Med. 2015;20(1):31. PMID: 25260357.25260357
69 Bump RC. “Pelvic: deferred”-have nongynecologists been right all along? American journal of obstetrics and gynecology. 2013;208(2):91. PMID: 23351727.23351727
70 Bates C, Potter J. Screening pelvic examination in adult women. Ann Intern Med. 2014;161(12):925-6. PMID: 25506865.25506865
71 Metz S, Gussman D. Screening pelvic examination in adult women. Ann Intern Med. 2014;161(12):925. PMID: 25506864.25506864
72 Jennings JC, Blake J. Screening pelvic examinations in asymptomatic, average-risk adult women. Ann Intern Med. 2014;161(12):924. PMID: 25506862.25506862
73 Oboler SK, Prochazka AV, Gonzales R, . Public expectations and attitudes for annual physical examinations and testing. Ann Intern Med. 2002;136(9):652-9. PMID: 11992300.11992300
74 Prochazka AV, Lundahl K, Pearson W, . Support of evidence-based guidelines for the annual physical examination: a survey of primary care providers. Arch Intern Med. 2005;165(12):1347-52. PMID: 15983282.15983282
75 Burns RB, Potter JE, Ricciotti HA, . Screening Pelvic Examinations in Adult Women: Grand Rounds Discussion From the Beth Israel Deaconess Medical CenterScreening Pelvic Examinations in Adult Women. Ann Intern Med. 2015;163(7):537-47. PMID: 26436618.26436618
76 Committee on Health Care for Underserved Women. Committee opinion no. 615: Access to contraception. Obstet Gynecol. 2015;125(1):250-5. PMID: 25560140.25560140
77 Gavin L, Moskosky S, Carter M, . Providing quality family planning services: Recommendations of CDC and the U.S. Office of Population Affairs. MMWR Recomm Rep. 2014;63(Rr-04):1-54. PMID: 24759690.24759690
78 Yu JM, Henderson JT, Harper CC, . Obstetrician-gynecologists' beliefs on the importance of pelvic examinations in assessing hormonal contraception eligibility. Contraception. 2014;90(6):612-4. PMID: 25108582.25108582
79 Henderson JT, Sawaya GF, Blum M, . Pelvic examinations and access to oral hormonal contraception. Obstet Gynecol. 2010;116(6):1257-64. PMID: 21099589.21099589
80 Clancy CM, Massion CT. American women's health care. A patchwork quilt with gaps. JAMA. 1992;268(14):1918-20. PMID: 1404719.1404719
81 Institute of Medicine. Clinical Preventive Services for Women: Closing the Gaps. Washington, D.C.: The National Academies Press; 2011. PMID: None
82 Henderson JT, Weisman CS, Grason H. Are two doctors better than one? Women's physician use and appropriate care. Womens Health Issues. 2002;12(3):138-49. PMID: 12015186.12015186
83 Henderson JT, Weisman CS. Women's patterns of provider use across the lifespan and satisfaction with primary care coordination and comprehensiveness. Med Care. 2005;43(8):826-33. PMID: 16034297.16034297
84 Stormo AR, Saraiya M, Hing E, . Women's clinical preventive services in the United States: who is doing what? JAMA Intern Med. 2014;174(9):1512-4. PMID: 25003954.25003954
85 Oei AL, Massuger LF, Bulten J, . Surveillance of women at high risk for hereditary ovarian cancer is inefficient. Br J Cancer. 2006;94(6):814-9. PMID: 16495917.16495917
86 Olivier RI, Lubsen-Brandsma MA, Verhoef S, . CA125 and transvaginal ultrasound monitoring in high-risk women cannot prevent the diagnosis of advanced ovarian cancer. Gynecol Oncol. 2006;100(1):20-6. PMID: 16188302.16188302
87 van der Velde NM, Mourits MJ, Arts HJ, . Time to stop ovarian cancer screening in BRCA1/2 mutation carriers? Int J Cancer. 2009;124(4):919-23. PMID: 19035463.19035463
88 Balbi GC, Musone R, Menditto A, . Women with a pelvic mass: indicators of malignancy. Eur J Gynaecol Oncol. 2001;22(6):459-62. PMID: 11874083.11874083
89 van Nagell JR, Jr., Gallion HH, Pavlik EJ, . Ovarian cancer screening. Cancer. 1995;76(10 Suppl):2086-91. PMID: 8635005.8635005
90 Kurjak A, Prka M, Arenas JM, . Three-dimensional ultrasonography and power Doppler in ovarian cancer screening of asymptomatic peri- and postmenopausal women. Croat Med J. 2005;46(5):757-64. PMID: 16158468.16158468
91 LeFevre ML. Screening for Chlamydia and Gonorrhea: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2014.
92 National Cancer Institute. PDQ Endometrial Cancer Screening. http://cancer.gov/cancertopics/pdq/screening/endometrial/HealthProfessional. Accessed 08/21/2014.
93 American Cancer Society. Signs and symptoms of endometrial cancer. http://www.cancer.org/cancer/endometrialcancer/detailedguide/endometrial-uterine-cancer-signs-and-symptoms. Accessed 10/26/2015.
94 National Cancer Institute. SEER Stat Fact Sheets: Ovary Cancer. http://seer.cancer.gov/statfacts/html/ovary.html. Accessed 08/21/2014.
95 National Cancer Institute. PDQ Ovarian Cancer Screening. http://cancer.gov/cancertopics/pdq/screening/ovarian/HealthProfessional. Accessed 08/21/2014.
96 National Cancer Institute. PDQ Vaginal Cancer Treatment. http://www.cancer.gov/types/vaginal/patient/vaginal-treatment-pdq.Accessed 10/26/2015.
97 Centers for Disease Control and Prevention. Vaginal and Vulvar Cancers. http://www.cdc.gov/cancer/vagvulv. Accessed 08/21/2014.
98 National Cancer Institute. SEER Stat Fact Sheets: Vulvar Cancer. http://seer.cancer.gov/statfacts/html/vulva.html. Accessed 08/21/2014.
99 Centers for Disease Control and Prevention. Bacterial Vaginosis - CDC Fact Sheet. http://www.cdc.gov/std/bv/STDFact-Bacterial-Vaginosis.htm. Accessed 09/03/2014.
100 Koumans EH, Sternberg M, Bruce C, . The prevalence of bacterial vaginosis in the United States, 2001-2004; associations with symptoms, sexual behaviors, and reproductive health. Sex Transm Dis. 2007;34(11):864-9. PMID: 17621244.17621244
101 Centers for Disease Control and Prevention. Candidiasis Risk and Prevention. http://www.cdc.gov/fungal/diseases/candidiasis/genital/risk-prevention.html. Accessed 09/03/2014.
102 Sobel JD. UpToDate: Candida vulvovaginitis. http://www.uptodate.com/contents/candida-vulvovaginitis. Accessed 11/11/2015.
103 Patel H, Wagner M, Singhal P, . Systematic review of the incidence and prevalence of genital warts. BMC Infect Dis. 2013;13:39. PMID: 23347441.23347441
104 Centers for Disease Control and Prevention. Genital Herpes - CDC Fact Sheet (Detailed Version). http://www.cdc.gov/std/herpes/stdfact-herpes-detailed.htm. Accessed 08/21/2014.
105 Bradley H, Markowitz LE, Gibson T, . Seroprevalence of herpes simplex virus types 1 and 2--United States, 1999-2010. The Journal of infectious diseases. 2014;209(3):325-33. PMID: 24136792.24136792
106 Centers for Disease Control and Prevention. Pelvic Inflammatory Disease (PID) - CDC Fact Sheet. http://www.cdc.gov/std/pid/STDFact-PID.htm. Accessed 08/21/2014.
107 Centers for Disease Control and Prevention. STDs in Women and Infants. 2014.
108 Leichliter JS, Chandra A, Aral SO. Correlates of self-reported pelvic inflammatory disease treatment in sexually experienced reproductive-aged women in the United States, 1995 and 2006-2010. Sex Transm Dis. 2013;40(5):413-8. PMID: 23588132.23588132
109 Bohm MK, Newman L, Satterwhite CL, . Pelvic inflammatory disease among privately insured women, United States, 2001-2005. Sex Transm Dis. 2010;37(3):131-6. PMID: 20051931.20051931
110 Centers for Disease Control and Prevention. Trichomoniasis - CDC Fact Sheet. http://www.cdc.gov/std/trichomonas/stdfact-trichomoniasis.htm. Accessed 10/30/2014.
111 Sobel JD. Trichomoniasis. UpToDate 2014.
112 Mac Bride MB, Rhodes DJ, Shuster LT. Vulvovaginal atrophy. Mayo Clinic proceedings. 2010;85(1):87-94. PMID: 20042564.20042564
113 MedlinePlus. Cervical polyps. https://www.nlm.nih.gov/medlineplus/ency/article/001494.htm. Accessed 11/11/2015.
114 Schenken RS. UpToDate: Pathogenesis, clinical features, and diagnosis of endometriosis. http://www.uptodate.com/contents/endometriosis-pathogenesis-clinical-features-and-diagnosis. Accessed 9/17/2014.
115 Ballard KD, Seaman HE, de Vries CS, . Can symptomatology help in the diagnosis of endometriosis? Findings from a national case-control study--Part 1. BJOG : an international journal of obstetrics and gynaecology. 2008;115(11):1382-91. PMID: 18715240.18715240
116 Greenlee RT, Kessel B, Williams CR, . Prevalence, incidence, and natural history of simple ovarian cysts among women >55 years old in a large cancer screening trial. American journal of obstetrics and gynecology. 2010;202(4):373.e1-9. PMID: 20096820.20096820
117 Wu JM, Vaughan CP, Goode PS, . Prevalence and trends of symptomatic pelvic floor disorders in U.S. women. Obstet Gynecol. 2014;123(1):141-8. PMID: 24463674.24463674
118 Wu JM, Hundley AF, Fulton RG, . Forecasting the prevalence of pelvic floor disorders in U.S. Women: 2010 to 2050. Obstet Gynecol. 2009;114(6):1278-83. PMID: 19935030.19935030
119 Zimmermann A, Bernuit D, Gerlinger C, . Prevalence, symptoms and management of uterine fibroids: an international internet-based survey of 21,746 women. BMC women's health. 2012;12:6. PMID: 22448610.22448610
120 Cooper SM A, S.J. UpToDate: Vulvar lichen sclerosus. http://www.uptodate.com/contents/vulvar-lichen-sclerosus. Accessed 01/11/2016.
121 Practice Bulletin No. 149: Endometrial cancer.Obstet Gynecol. 2015;125(4):1006-26. PMID: 25798986.25798986
122 Smith RA, von Eschenbach AC, Wender R, . American Cancer Society guidelines for the early detection of cancer: update of early detection guidelines for prostate, colorectal, and endometrial cancers. Also: update 2001--testing for early lung cancer detection. CA Cancer J Clin. 2001;51(1):38-75; quiz 7-80.PMID: 11577479.11577479
123 Moyer VA Screening for ovarian cancer: U.S. Preventive Services Task Force reaffirmation recommendation statement. Ann Intern Med. 2012;157(12):900-4. PMID: 22964825.22964825
124 American Academy of Family Physicians. Clinical Preventive Service Recommendation: Ovarian Cancer. http://www.aafp.org/patient-care/clinical-recommendations/all/ovarian-cancer.html. Accessed 11/09/2015.
125 American College of Obstetricians and Gynecologists Committee on Gynecologic Practice. Committee Opinion No. 477: the role of the obstetrician-gynecologist in the early detection of epithelial ovarian cancer. Obstet Gynecol. 2011;117(3):742-6. PMID: 2134379121343791
126 American Cancer Society. Ovarian Cancer: Can ovarian cancer be found early? http://www.cancer.org/cancer/ovariancancer/detailedguide/ovarian-cancer-detection. Accessed 11/09/2015.
127 American Cancer Society. Vulvar Cancer: Can vulvar cancer be found early? http://www.cancer.org/cancer/vulvarcancer/detailedguide/vulvar-cancer-detection. Accessed 11/09/2015.
128 U.S. Preventive Services Task Force. Screening for Genital Herpes. http://www.uspreventiveservicestaskforce.org/uspstf05/herpes/herpesrs.pdf. Accessed 09/03/2014.
129 American Academy of Family Physicians. Clinical Preventive Service Recommendation: Genital Herpes Simplex Virus Infection. http://www.aafp.org/patient-care/clinical-recommendations/all/genital-herpes.html. Accessed 11/09/2015.
130 U.S. Preventive Services Task Force. Screening for bacterial vaginosis in pregnancy to prevent preterm delivery: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2008;148(3):214-9. PMID: 18252683.18252683