# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Smyth Lai, MLS, for creating and conducting the literature searches; Kevin Lutz, MFA, for editorial assistance; Nadia Redmond, MSPH, for assistance with data abstraction; Jennifer S. Lin, MD, for review of the final report; Tina Fan, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; and Hanna Bloomfield, MD, MPH, Melinda A. Cavicchia, MD, MPH, David Chelmow, MD, Esther Eisenberg, MD, MPH, Tara Jatlaoui, MD, MPH, Barnett Kramer, MD, MPH, Giang Nguyen, MD, MPH, Mary Roary, PhD, Mona Saraiya, MD, MPH, Sherri Stewart, PhD, and Naomi Tepper, MD, MPH, for their expert feedback on this report. The authors thank Barnett Kramer, MD, MPH, Paul Pinsky, PhD, and Maryam Doroudi, PhD, for providing unpublished data from the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial for participants undergoing ovarian palpation.