# 4 Discussion

We identified no literature that assessed the overall value of the pelvic examination in improving health outcomes for any medical conditions. Despite the many medical conditions that are plausibly detectable or that physicians cite as a rationale for routine screening pelvic examinations, our review identified diagnostic accuracy studies for only one cancerous condition (ovarian cancer) and three infectious conditions (BV, trichomoniasis, and HSV) (Table 10).

Table 10 Summary of Evidence by Key Question and Condition

Condition | # Studies (k) Sample Size (n) Design | Summary of Findings^*^ | Body of Evidence Limitations^†^ | Quality | Applicability
KQ1. Direct screening effectiveness
All | No evidence | Not applicable | Not applicable | Not applicable | Not applicable
KQ2. Screening accuracy
Ovarian cancer | k=4 n=26,432 3 prospective diagnostic accuracy studies and 1 RCT | Sensitivity was reported as 100% in 2 studies where 1 or 2 ovarian cancer cases were palpable on pelvic exam; sensitivity was 0% in 1 study where the single case of ovarian cancer was not detected on pelvic exam. The large PLCO screening trial reported a sensitivity of 4.3% at 1 year. Specificity ranged from 91% to nearly 99%. | Rare ovarian cancer events; accuracy estimates had wide confidence intervals due to the very low event rate. | Fair | Fair Average-risk population, low prevalence of ovarian cancer; ultrasound technology from 2 decades ago
Bacterial vaginosis | k=2 n=930 Prospective diagnostic accuracy | In 1 study, sensitivity and specificity of thin, homogeneous discharge was 79% and 54%, respectively; the second study reported these values as 69% and 97%, respectively. | No screening studies conducted solely in asymptomatic primary care populations; the studies had large proportions of symptomatic patients and substantial clinical heterogeneity (populations, personnel performing index test, description of results of index tests, reference standards) and statistical heterogeneity (disparate accuracy results). | Fair | Poor High-risk population; likely overestimates test performance
Genital herpes | k=1 n=779 Prospective diagnostic accuracy | Pelvic exam finding of vulvar ulcerations had a sensitivity of 20% and specificity of 98% in detecting genital herpes simplex virus at any stage. | No screening studies conducted solely in asymptomatic primary care populations; 78% of women with any genital herpes had asymptomatic shedding or latent disease which could not be detected by pelvic exam. | Fair | Poor High-risk population, likely overestimates test performance
Trichomoniasis | k=1 n=779 Prospective diagnostic accuracy | For colpitis macularis, sensitivity was 2% and specificity 100%; for other individual clinical findings, sensitivity ranged from 8% to 59% and specificity from 72% to 99%. | No screening studies conducted solely in asymptomatic primary care populations; data reporting did not provide sufficient information to calculate the sensitivity and specificity for the presence of one or more abnormal finding on pelvic exam. | Fair | Poor High-risk population, likely overestimates test performance
KQ3. Adverse effects
Pelvic examination | k=1 n=150 Prospective cohort | Urinary tract infection was diagnosed clinically (without culture) for 1 subject in the pelvic exam group; dysuria (11/63 vs. 6/87; p<0.01) and urinary frequency (17/63 vs. 12/87; p<0.01) were more common in the pelvic exam group during the 4-week followup. | High loss to followup rate, underpowered to detect differences in urinary tract infections, and between-group differences in intercourse and barrier use; cannot be used to make conclusions about causality between pelvic exams and urinary tract infections. | Poor to Fair | Poor to fair Reflects community practice, only 1 exploratory study
Ovarian cancer | k=4 n=26,432 3 Prospective diagnostic accuracy studies and 1 RCT | Percentage of patients with positive pelvic exam results who underwent surgery ranged from 5 to 36, depending on the study design and management protocols. Single study reported complication rate of 1% at 5 years downstream from abnormal pelvic exam. | Limited number of studies, different ultrasound techniques and threshold positivity, and rare ovarian cancer events. | Fair | Fair
Bacterial vaginosis | k=2 n=930 Prospective diagnostic accuracy | In 1 study, false-positive and false-negative rates for a pelvic exam finding of thin, homogeneous discharge were 46% and 21%, respectively; in a second study, the rates were 3% and 31%, respectively. | High-risk, symptomatic population | Fair | Poor
Genital herpes | k=1 n=779 Prospective diagnostic accuracy | For the clinical finding of vulvar ulceration, the false-negative and false-positive rates were 80% and 2% for any stage of genital herpes; for clinical finding of tender lymphadenopathy, the rates were 86% and 3%, respectively, for any stage of genital herpes | High-risk, symptomatic population | Fair | Poor
Trichomoniasis | k=1 n=779 Prospective diagnostic accuracy | For clinical findings of colpitis macularis, purulent discharge, frothy discharge, vulvar erythema, and vaginal erythema, the false-negative rate ranged from 41% to 92% and the false-positive rate ranged from 0% to 28%; the degree of harm from false-positive results is expected to be minimal given that the diagnostic test is benign and confirmation is conducted in the clinic without delay between a positive screening finding and confirmation. | High-risk, symptomatic population | Fair | Poor

* Includes consistency and precision.

† Includes reporting bias.

Abbreviations: k=number of studies; KQ=key question; n=number.

## Screening Accuracy

### Ovarian Cancer

Our systematic review findings are consistent with other recent systematic reviews,^37, 38^ but our review is the first to present unpublished data from the PLCO trial from more than 20,000 screened women (P. Pinsky, written communication, May 2, 2016).^21^ All four studies included in our review recruited average-risk women; unsurprisingly, the prevalence of ovarian cancer was quite low (0.04% to 0.10%) and the PPVs were also consistently low (<4%). These rare cases reflect the low incidence of ovarian cancer seen in U.S. women (0.01% [11/100,000 women]).^39^ The downstream consequences resulting from positive pelvic examination findings include surveillance with ultrasonography (one-time or repeated) or other imaging and, in some cases, surgery. In our included studies, at 1 year, the prevalence of abnormal pelvic examination results ranged from 1.2 to 8.7 percent, and the prevalence of surgery among those women with abnormal findings ranged from 5 to 36 percent (P. Pinsky, written communication, May 2, 2016).^21, 28-30^ Due to advances in ultrasound technology since the publication of these studies, it could be hypothesized that the surgical intervention rate lies on the lower end of this range. In the only included U.S. study, the large PLCO trial of almost all postmenopausal women, the ovarian palpation protocol occurred in the early to mid-1990s and reported a surgery rate of 11.2 percent within 1 year of an abnormal pelvic examination after one to four rounds of screening. There is no more recent evidence available to estimate the risk of surgical intervention resulting from screening pelvic examinations.

The PLCO trial used an even more sensitive screening procedure (transvaginal ultrasonography and blood testing for CA-125) and found abnormal ultrasonography results in 5 percent of women (n=1,338) who had received a baseline examination (n=28,519). Between the ultrasonography results and CA-125 levels, 6 percent of women required further assessment (n=1,703) and 2 percent (n=570) underwent surgery (n=325 laparotomy; n=245 laparoscopy and/or vaginal approach). Ninety-eight percent of women with an initial abnormal result on any of the screening tests used in the PLCO trial, and 94 percent of those who underwent surgery following a positive result were not diagnosed with ovarian cancer.^16^ Furthermore, evidence suggests that complex ovarian cysts detected on ultrasound are not immediate precursors to ovarian cancer.^40^ As mentioned earlier, the PLCO trial originally included bimanual examination of the ovaries and rectovaginal examination in the screening protocol.^31^ The pelvic examination component was discontinued, however, because no ovarian cancers were detected solely with bimanual palpation.^16^ Notably, even the more sensitive screening tests (transvaginal ultrasonography and CA-125 blood testing) were not found to significantly reduce rates of ovarian cancer–related mortality.^41^

Cross-sectional studies showed that under the most optimal circumstances (patients preoperatively under anesthesia, all with some pelvic abnormality as indication for surgery, examination performed by attending physicians), the accuracy of the pelvic examination for detecting pelvic masses is low.^42, 43^ Moreover, the accuracy of this examination to detect pelvic masses has been shown to be lower when performed by inexperienced trainee examiners, with obese patients, or with patients with an enlarged uterus.^42-45^ Our narrative synthesis of the limited available evidence suggests poor performance of the screening pelvic examination for detecting ovarian cancer.

### Infectious Diseases

There were no diagnostic accuracy studies for infectious conditions in solely asymptomatic, average-risk populations. We did include four studies reporting diagnostic accuracy in high-risk settings (STI clinics or populations with high rates of symptoms), acknowledging that these studies likely overestimate accuracy characteristics when pelvic examinations are administered to average-risk, asymptomatic primary care populations. Again, even in these high-risk populations, the reported sensitivities are well below what would be considered minimal thresholds for clinically useful screening instruments.

## Harms

Our review identified few studies on harms that met the inclusion criteria. The studies were largely the same ones from key question 2 (accuracy) on estimating indirect harms from false-positive results and missed cases, with an additional small cohort study by Tiemstra and colleagues^36^ on possible associations between pelvic examination and subsequent urinary symptoms. The potential downstream harms resulting from the diagnostic workup vary widely by gynecologic condition. For example, a false-positive result on pelvic examination for adnexal mass could result in ultrasonographic surveillance with or without diagnostic laparoscopy, while a false-positive finding on pelvic examination for abnormal vaginal discharge may result in the additional cost of a laboratory Gram stain or NAAT or even unnecessary empiric antibiotic treatment. From a patient's perspective, and in the absence of empiric treatment, false-positive results associated with screening for trichomoniasis might have a modest impact given that the diagnostic testing and immediate confirmation or disconfirmation does not require an invasive test and there is little delay between the screening and diagnostic test results.

Another recent systematic review^38^ included 14 cross-sectional surveys^46-59^ and one cohort study^60^ addressing harms associated with pelvic examination and women's attitudes about the examination; these studies were not included in our review because they did not meet the inclusion criteria. Exclusions were primarily due to their lack of generalizability and applicability to the U.S. primary care setting. The authors of that systematic review concluded that the pelvic examination may lead to pain, fear, anxiety, discomfort, or embarrassment in some proportion of women (range, 10% to 80%), but those data were of low quality. Additional cross-sectional literature suggests that certain populations of women—especially those with a history of sexual violence^61-64^ or abuse,^65^ chronic pelvic pain,^66^ or obesity^67^—report more negative experiences from a pelvic examination and, as a result, may avoid seeking medical care.

## Clinical Implications

Controversy surrounds the clinical implications of changes in screening periods for cervical cancer with respect to the role of annual screening pelvic examination.^4, 68-72^ There are concerns that scrutiny of the accuracy of screening pelvic examination is misdirected, as the benefit of other routinely provided physical examination components (e.g., heart and lung auscultation) in the context of screening is similarly lacking.^69^ Rather than viewing the examination as a screening test, this perspective suggests that it is a point of contact with patients with broader clinical purpose, including to facilitate discussion of sensitive topics that would otherwise not be brought up.^72^ These concerns may echo physicians' attitudes about the annual physical examination in general; one survey reported that most primary care physicians believe that an annual physical examination provides counseling time for preventive services, improves detection of subclinical disease, improves therapeutic relationships, and is desired by patients.^73, 74^ Others are concerned that clinicians rely on ultrasonography so heavily that clinical acumen for the pelvic examination has declined; this concern has been cited as one reason for continued performance of routine pelvic examinations.^7, 70, 75^ On the other hand, the screening pelvic examination can cause anxiety and discomfort and could pose unnecessary barriers to care,^52^ especially in certain subpopulations of women (e.g., those with a history of sexual abuse^62-64^). Notably, despite recommendations to the contrary,^76, 77^ a survey reported that 79 percent of obstetrician-gynecologists thought at least one component of the pelvic examination was of some importance for determining contraception eligibility,^78^ and a survey from 2008 to 2009 found that nearly a third of obstetrician-gynecologists and family medicine physicians required the patient to undergo a pelvic examination before being prescribed oral contraceptives.^79^

The fragmentation of preventive services in women's health care is a well-recognized problem.^80, 81^ Women's preventive care is provided by clinicians with diverse training and professional orientations, and women seek care from different types of providers over the lifespan, resulting in variability in the comprehensiveness of primary care.^82-84^ It is uncertain if changes to routine screening pelvic examination practices will affect women's patterns of health care use and their receipt of comprehensive primary and preventive health care at different stages of life.

## Limitations

Our systematic review captured all of the English-language published literature on the screening accuracy of the pelvic examination in asymptomatic, average-risk populations. In our initial abstract review, we conservatively included studies that could possibly meet the inclusion criteria for full-text review. In almost all cases, these studies did not meet inclusion criteria on full-text review. We specifically excluded studies recruiting participants at high risk for ovarian cancer (e.g., those with symptoms, known masses, or a family history of ovarian cancer)^85-88^ or those reporting incomplete data regarding accuracy^89, 90^; these studies are summarized elsewhere.^37^ We included STI accuracy studies in settings outside of primary care, but these studies probably included some average-risk patients, thus providing data on accuracy which should be cautiously interpreted for average-risk primary care populations. In addition, our study design inclusion criteria excluded several qualitative studies and survey studies on the harms of pelvic examination (including discomfort and anxiety), but we do not believe that those studies added precision to the estimation of screening harms.^46-59^

The aim of the conceptual framework presented in our report was to define the potential yield as well as the presence of well-established, evidence-based alternative screening tests for conditions like cervical cancer, gonorrhea, and chlamydia.^2, 21, 91^ We acknowledge that no studies examined the yield of the pelvic examination in detecting any treatable pelvic pathology. In other words, while the sensitivity of the pelvic examination was low for detecting a single condition (e.g., ovarian cancer or BV), on the basis of current evidence we could not estimate the value of the screening pelvic examination to detect any condition in the list of possible disease conditions prior to clinical presentation with symptoms. Epidemiologic evidence for estimating the burden of a single condition, biologic plausibility of early detection using the pelvic examination, treatability of the disease at earlier stages, and alternative, superior screening approaches are considerations for clinical guidance, as there is no literature available to estimate the potential cumulative benefits or harms of screening pelvic examination.

This systematic review did not evaluate the role of history taking in eliciting symptoms in patients who do not present with gynecologic-related chief complaints but do affirm one or more gynecological symptoms on review of body systems. This topic was not considered in the scope of this systematic review since it was aimed at determining the effectiveness of routine screening pelvic examinations in average-risk, asymptomatic women in primary care settings. We did perform a targeted search of this approach to case-finding and found no relevant literature. Furthermore, studies examining the accuracy of the pelvic examination as a diagnostic tool for symptomatic patients (e.g., patients presenting with symptoms of pelvic pain, vaginal discharge, or dyspareunia) were outside the scope of this review. Pelvic examination remains an important tool in diagnosing pelvic pathology for symptomatic patients.^20^

## Research Gaps

We found no studies examining the effect of the pelvic examination on morbidity, mortality, or quality of life. Further, we identified no in-progress studies examining the effectiveness or screening accuracy of the pelvic examination for any condition. Given the inconsistent guidelines and limited evidence, trials randomizing women to different pelvic screening examination protocols could provide estimates of the benefits and harms for women at different stages of life. In light of the limited evidence on the clinical benefits or harms of routine pelvic examination for preventive screening, research questions related to improvements to women's primary health care delivery warrant consideration. In the face of changing clinical practice with respect to cervical cancer screening frequency and new recommendations from professional organizations,^9, 20^ it remains unclear if altering the schedule for routine pelvic examinations will influence the uptake of other evidence-based preventive services (e.g., blood pressure or obesity screening). Similarly, there is no literature on the opportunity costs the pelvic examination could pose for the receipt of other recommended preventive services. These changes and others would be important to study given the longstanding patterns of women's primary health care delivery. Also needed are investigations that compare strategies for implementing patient-centered approaches to preventive screening along with provider- and patient-focused strategies to continue improving the delivery of evidence-based prevention.

Further research into the primary care gaps and coordination issues that women face in obtaining comprehensive primary care might help to clarify optimal patterns of health care use from the patient's perspective as well as from public health and clinical standpoints. It remains unclear what components of physical examination in routine primary care visits are most important for maintaining health and whether women's patterns of health care use would change if routine pelvic examinations were not recommended per the American College of Physicians' guidelines^9^ or were based on shared decisionmaking conversations, as suggested in the recent WWTF guidelines.^20^ Changes to routine practices of pelvic examination could either improve or worsen the comprehensiveness and continuity of primary care for women; the effects could also depend on a woman's age or overall health. Patients' expectations and preferences for pelvic examination also warrant further investigation, as the current guidance on screening pelvic examinations from ACOG and WWTF suggest a shared decisionmaking paradigm wherein these personal perspectives would inform practices.^10, 20^ Regardless of the need for targeted preventive screening services, some women may wish to have an annual gynecological visit.^81^

## Conclusions

No studies have provided evidence of the health benefits—and limited evidence on the accuracy—of the screening pelvic examination for gynecologic conditions that might be detected. Although lack of evidence is not conclusive evidence of no benefit, the existing evidence highlights the limited sensitivity of screening pelvic examination in detecting ovarian cancer and select infections. Asymptomatic conditions that might be detected during a routine pelvic examination and treated to improve a patient's health have not been fully outlined and evaluated for test accuracy. Nor has there been sufficient evidence to fully evaluate the potential harms of the examination. Furthermore, no studies have examined the health outcomes for screened and unscreened populations to provide overarching evidence of the overall benefits and harms of the screening pelvic examination across all potential health conditions prevented.