# 3 Results

## Key Question 1 What Is the Direct Evidence for the Effectiveness of the Pelvic Examination in a) Reducing All-Cause Mortality, b) Reducing Cancer- and Disease-Specific Morbidity and Mortality, and c) Improving Quality of Life?

We found no studies that assessed the effectiveness of pelvic examination in reducing all-cause mortality, reducing cancer- and disease-specific morbidity and mortality, or improving quality of life.

## Key Questions 2 and 3 What Are the Test Performance Characteristics of the Pelvic Examination in Screening for Gynecologic Cancers and Other Gynecologic Conditions? What Are the Adverse Effects of Screening Using the Pelvic Examination?

We found four studies examining the accuracy of the pelvic examination to detect ovarian cancer, two studies for BV, and one study each for trichomoniasis and genital herpes. All of these accuracy studies (k=8) were included for harms (false-positive rates and resulting diagnostic workup), and one additional study was included for other harms.

### Ovarian Cancer

#### Summary of Findings

Despite limitations of the evidence, the low prevalence of ovarian cancer in the general population consistently resulted in low positive predictive values (PPVs) for the screening pelvic examination in detecting ovarian cancer. Based on a large study of more than 20,000 women, sensitivity is low (<5%) for the detection of ovarian cancer. Considering all four included screening studies, we could not estimate accuracy with precision due to rarity of the disease, few studies, and short followup time in most studies. In the evidence we reviewed, surgery due to abnormal pelvic examination results ranged from 5 to 36 percent of women, depending on the study design and management protocols.

#### Study Characteristics

We identified one good-quality and three fair-quality studies (n=26,432) that examined the screening accuracy of pelvic examination in identifying ovarian cancer (P. Pinsky, written communication, May 2, 2016).^21, 28-30^ One large, multicenter U.S. randomized, controlled trial, the PLCO trial,^31^ recruited average-risk women ages 55 to 74 years from the community with an overall aim of examining the benefits and harms of ovarian cancer screening using a combination of three modalities: blood testing for CA-125, transvaginal ultrasound, and ovarian palpation/rectovaginal examination (ovarian palpation was dropped 5 years after trial recruitment began because no ovarian cancers were detected solely based on an abnormal ovarian palpation examination). The other three studies, conducted in Greece, Australia, and the United Kingdom, primarily recruited average-risk women ages 40 to 45 years and older from the community, but none excluded women with a family history of ovarian cancer, and one actively recruited younger women with a family history of ovarian cancer (Table 5). One study recruited all or nearly all postmenopausal women based on a lower age limit of 55 years^31^ and one study specifically recruited postmenopausal women older than age 45 years.^28^ The PLCO trial excluded women with prior ovarian, lung, or colon cancer. Two studies excluded women with a history of ovarian cancer, any malignancy, or bilateral oophorectomy.^28, 29^ The fourth study recruited apparently healthy women without exclusions, and any women with a past history of cancer had to be in remission to participate.^30^ None of the studies excluded women with a family history of ovarian cancer. The number of participants who received a pelvic examination ranged from 1,010 to 20,872 across the four studies.

Table 5 Study Characteristics, Ovarian Cancer Screening

Author, Year Quality | Country Recruitment Setting | Study Aim | Inclusion/Exclusion Criteria | N Screened | Age | Screening Test Description | Reference Standard Description | Yield of Ovarian Cancer, n/N (%)
PLCO, 2016^21, 31^ (2016 personal communication with Dr. Paul Pinsky) Good | US Community | To determine the effect of specific cancer screening tests on cause-specific mortality | Inclusion: Women ages 55–74 years Exclusion: Undergoing treatment for cancer (excluding basal cell and squamous cell skin cancer); known prior cancer of the lung, colon, rectum, or ovary; previous surgical removal of 1 lung or the entire colon; had a colonoscopy, sigmoidoscopy, or barium enema in the past 3 years; unable or unwilling to sign the consent form | 20,872 | 62.9 (mean) 55–74 (range) | Palpable ovarian mass or cul-de-sac nodularity (for obese patients with nonpalpable ovaries, the exam was considered negative) | Diagnosis of ovarian cancer within 1 to 5 years of exam based on medical records, patient questionnaires for ovarian cancer diagnoses (All women also received a TVU and CA-125 measurement. While these results were available to the provider, they are not being used as a reference standard.) | 23/20,872 (0.1) for 1-year followup 72/20,872 (0.3) for 1- to 5-year followup^*^
Adonakis, 1996^29^ Fair | Greece Community | Investigate effectiveness of pelvic exam and CA-125 followed by ultrasonography as a screening method | Inclusion: Age ≥45 years without any evidence of adnexal pathology Exclusion: History of ovarian cancer (familial or not) or any other malignancy; bilateral oophorectomy; with ascites | 2000 | 58.1 (mean) 45–80 (range) | Detection of palpable adnexal mass on pelvic exam | Transvaginal ultrasonography for those with abnormal pelvic exam result or serum CA-125 ≥35 U/mL 1-year followup visit to measure CA-125 levels for those with normal pelvic exam results and CA-125 levels | 2/2000 (0.1)
Grover, 1995^30^ Fair | Australia Community | Assess effectiveness of serum CA-125 plus vaginal exam as a screening test | Inclusion: Apparently healthy and age ≥40 years (younger females included if they had a family history of ovarian cancer) Exclusion: NR | 2550 | 51 (median) 21–92 (range) | Adnexal mass was palpable during bimanual exam in postmenopausal females, or if a larger than normal-size ovary was palpable in premenopausal females | Abdominal and/or vaginal ultrasonography for those with abnormal pelvic exam result or serum CA-125 >35 U/mL 1-year postal questionnaire for all patients | 1/2550 (0.04)
Jacobs, 1988^28^ Fair | UK Community | Examine screening capabilities of vaginal exam, CA-125, and ultrasonography in various combinations | Inclusion: Age >45 years; amenorrheic for >12 months Exclusion: History of ovarian cancer or bilateral oophrectomy; being treated for any malignancy | 1010 | 54.0 (median) 45–83 (range) | Palpable pelvic mass of any size that could be clinically distinguished as being separate from the uterus and gastrointestinal tract during vaginal exam | Abdominal ultrasonography for those with abnormal pelvic exam result or serum CA-125 >30 U/mL 1-year postal questionnaire for those with normal pelvic exam results and CA-125 levels | 1/1010 (0.1)

* Includes all participants also diagnosed within the first year (n=23).

Abbreviations: CA-125=cancer antigen 125; N=number; n=number; NR=not reported; PLCO=Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial.

One study defined the test as bimanual ovarian palpation plus rectovaginal examination.^31^ One study clearly defined the index pelvic examination test as the bimanual and speculum examination,^30^ while the other two studies did not define the index test beyond “pelvic exam”^29^ or “vaginal exam.”^28^ Two studies specified that experienced gynecologists or examiners performed the examination,^29, 31^ another stated that a single examiner performed all examinations,^30^ and the third stated that one of two physicians examined all women.^28^ Only one study specified the ultrasonography operator as a gynecologist specializing in ultrasonography.^30^ In the PLCO trial, all participants received the bimanual ovarian palpation and rectovaginal examination in addition to blood testing for CA-125 and transvaginal ultrasound, with screening tests repeated annually. Women who received the ovarian palpation/rectovaginal examination had a mean of 2.4 examinations (with no more than 4 examinations) over the initial 5 years of the trial period when this examination was a part of the screening intervention protocol. In three of the studies, all women had an examination with CA-125 blood testing, and only those with abnormal pelvic examination findings or abnormal CA-125 results had transvaginal or abdominal ultrasonography. ^28-30^ These three studies used different thresholds for acceptable CA-125 levels (>30 U/mL,^28^ >35 U/mL,^30^ and ≥35 U/mL^29^). Likewise, these three studies used differing thresholds to define an abnormal reference ultrasonography result (18 mL/8 mL in pre- and postmenopausal women, respectively^29^; >6 cm^30^; and >8.8 mL^28^). For the PLCO trial, cancer incidence followup at 1 year and up to 5 years was captured in medical records and patient questionnaires.^16, 31^ For the other three studies, followup at 1 year consisted of a postal questionnaire for all patients^30^ or for those with normal pelvic examination findings and CA-125 levels^28^; a fourth study additionally measured CA-125 levels at 1 year for patients with normal baseline pelvic examination and CA-125 results.^29^ Any patients with abnormal CA-125 levels and normal ultrasonography findings were followed with serial CA-125 blood testing and/or ultrasonography every 3 to 6 months. For all four studies, any abnormal results were referred for further management.

Mean or median age ranged from 51 to 63 years. Forty-three and 65 percent of participants were postmenopausal in the two studies reporting menopausal status.^29, 30^ In the other two studies, all or nearly all participants were postmenopausal.^28, 31^

#### Yield and Accuracy

Ovarian cancer prevalence was reported as 0.10 percent in three studies^28, 29^ (P. Pinsky, written communication, May 2, 2016) and 0.04 percent in one study^30^; the longer followup from the PLCO trial (up to 5 years) reported a 0.30 percent prevalence of ovarian cancer (P. Pinsky, written communication, May 2, 2016)^21^(Table 6). Focusing on comparable 1-year data from the four studies, the proportion of participants with positive pelvic examination results ranged from 1.2 to 8.7 percent. Sensitivity was reported as 100 percent in two of the studies^28, 29^ (up to two ovarian cancer cases were palpable on pelvic examination) and 0 percent in the study where the single case of ovarian cancer was not detected on the pelvic examination.^30^ The PLCO trial reported a sensitivity of 4.3 and 2.8 percent from the first screening examination at 1 year and at up to 5 years followup, respectively. In this trial, over the multiple rounds of screening (mean number of screenings, 2.4 [range, 1 to 4]), 91 cases of cancer were detected within 5 years of a screening examination and 88 cases (96.7%) were not detected by the palpation examination (P. Pinsky, written communication, May 2, 2016). Specificity ranged from 91 to 99 percent in the four studies. Calculated PPV ranged from 0 to 3.6 percent, and negative predictive value (NPV) was 99 percent or greater for all studies. Accuracy estimates had wide confidence intervals due to the very low event rate.

Table 6 Summary of Diagnostic Accuracy of Pelvic Examination for Ovarian Cancer

Author, Year Quality Country | N Age | Followup^*^ | Yield, n (%) | TP | FN | FP | TN | Sensitivity (95% CI)^†^ | Specificity (95% CI)^†^ | PPV (95% CI)^†^ | NPV (95% CI)^†^ | FPR (95% CI)^†^ | FNR (95% CI)^†^
PLCO, 2016^21, 31^ (2016 personal communication with Dr. Paul Pinsky) Good US | 20,872 63 years (mean) | 1 year | 23/20,872 (0.1) | 1 | 22 | 242 | 20,607 | 4.3 (0.5 to 18.6) | 98.8 (98.7 to 99.0) | 0.4 (0.04 to 1.9) | 99.9 (99.8 to 99.9) | 1.2 (1.0 to 1.3) | 95.7 (81.4 to 99.5)
PLCO, 2016^21, 31^ (2016 personal communication with Dr. Paul Pinsky) Good US | 20,872 63 years (mean) | 5 years | 72/20,872 (0.3) | 2 | 70 | 241 | 20,559 | 2.8 (0.6 to 8.6) | 98.8 (98.7 to 99.0) | 0.8 (0.2 to 2.6) | 99.7 (99.6 to 99.7) | 1.2 (1.0 to 1.3) | 97.2 (91.4 to 99.4)
Adonakis, 1996^29^ Fair Greece | 2000 58 years (mean) | 1 year | 2 (0.1) | 2 | 0 | 172 | 1826 | 100.0^‡^ (33.3 to 100.0) | 91.4^‡^ (90.1 to 92.6) | 1.2^‡^ (0.2 to 3.6) | 100.0^‡^ (99.9 to 100.0) | 8.6^‡^ (7.4 to 9.9) | 0^‡^ (0 to 66.7)
Grover, 1995^30^ Fair Australia | 2550 51 years (median) | 1 year | 1 (0.04) | 0 | 1 | 40 | 2509 | 0 (0 to 85.3) | 98.4 (97.9 to 98.9) | 0 (0 to 6.0) | 100.0 (99.8 to 100.0) | 1.6 (1.1 to 2.1) | 100.0 (14.7 to 100.0)
Jacobs, 1988^28^ Fair UK | 1010 54 years (median) | 1 year | 1 (0.1) | 1 | 0 | 27 | 982 | 100.0 (14.7 to 100.0) | 97.3 (96.2 to 98.2) | 3.6 (0.4 to 15.5) | 100.0 (99.7 to 100.0) | 2.7 (1.8 to 3.8) | 0 (0 to 85.3)

* Length of followup for ovarian cancer diagnosis.

† Calculated, not study reported.

‡ Adonakis et al^29^ treated ambiguous pelvic examinations as negative screens, whereas we treated the ambiguous examinations as positive screens. The author-reported sensitivity was 97.2%, specificity 66.7%, and PPV 3.4%.

Abbreviations: CA-125=cancer antigen 125; CI=confidence interval; FN=false negative; FP=false positive; N=number; n=number; NPV=negative predictive value; PLCO=Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; PPV=positive predictive value; TN=true negative; TP=true positive.

#### Harms

Because more than 98 percent of the women with abnormal pelvic examination findings were false positives, additional imaging and unnecessary surgical intervention are potential harms of pelvic examination screening for ovarian cancer. The prevalence of laparoscopy or laparotomy for patients with abnormal findings on pelvic examination ranged from 5 to 36 percent. In the Greek study, 17 percent of the women with abnormal pelvic examination results underwent surgery due to the examination results. Pathology findings revealed two cases of ovarian cancer (one was metastatic and the other was a stage Ia serous cystadenocarcinoma), four serous cystadenomas, three mucinous cystadenomas, five endometroid cysts of the ovary, 12 benign cysts, and three normal pathology results.^29^ In the Australian study, two women (5%) with abnormal findings on pelvic examination had surgery. The surgeries revealed that one patient had a fibroid uterus and one patient had a normal (negative) result; the single case of ovarian cancer was not detected on pelvic examination.^30^ In the U.K. study that recruited solely postmenopausal women, 36 percent of women with an abnormal pelvic examination result underwent surgery due to the examination results: one woman had ovarian cancer and nine women had benign conditions (six had benign ovarian cysts, one had a fimbrial cyst, and two had no identified pelvic pathology).^28^ In the PLCO trial, the surgery rate occurring within 1 year of an abnormal ovarian palpation examination was 11.2 percent (at the longest followup), with a complication rate (any complication: surgical, pulmonary, cardiovascular, infection, other) of 1.0 percent (Table 7). Further diagnostic procedures occurring subsequent to and within 1 year after an abnormal palpation examination in the trial are reported in Table 7 (P. Pinsky, written communication, May 2, 2016).^21^

Table 7 Diagnostic Procedures Within 1 Year of a Positive Palpation Examination in Women Without an Ovarian Cancer Diagnosis: PLCO Trial Only

Diagnostic procedure | Number (%) of women with a positive palpation exam in the first screening round (n=242) receiving diagnostic procedure within 1 year of a positive palpation exam^†^ | Number (%) of women with any positive palpation exam occurring any time during 4 rounds of annual screening^*^ (n=475) receiving diagnostic procedure within 1 year of a positive palpation exam^‡^
Additional CA-125^§^ | 10 (4.1) | 26 (5.5)
Additional TVU^§^ | 47 (19.4) | 87 (18.3)
Abdominal CT | 7 (2.9) | 11 (2.3)
Surgery | 31 (12.8) | 53 (11.2)
Any complication^‖^ | 4 (1.7) | 5 (1.0)
Surgical complication | 1 (0.4) | 1 (0.2)

* Due to rolling recruitment and early termination of the palpation component in the screening intervention arm of the trial, the number of palpation screening visits women completed was variable. On average, women received 2.4 palpation screening visits (28.0% received 1, 24.8% received 2, 24.4% received 3, and 22.8% received 4).

† Data from a 2016 personal communication with Dr. Paul Pinsky, National Cancer Institute.

‡ Data from Doroudi et al.^21^

§ All women received CA-125 and TVU as part of the PLCO trial protocol for ovarian cancer screening and these results were available to each woman's provider. These two diagnostic procedures in the table indicate additional CA-125 and TVU were conducted with a woman's provider within 1 year.

‖ Any complication includes: surgical, infection, cardiovascular, pulmonary or other complication.

Abbreviations: CA-125=cancer antigen 125; n=number; PLCO=Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; TVU=transvaginal ultrasound.

### BV

#### Summary of Findings

No screening studies were conducted solely in asymptomatic primary care populations. Two studies with large proportions of symptomatic patients had substantial clinical and methodological heterogeneity (populations, personnel performing index test, description of results of index tests, reference standards) and statistical heterogeneity (disparate accuracy results). These limitations hindered conclusions regarding the accuracy of the pelvic examination as a screening test for BV. Both included studies should be considered exploratory, hypothesis-generating investigations that cannot be used to estimate the accuracy of the pelvic examination as a screening test for BV in primary care populations.

#### Study Characteristics

We identified two fair-quality U.S. studies (n=930) that assessed the accuracy of different approaches to diagnosing BV, including pelvic examination.^32, 33^ Gutman et al^32^ recruited any woman undergoing a speculum examination from a hospital-based primary care, colposcopy, or research clinic, whereas Eschenbach et al^33^ recruited nonpregnant women ages 16 to 50 years from an STI clinic (Table 8). In the first study, personnel performing “routine pelvic examination” included second- through fourth-year obstetrician-gynecologists residents, research nurses, or an attending gynecologist,^32^ while the second study specified that a single “women's health care specialist” performed a “standardized pelvic examination,” with specific attention to the appearance of the vulva, vagina, and cervix; characteristics of vaginal discharge; and cervical, uterine, and adnexal tenderness.^33^

Table 8 Study Characteristics, Infectious Diseases

Author, Year Quality | Country Recruitment Setting | Study Aim | Inclusion/Exclusion Criteria | N Screened | Mean Age Race | Prevalence of Symptoms | Screening Test | Reference Standard Description | Yield of Disease, n/N (%)
Bacterial Vaginosis
Gutman, 2005^32^ Fair | US Hospital | Determine whether current clinical criteria for diagnosing BV can be simplified by using 2 clinical criteria rather than the standard (3 of 4 Amsel's criteria) | Inclusion: any woman undergoing a speculum exam Exclusion: large amount of vaginal bleeding on exam | 269 | 24.1 38% white | Any symptoms: 32.7% Vaginal discharge: 23.8% Foul-smelling odor: 14.1% Vaginal itching: 6.3% Vaginal burning: 2.6% | Thin, homogeneous vaginal discharge | Nugent's criteria: a score of ≥7 defined a diagnosis of BV^*^ | 104/269 (38.7)
Eschenbach, 1988^33,†^ Fair | US STI clinic | Compare accuracy of Gram stain criteria for BV with composite clinical criteria for diagnosing BV | Inclusion: age 16–50 years, English speaking Exclusion: pregnant, used oral antibiotics or vaginal medication in previous 14 days, hysterectomized, severely mentally or physically incapacitated, Trichomonas vaginalis (by culture), no evaluable Gram stain | 661 | NR NR | Any pelvic or abdominal symptom as a chief complaint: 59% | Standardized pelvic exam, with attention to appearance of vulva, vagina, and cervix (erythema, friability of cervix, color of cervical mucus), characteristics of vaginal discharge (amount, color, other characteristics), and tenderness (cervical, uterine, adnexal) | pH of vaginal contents, clue and epithelial cells present on microscopy, fishy amine-like odor | 311/661 (47.0)
Genital Herpes
Koutsky, 1992^34,†^ Fair | US STI clinic | Assess relative merits of different approaches to detecting genital HSV infection, including the approach of clinical exam and viral isolation | Inclusion: age 16–50 years; English-speaking Exclusion: pregnant, used oral antibiotics or vaginal medication in previous 14 days, hysterectomized, severely mentally or physically incapacitated | 779 | 24 years 70% white | 22% of women with evidence of herpes presented symptomatically | Genital exam, looking for vulva ulcerations and tender inguinal nodes | For HSV isolation: collection of urine, specimens from cervix and anal canal, swabs from external genital lesions; serum Western blot for antibodies | 372/779 (47.8)
Trichomoniasis
Wolner-Hansson, 1989^35,†^ Fair | US STI clinic | Identify relationships of specific genital microbial pathogens to clinical manifestations | Inclusion: ages 16–50 years, English-speaking Exclusion: pregnant, used oral antibiotics or vaginal medication in previous 14 days, hysterectomized, severely mentally or physically incapacitated | 779 | 24 years 70% white | Yellow discharge: 23% Abnormal vaginal odor: 36% Vulvar itching: 51% | Standardized pelvic exam with specific attention to appearance of vulva, vagina, and cervix; abnormal results included colitis macularis (“strawberry cervix”), purulent discharge, frothy discharge, vulvar or vaginal erythema | Cultures from 2 vaginal specimens examined for growth of Trichomonas vaginalis (identified by characteristic morphology and motility in unstained wet mounts) | 118/778 (15.2)

* 0- to 10-point score describing numbers of Lactobacilli, Gardenerella, and curved Gram-negative bacilli in 100× microscopy field of Gram stain sample.

† These three studies include the same sample of women.

Abbreviations: BV=bacterial vaginosis; HSV=herpes simplex virus; N=number; n=number; STI=sexually transmitted infection.

The Gutman study provided some details on patient characteristics and reported a mean age of 24.1 years, with 38 percent of patients being white, 30 percent black, and 27 percent Hispanic.^32^ Thirty-three percent of patients in the Gutman study were symptomatic,^32^ while the STI clinic study reported 59 percent presenting with some pelvic or abdominal symptom as a chief complaint.^33^ Risk factors for BV were not reported for either study.

Neither study had a primary aim of estimating the accuracy of the pelvic examination; instead, they explored different clinical signs and diagnostic criteria for BV measured against a gold standard. The aim of the Gutman study was to report the diagnostic accuracy of using any two of Amsel's criteria compared with the traditional diagnostic criteria of three of the four Amsel's criteria (thin, homogeneous discharge; vaginal pH >4.5; positive whiff test or release of amine odor with potassium hydroxide; and clue cells on saline wet preparation microscopy). The aim of the Eschenbach study was to compare the observed findings on clinical pelvic examination with the gold-standard diagnostic criteria for BV.^33^ In the Gutman study, the index test included Amsel's criteria with a score of 3 or greater; the reference test was a Gram stain with a Nugent's criteria score of 7 or greater.^32^ The Eschenbach study used the index test of a standard pelvic examination reporting the accuracy of individually observed findings from a physical examination (homogeneous, frothy, increased, or yellow vaginal discharge; ectopy; and adnexal tenderness) compared with the reference standard of pH level and Gram stain microscopy. BV was diagnosed if the Gram stain revealed Gardenerella, one or more other bacterial morphologic types, and Lactobacillus (at quantities of ≤4 per oil immersion field).

#### Yield and Accuracy

Both studies reported a high prevalence of BV (39% and 47%).^32, 33^ Gutman et al^32^ reported the sensitivity and specificity of thin, homogeneous discharge as 79 and 54 percent, respectively; PPV and NPV were calculated to be 52 and 80 percent, respectively (Table 9). Eschenbach et al^30^ reported the sensitivity and specificity of homogeneous discharge as 69 and 97 percent, respectively (PPV, 95%; NPV, 79%).^33^ That study also reported sensitivity for other individual pelvic examination findings, which ranged from 2 percent (frothy discharge) to 51 percent (ectopy), and specificity, which ranged from 48 percent (ectopy) to 100 percent (frothy discharge). PPV ranged from 42 to 100 percent and NPV from 52 to 58 percent. Data reporting did not allow for calculations for strictly asymptomatic patients.

Table 9 Summary of Diagnostic Accuracy of Pelvic Examination for Infectious Disease

Author, Year Quality Country | N Mean Age Race/Ethnicity | Yield, n (%) | Screening Test | TP^*^ | FN^*^ | FP^*^ | TN^*^ | Sensitivity (95% CI)^†^ | Specificity (95% CI)^†^ | PPV (95% CI)^†^ | NPV (95% CI)^†^ | FPR (95% CI) | FNR (95% CI)
Bacterial Vaginosis
Gutman, 2005^32^ Fair US | 269 24.1 years 38% white | 104 (38.7) | Thin, homogeneous discharge on pelvic exam | 82 | 22 | 76 | 89 | 78.8 (70.3 to 85.8) | 53.9 (46.3 to 61.4) | 51.9 (44.1 to 59.6) | 80.2 (72.0 to 86.8) | 46.1 (38.6 to 53.7) | 21.2 (14.2 to 29.7)
Eschenbach, 1988^33,‡^ Fair US^†^ | 661 NR NR | 311 (47.0) | Homogeneous discharge | 184 | 82 | 9 | 309 | 69.2 (63.4 to 74.5) | 97.2 (94.9 to 98.6) | 95.3 (91.7 to 97.7) | 79.0 (74.8 to 82.8) | 2.8 (1.4 to 5.1) | 30.8 (25.5 to 36.6)
Eschenbach, 1988^33,‡^ Fair US^†^ | 661 NR NR | 311 (47.0) | Frothy discharge | 6 | 260 | 0 | 318 | 2.3 (0.9 to 45.9) | 100.0 (99.2 to 100.0) | 100 (67.0 to 100.0) | 55.0 (50.9 to 59.0) | 0 (0 to 7.9) | 97.7 (95.4 to 99.0)
Eschenbach, 1988^33,‡^ Fair US^†^ | 661 NR NR | 311 (47.0) | Increased discharge | 25 | 241 | 14 | 304 | 9.4 (6.3 to 13.3) | 95.6 (92.9 to 97.5) | 64.1 (48.5 to 77.7) | 55.8 (51.6 to 59.9) | 4.4 (2.5 to 7.1) | 90.6 (86.7 to 93.7)
Eschenbach, 1988^33,‡^ Fair US^†^ | 661 NR NR | 311 (47.0) | Yellow discharge | 83 | 179 | 53 | 246 | 31.7 (26.3 to 37.5) | 82.3 (77.6 to 86.3) | 61.0 (52.7 to 68.9) | 57.9 (53.1 to 62.5) | 17.7 (13.7 to 22.4) | 68.3 (62.5 to 73.7)
Eschenbach, 1988^33,‡^ Fair US^†^ | 661 NR NR | 311 (47.0) | Ectopy (any) | 155 | 151 | 176 | 165 | 50.7 (45.1 to 56.2) | 48.4 (43.1 to 53.7) | 46.8 (41.5 to 52.2) | 52.2 (46.7 to 57.7) | 51.6 (46.3 to 56.9) | 49.3 (43.8 to 54.9)
Eschenbach, 1988^33,‡^ Fair US^†^ | 661 NR NR | 311 (47.0) | Ectopy (50%) | 20 | 286 | 28 | 313 | 6.5 (4.2 to 9.7) | 91.8 (88.5 to 94.4) | 41.7 (28.5 to 55.8) | 52.3 (48.3 to 56.2) | 8.2 (5.6 to 11.5) | 93.5 (90.3 to 95.8)
Eschenbach, 1988^33,‡^ Fair US^†^ | 661 NR NR | 311 (47.0) | Adnexal tenderness | 11 | 282 | 1 | 331 | 3.8 (2.0 to 6.4) | 99.7 (98.6 to 100.0) | 91.7 (67.2 to 99.1) | 54.0 (50.0 to 57.9) | 0.3 (0.03 to 1.4) | 96.2 (93.6 to 98.0)
Eschenbach, 1988^33,‡^ Fair US^†^ | 661 NR NR | 311 (47.0) | Uterine tenderness | 11 | 297 | 5 | 343 | 3.6 (1.9 to 6.1) | 98.6 (96.9 to 99.4) | 68.8 (44.4 to 86.9) | 53.6 (49.7 to 57.4) | 1.4 (0.6 to 3.1) | 96.4 (93.9 to 98.1)
Eschenbach, 1988^33,‡^ Fair US^†^ | 661 NR NR | 311 (47.0) | Cervical motion tenderness | 8 | 301 | 2 | 346 | 2.6 (1.2 to 4.8) | 99.4 (98.2 to 99.9) | 80.0 (49.7 to 95.6) | 53.5 (49.6 to 57.3) | 0.6 (0.1 to 1.8) | 97.4 (95.2 to 98.8)
Genital Herpes
Koutsky, 1992^34,‡^ Fair US^§^ | 779 24 years 70% white | 372 (47.8) | Vulvar ulcerations | 73 | 299 | 10 | 397 | 19.6 (15.8 to 23.9) | 97.5 (95.7 to 98.7) | 88.0 (79.7 to 93.6) | 57.0 (53.3 to 60.7) | 2.5 (1.3 to 4.3) | 80.4 (76.1 to 84.2)
Koutsky, 1992^34,‡^ Fair US^§^ | 779 24 years 70% white | 372 (47.8) | Tender inguinal nodes | 53 | 319 | 12 | 395 | 14.2 (11.0 to 18.1) | 97.1 (95.1 to 98.4) | 81.5 (70.8 to 89.5) | 55.3 (51.7 to 58.9) | 2.9 (1.6 to 4.9) | 85.8 (81.9 to 89.0)
Trichomoniasis
Wolner-Hansson, 1989^35,‡^ Fair US^§^ | 779 24 years 70% white | 118 (15.2) | Colpitis macularis | 2 | 116 | 0 | 660 | 1.7 (0.4 to 5.3) | 100.0 (99.6 to 100.0) | 100.0 (33.3 to 100.0) | 85.1 (82.4 to 87.4) | 0 (0 to 0.4) | 98.3 (94.7 to 99.6)
Wolner-Hansson, 1989^35,‡^ Fair US^§^ | 779 24 years 70% white | 118 (15.2) | Purulent discharge | 58 | 40 | 134 | 426 | 59.2 (49.3 to 68.5) | 76.1 (72.4 to 79.5) | 30.2 (24.0 to 37.0) | 91.4 (88.6 to 93.7) | 23.9 (20.5 to 27.6) | 40.8 (31.5 to 50.7)
Wolner-Hansson, 1989^35,‡^ Fair US^§^ | 779 24 years 70% white | 118 (15.2) | Frothy discharge | 8 | 92 | 5 | 578 | 8.0 (3.8 to 14.5) | 99.1 (98.1 to 99.7) | 61.5 (35.0 to 83.5) | 86.3 (83.5 to 88.7) | 0.9 (0.3 to 1.9) | 92.0 (85.5 to 96.1)
Wolner-Hansson, 1989^35,‡^ Fair US^§^ | 779 24 years 70% white | 118 (15.2) | Vulvar erythema | 44 | 74 | 185 | 476 | 37.3 (29.0 to 46.2) | 72.0 (68.5 to 75.3) | 19.2 (14.5 to 24.7) | 86.5 (83.5 to 89.2) | 28.0 (24.7 to 31.5) | 62.7 (53.8 to 71.0)
Wolner-Hansson, 1989^35,‡^ Fair US^§^ | 779 24 years 70% white | 118 (15.2) | Vaginal erythema | 23 | 95 | 46 | 615 | 19.5 (13.1 to 27.3) | 93.0 (90.9 to 94.8) | 33.3 (23.1 to 45.0) | 86.6 (84.0 to 89.0) | 7.0 (5.2 to 9.1) | 80.5 (72.7 to 86.9)

* Note that these numbers do not always add up to the number of people screened.

† Calculated; not reported in the study.

‡ These three studies include the same sample of women.

§ STI clinic; population at higher risk and more symptomatic than average.

Abbreviations: BV=bacterial vaginosis; CI=confidence interval; FN=false negative; FP=false positive; HSV=herpes simplex virus; N=number; n=number; NPV=negative predictive value; NR=not reported; PPV=positive predictive value; TN=true negative; TP=true positive.

#### Harms

A possible harm of using pelvic examination to screen for BV is that the test could result in false-positive or false-negative results, leading to unnecessary diagnostic workup for some women, while others would not receive indicated treatment. In the Gutman study,^32^ the false-positive and false-negative rates for the pelvic examination finding of thin, homogeneous discharge were 46 and 21 percent, respectively. In the second study, the false-positive and false-negative rates for homogeneous discharge were 3 and 31 percent, respectively.^33^ Individual false-positive and false-negative rates for other signs ranged from 0 to 52 percent and 49 to 98 percent, respectively.^33^

### Genital Herpes (Herpes Simplex Virus-1 or -2)

#### Summary of Findings

No screening studies were conducted solely in asymptomatic primary care populations. The single available study on the accuracy of pelvic examination to detect genital herpes recruited women from an STI clinic who were at high risk for the condition.^34^ Nonetheless, even in this higher STI prevalence population, 78 percent of women who had contracted any type of genital herpes at any time had asymptomatic shedding or latent disease, which would not be detectable with a pelvic examination. In this single study, the pelvic examination finding of vulvar ulcerations had a sensitivity of 20 percent and specificity of 98 percent in detecting genital herpes simplex virus (HSV) at any stage.

#### Study Characteristics

One fair-quality trial by Koutsky et al (n=779) assessed the accuracy of approaches to detect genital herpes infection and provided data on the accuracy of specific pelvic examination findings in detecting this condition.^34^ The study recruited nonpregnant women ages 16 to 50 years from the same population seen in the STI clinic for the BV study by Eschenbach^33^ and for the trichomoniasis study by Wolner-Hansson et al^35^ (Table 8). All pelvic examinations were performed by one “women's health care specialist.” Mean age was 24 years and 70 percent of participants were white. Almost all patients were sexually active (98%). Seven percent used condoms as the primary method of contraception and 33 percent did not use any contraception. Ten percent were symptomatic.

The index test was a “genital examination” with colposcopy (our report did not include lesions detected by colposcopy). A positive pelvic examination result was defined as clinician-detected lesions, but we could use reported data for only vulvar ulcerations and tender inguinal nodes in the accuracy calculations. All patients received the reference test, which included cultures from urine, cervical swabs, anal swabs, and any lesion swabs (all HSV isolates were confirmed and typed by direct immunofluorescence with use of mouse monoclonal antibodies), as well as serum testing for HSV-1 or HSV-2 antibodies using the western blot. The authors clearly defined cases as first episode (bilateral painful multiple vesicles, pustules, or ulcers on external genitalia, perineum, perianal area, or vaginal walls; cervical necrosis; or unilateral lesions plus constitutional symptoms without history of similar episodes, plus culture positivity and HSV-2 antibody negativity), recurrent episode (unilateral painful lesions on external genitalia, perineum, or perianal area; or bilateral small lesions and similar history or cervical ulcers without associated constitutional symptoms, plus culture or HSV-2 antibody positivity), asymptomatic viral shedding (no signs or symptoms, plus culture or antibody positivity), or latent subclinical infection (no signs or symptoms, plus HSV-2 antibodies present).

#### Yield and Accuracy

Nearly half (48%) of all study participants were diagnosed with genital herpes at some stage of the disease: 6 percent were diagnosed at the first episode, 5 percent had symptomatic recurrence, 2 percent had asymptomatic shedding, and 35 percent had latent HSV-2 infection (Table 9). Among patients at any stage of genital herpes, 22 percent were symptomatic on examination. We calculated the specificity and sensitivity of specific individual clinical findings as reported in the study (i.e., vulvar ulcerations, tender inguinal nodes) but were unable to use data on cervical ulcers because these numbers were aggregated to include cervical ulcers detected grossly with speculum examination as well as those found using a colposcope.

The presence of vulvar ulcerations had a sensitivity of 20 percent and specificity of 98 percent in detecting genital HSV at any stage (PPV, 88%; NPV, 57%). Similarly, the presence of tender inguinal lymphadenopathy had a sensitivity of 14 percent and specificity of 97 percent (PPV, 82%; NPV, 55%). Data reporting did not allow calculations for strictly asymptomatic patients.

#### Harms

For the clinical finding of vulvar ulceration, the false-positive and false-negative rates were 2 and 80 percent, respectively, for any stage of genital herpes. For the clinical finding of tender lymphadenopathy, the false-positive and false-negative rates were 3 and 86 percent, respectively, for any stage of genital herpes.

### Trichomoniasis

#### Summary of Findings

There were no screening studies conducted solely in asymptomatic primary care populations. One study of women with a high prevalence of symptoms (>50%) for Trichomonas vaginalis (trichomoniasis) who were recruited from an STI clinic provided an exploratory analysis of the accuracy of individual clinical examination findings, showing less than 60 percent sensitivity for detecting trichomoniasis.^35^

#### Study Characteristics

The one study, a fair-quality trial by Wolner-Hanssen et al (n=779), aimed to analyze the clinical manifestations of trichomoniasis and determine the accuracy of specific clinical findings on pelvic examination in detecting trichomoniasis.^35^ The study recruited nonpregnant women ages 16 to 50 years from the same population seen in the STI clinic as the BV study by Eschenbach^33^ and the HSV study by Koutsky (Table 8).^34^ All pelvic examinations were performed by a single “women's health care specialist.” Patient characteristics were described previously (Genital Herpes, Study Characteristics) from this random sample of STI clinic patients. At least half of the patients had vaginal symptoms: yellow discharge (23%), abnormal vaginal odor (36%), and vulvar itching (51%).

The index test was a standardized pelvic examination that included colposcopy. For the purposes of this report, we did not consider any findings from colposcopic examination. The definition of an abnormal finding was reported as increased vaginal fluid, and reported if the clinician noted moderate to markedly increased discharge compared with that seen in patients without genital infections. Saline preparation as well as Gram stain of vaginal samples were examined under a microscope at 100× and 400× magnification. All patients were specifically evaluated for colpitis macularis (“strawberry cervix,” defined as diffuse or patchy maculoerythematous lesions of the ectocervical epithelium). The reference test for identifying trichomoniasis was culture.

#### Yield and Accuracy

The prevalence of culture-confirmed trichomoniasis was 15 percent. For the most specific clinical sign, colpitis macularis (detected grossly, without a colposcope), we calculated the sensitivity as 2 percent and the specificity as 100 percent; PPV was calculated as 100 percent and NPV as 85 percent (Table 9). For other individual clinical findings, sensitivity ranged from 8 to 59 percent and specificity from 72 to 99 percent; PPV ranged from 19 to 62 percent and NPV from 86 to 91 percent (Table 9). Data reporting did not provide sufficient information to calculate the sensitivity and specificity for the presence of any one or more abnormal findings on pelvic examination. Data reporting did not allow calculations for strictly asymptomatic patients.

#### Harms

Pelvic examination screening for trichomoniasis could result in missed cases whereby women do not receive indicated treatment. For the clinical findings of colpitis macularis, purulent discharge, frothy discharge, vulvar erythema, and vaginal erythema, the false-positive rate ranged from 0 percent (colpitis macularis) to 28 percent (vulvar erythema). The false-negative rate ranged from 41 percent (purulent discharge) to 98 percent (colpitis macularis). The degree of harm from false-positive results is expected to be minimal given that the diagnostic test is benign and confirmation is conducted in the clinic, without delay, between a positive screening result and confirmation.

### Other Harms

#### Summary of Findings

Beyond the false-positive rates and missed cases (described above) from accuracy studies, we identified one additional small fair-quality cohort study investigating a possible association between the pelvic examination and subsequent development of urinary symptoms. Further research is needed, in larger studies with urine culture-confirmed urinary tract infection (UTI) as the outcome, to confirm or disprove this potential harm.

#### Characteristics of Included Studies

In addition to the studies of harms related to the sensitivity and specificity estimates reported in diagnostic accuracy studies, we identified one study that considered the possibility of genitourinary infection being caused by routine pelvic examinations.^36^ In this poor-to-fair quality 4-week prospective controlled cohort (n=150), sexually active women ages 18 to 40 years were seen in a university-based family medicine residency clinic. Subjects presented for a screening speculum examination, Pap test, and bimanual examination, while age-matched controls presented for other kinds of health maintenance visits. The study excluded women who had current or chronic urinary or vaginal symptoms, were being treated with anti-infectives, had diabetes, or were taking immunosuppressants. Outcomes were obtained through daily self-reported logs of urinary symptoms as well as medical chart review for a UTI diagnosis. Half of the enrolled patients (49%) dropped out before the end of the 4-week trial.

The average age of those completing the study was 26 years. The groups differed in two statistically significant ways: the control patients had intercourse more frequently and they used condoms more often than the group that had undergone pelvic examination.

#### Results

UTI was diagnosed clinically (without culture) in only one subject in the pelvic examination group. Dysuria (11/63 vs. 6/87; p<0.01) and urinary frequency (17/63 vs. 12/87; p<0.01) were more common in the pelvic examination group during the 4-week followup. This study was limited in that there was high loss to followup, it was underpowered to detect a difference in UTI diagnoses between groups, and there were significant between-group differences in intercourse frequency and barrier use. This exploratory study cannot be used to make conclusions about the causality between pelvic examinations and UTIs.