# 2 Methods

## Scope and Purpose

The USPSTF will use this evidence review to issue a new recommendation statement on the use of periodic screening pelvic examinations in unselected, asymptomatic, nonpregnant adult women. This review addresses the benefits and harms of screening with the pelvic examination for gynecologic cancers and conditions as well as the diagnostic accuracy of the pelvic examination in detecting individual gynecologic cancers and conditions.

While the pelvic examination is common for adolescent and pregnant women, these populations were specifically excluded from the scope of this review. The purpose of conducting the pelvic examination in unselected nonpregnant adult women may differ from that in special populations of adolescents (e.g., Tanner staging, congenital abnormality case-finding) or pregnant women (e.g., pregnancy dating, pelvic outlet adequacy, cervical dilation checks). Likewise, screening for congenital gynecological conditions was excluded because this review focuses on routine periodic screening, and many congenital conditions would be detected at the symptomatic stage, during pregnancy, at infertility workup, or incidentally during cervical cancer screening.

Further, the USPSTF previously determined that there is good evidence for primary screening approaches for cervical cancer, gonorrhea, and chlamydia. Since the pelvic examination alone is less accurate than the existing screening approaches for these conditions (i.e., NAATs for gonorrhea and chlamydia, Pap/HPV cotesting for cervical cancer), they were not included in the scope of this review.

## Key Questions and Analytic Framework

The analytic framework is presented in Figure 1.

Figure 1 Analytic Framework

Figure 1 is an analytic framework for the key questions of this report. In general, the figure illustrates how screening with the pelvic examination could lead to the detection of gynecologic cancers and conditions and, with treatment, decrease mortality and morbidity and improve quality of life.

### Key Questions

1. What is the direct evidence for the effectiveness of the pelvic examination in a) reducing all-cause mortality, b) reducing cancer- and disease-specific morbidity and mortality, and c) improving quality of life?
2. What are the test performance characteristics of the pelvic examination (sensitivity, specificity, and positive and negative predictive values) in screening for gynecologic cancers and other gynecologic conditions?
3. What are the adverse effects of screening by pelvic examination?

## Data Sources and Searches

We searched MEDLINE, PubMed (publisher-supplied references only), and the Cochrane Central Register of Controlled Trials to locate relevant studies for all three key questions. We searched for articles from the earliest date indexed (1946 for MEDLINE) through January 13, 2016. We supplemented our database searches with experts' suggestions and by reviewing reference lists from all other recent existing systematic reviews. We also searched selected sources of grey literature, including ClinicalTrials.gov and the World Health Organization International Clinical Trials Registry Platform, for ongoing trials. The National Cancer Institute provided previously unpublished 1 and 5 year followup data from the Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening Trial from the subset of women receiving bimanual ovarian palpation and rectovaginal examination; the 5 year results were subsequently published.^21^

## Study Selection

Two investigators independently reviewed 8,678 titles and abstracts by using an online platform (abstrackr^22^) and 316 articles (Appendix A Figure 1) with specified inclusion criteria (Appendix A Table 1). We resolved discrepancies through consensus and consultation with a third investigator. We excluded articles that did not meet inclusion criteria or those we rated as poor quality. To ensure that studies using the pelvic examination as a secondary screening test (e.g., ovarian cancer screening studies using the tumor marker cancer antigen 125 [CA-125] and ultrasound technology that also included a pelvic examination component) were not missed, we were more inclusive during the review of abstracts and titles. As a result, many studies were excluded at the full-text review. Appendix B lists all excluded trials.

Eligible studies included unselected adult women who were not symptomatic or pregnant. We excluded studies that were conducted solely in symptomatic populations.

For the greatest applicability to U.S. practice, we focused on studies conducted in developed countries, as defined by “very high” development according to the 2014 United Nations Human Development Index.^23^ We included only studies that published their results in English because of resource constraints.

Any study that examined the effects of pelvic examination on all-cause mortality, cancer- or disease-specific morbidity or mortality, or quality of life was eligible for inclusion in our review. Further, studies examining the screening accuracy of the pelvic examination in a single encounter or as a periodic program of screening were also eligible.

## Quality Assessment and Data Abstraction

At least two reviewers critically appraised all articles that met the inclusion criteria using the Newcastle Ottawa Scale for cohort and case-control studies^24^ and Quality Assessment of Diagnostic Accuracy Studies I and II for studies of diagnostic accuracy,^25, 26^ adapted to align with the USPSTF's design-specific quality criteria^27^ (Appendix A Table 2). We rated articles as good, fair, or poor quality. In general, a good-quality study met all criteria, indicating low risk of bias. A fair-quality study did not meet, or it was unclear if it met, at least one criterion and also had no known important limitations that could invalidate its results. A poor-quality study had a single fatal flaw or multiple important limitations. We excluded poor-quality studies from this review. Disagreements about critical appraisal were resolved by consensus and, if needed, consultation with a third independent reviewer.

One reviewer extracted key elements of included studies into standardized evidence tables. A second reviewer checked the data for accuracy. Evidence tables were tailored for each key question and to specific study designs and/or specific screening tests. Tables generally included details on study quality, setting and population (e.g., country, inclusion criteria, age, sex, race/ethnicity, symptomatic), screening test and protocol (e.g., who administered, how it was administered, definition of a positive test), reference standard or comparator (if applicable), length of followup, and outcomes (e.g., mortality, sensitivity and specificity, harms).

## Data Synthesis and Analysis

We synthesized results by key question and type of screening test. We used a standardized summary of evidence table to describe the overall strength of evidence for each key question. This table included the number and design of included studies, summary of results, consistency or precision of results, reporting bias, summary of study quality, limitations of the body of evidence, and applicability of findings.

The results are organized by key question. Since seven of the eight included studies reported outcomes for both key questions 2 (accuracy) and 3 (harms), we present the results for both key questions together for each disease condition. An exception was a single additional study on harms in a section entitled “Other Harms.”

### Key Question 1

There were no studies found for key question 1.

### Key Questions 2 and 3

This combined question focused on the one-time test performance of a single pelvic examination for a single condition. We organized our synthesis by condition and discuss the harms of examination due to false-positive results or further diagnostic workup. We calculated sensitivity and specificity in Stata version 13.1 (StataCorp, College Station, TX) using Jeffrey's confidence intervals. We used 2×2 tables constructed from data reported in the primary studies. If the observed sensitivity or specificity was 100 percent, only the lower 95 percent confidence interval was calculated. In many cases, the data presented in our report differ slightly from the published paper because of these calculations. Since there was a limited number of studies for each condition, no pooled analyses were conducted.

### Key Question 3

Due to the limited number of studies that were included only for key question 3, these results are summarized qualitatively.

## Expert Review and Public Comment

The draft research plan was posted for public comment on the USPSTF Web site from December 4, 2014, through January 7, 2015. After that feedback was reviewed, the rectovaginal examination was included as a component of the pelvic examination. No other substantive changes were made. The full draft report was also reviewed by invited content experts and USPSTF federal partners and posted for public comment on the USPSTF Web site from July 5 to July 25, 2016. Comments received during any period were reviewed, considered, and addressed, as appropriate. No new substantive issues were identified that were not previously considered and no major changes were made to the text in the final report.

## USPSTF Involvement

The authors worked with four USPSTF liaisons throughout the review process to develop and refine the analytic framework. These liaisons also helped to develop the key questions and to resolve scope issues for the final evidence synthesis.

This research was funded by the Agency for Healthcare Research and Quality under a contract to support the work of the USPSTF. Agency staff provided oversight for the project, reviewed the draft report, and assisted with the federal partner review of the draft report.