# 1 Introduction

In recent years, evidence reviews and expert consensus have been the basis for changes to longstanding practices of preventive gynecologic screening. There have been several monumental changes in women's health in the past decade, including a shift away from annual cervical cancer screening and a move toward urine-based screening for sexually transmitted infections (STIs) (specifically, chlamydia and gonorrhea) among young women. Later initiation of cervical cancer screening and longer intervals between Papanicolaou (Pap) tests were recommended by the American College of Obstetricians and Gynecologists (ACOG) in 2009.^1^ Current guidelines from the U.S. Preventive Services Task Force (USPSTF) and ACOG recommend screening for cervical cancer beginning at age 21 years and every 3 years thereafter until age 30 years; after age 30 years, 5-year intervals are recommended for most women not at high risk of this disease.^2, 3^ Prior to these changes, annual visits for cervical cancer screening provided an opportunity for routine examination of the external and internal reproductive organs. As the intervals for cervical cancer screening have been extended, the independent clinical value of the pelvic examination has been increasingly questioned and debated^4-7^ and a variety of recommendations have been issued.^8-10^ Currently, a central question in women's primary health care is whether women attending routine visits without gynecologic symptoms would benefit from a screening pelvic examination.

## Background

The pelvic examination consists of visual and physical assessments of female reproductive organs. The pelvic examination may be performed for the purpose of screening for a specific condition, diagnostic evaluation of gynecological symptoms, or disease surveillance. Typically, the screening pelvic examination for asymptomatic women includes a visual inspection of the external genitalia; a speculum examination of the vagina and cervix; bimanual examination of the adnexa, uterus, and cervix; and may include a rectovaginal examination.^8^ In addition, tests for cervical cancer screening (i.e., Pap test, human papillomavirus [HPV] test) may be collected during a routine pelvic examination. Historically, screening pelvic examinations were part of routine annual gynecological examinations during which Pap test collections occur. Even after most professional societies endorsed less frequent cervical cancer screening, many women continued to present annually for routine gynecologic care.^11^ Routine pelvic examination is a longstanding practice that some patients and providers may view as an opportunity to discuss a broad range of sexual and reproductive health issues.

In contrast to most screening tests, the pelvic examination does not identify a unique disease entity. Multiple gynecologic conditions (malignant and benign) could plausibly be detected by pelvic examination or are cited by providers^12, 13^ as reasons for conducting a pelvic examination, including: cervical, endometrial, ovarian, vaginal, and vulvar cancer; bacterial vaginosis (BV), candidiasis, chlamydia, gonorrhea, genital warts, genital herpes, pelvic inflammatory disease (PID), and trichomoniasis; and atrophic vaginitis, cervical polyps, endometriosis, ovarian cysts, pelvic organ prolapse, uterine fibroids, and vulvar lichen sclerosis (Table 1). Each disease can be considered individually for evidence-based screening recommendations by weighing the potential benefits and risks based on test-, disease-, and population-specific factors.^14, 15^ Specifically, each condition can be evaluated for prevalence and burden, typical clinical presentation, screening test accuracy during the asymptomatic phase, and treatment benefits in early-stage disease. Moreover, the gynecologic conditions potentially detectable with the pelvic examination vary by target population—some conditions occur only in specific age groups (adolescent, young adult, pregnant, premenopausal, or postmenopausal) or primarily among women at increased risk based on behavioral or genetic factors.

Table 1 Epidemiology of Gynecologic Cancers and Conditions^*^

Condition | | Population Affected | Burden/Epidemiology | Typical Clinical Presentation | Expected Pelvic Examination Finding in Asymptomatic Women
Cancers | Endometrial | Primarily postmenopausal (mean age of diagnosis, 60 years)^92^ | Incidence rate: 25.1/100,000^†^ Mortality rate: 4.4/100,000^†,39^ | Abnormal vaginal bleeding^93^ | Enlarged uterus on bimanual exam, gross lesions on internal speculum exam (advanced disease)
Cancers | Ovarian | All ages, most frequently those ages 55–64 years^94^ | Incidence rate: 11.3/100,000^†^ Mortality rate: 7.4/100,000^†,39^ | Persistent, vague symptoms (usually after metastasizing)^95^ | Enlarged adnexa, ascites (bimanual exam)
Cancers | Vaginal | All ages, but usually those age ≥60 years^96^ | Incidence rate: 0.7/100,000^†^ Mortality rate: 0.2/100,000^†,39^ | Vaginal discharge; abnormal bleeding; change in bathroom habits; pelvic or abdominal pain, dysuria, dyspareunia^97^ | Gross vaginal lesions on internal speculum exam
Cancers | Vulvar | All ages, but mostly women ages 75–84 years^98^ | Incidence rate: 2.6/100,000^†^ Mortality rate: 0.5/100,000^†,39^ | Itching, burning, or bleeding on the vulva; changes in vulva skin color or appearance; sores, lumps, or ulcers on vulva; pelvic pain, dysuria, dyspareunia^97^ | Gross vulvar lesions on external exam
Infectious diseases | Bacterial vaginosis | All ages, most commonly women ages 15–44 years^99^ | Most common vaginal infection among females ages 15–44 years^99^ Prevalence: 29.2% (ages 14–49 years)^‡,100^ | Often asymptomatic^99^ Malodorous vaginal discharge | Asymptomatic discharge on internal speculum exam
Infectious diseases | Candidiasis | All ages; but those who have diabetes, are pregnant, have long-term use of broad-spectrum antibiotics, or use corticosteroid medications are at higher risk^101^ | Nearly 75% of adult women have had ≥1 candidiasis occurrence^101^ Between 29% and 49% of premenopausal women had ≥1 lifetime episode^102^ | Symptomatic vaginal discharge, pruritus | Vaginal discharge detected on internal speculum exam
Infectious diseases | Genital warts (HPV) | All ages | 120 incident cases/100,000 women each year^103^ Lifetime history of anogenital warts: 7.2%^103^ | Asymptomatic or symptomatic, depending on location and size of warts | Gross lesions on external or internal speculum exam
Infectious diseases | Herpes (HSV-1, HSV-2) | All ages | 20.9% (HSV-2) among females ages 14–49 years^104^ 52.3% (HSV-1) among women ages 20–29 years, 33.2% among women ages 14–19 years^105^ | Asymptomatic or primary/secondary disease with typical labial ulcerative lesions | Gross ulcerative lesions on external or internal speculum exam
Infectious diseases | Pelvic inflammatory disease | Sexually active, especially with untreated STIs^106^ | Proportion of women (ages 15–44 years) ever treated for PID: 5.0%^§,107, 108^ Diagnosis rate (ages 15–44 years): 236.0/100,000^¶,109^ | Abdominal or pelvic pain, discharge, abnormal vaginal bleeding, fever or chills | Tenderness on bimanual exam
Infectious diseases | Trichomoniasis | All ages, but more commonly older women^110^ | Prevalence (ages 14–49 years): 3.1%^111^ | Often asymptomatic^111^ Purulent, malodorous, thin discharge associated with burning, pruritus, dysuria, frequency, lower abdominal pain, or dyspareunia^111^ | Discharge, colpitis macularis
Other | Atrophic vaginitis | Primarily postmenopausal; women of any age with low estrogen level^112^ | Prevalence from 4% in premenopausal women to 47% in postmenopausal women^112^ | Reported symptoms (dyspareunia, spotting, vaginal discharge, burning, soreness) | Atrophic changes on internal speculum exam
Other | Cervical polyps | All ages; most commonly among parous women age ≥20 years^113^ | NR | Often asymptomatic; abnormal bleeding^113^ | Cervical polyp on internal speculum exam
Other | Endometriosis | All ages; most commonly among women ages 25–35 years | Prevalence in the general population is unknown 1% undergoing major surgery for any gynecologic indication^114^ 1%–7% undergoing tubal sterilization^114^ 12%–32% of reproductive age undergoing laparoscopy to determine the cause of pelvic pain^114^ 9%–50% undergoing laparoscopy for infertility^114^ | Dysmenorrhea, pelvic pain, dyspareunia, infertility, bowel upset, bowel pain, ovarian mass, dysuria, other urinary problems May occur asymptomatically Most present symptomatically (chronic pelvic pain, 71%–87%)^115^ | Pelvic mass could be detected with bimanual exam on ovaries, uterus, peritoneum, and uterosacral ligaments Less commonly, internal speculum exam could detect an endometric lesion on the cervix or vaginal mucosa
Other | Ovarian cysts | All ages | Simple cyst at initial visualization (ages 55–74 years): 15%^**,116^ 1-year incidence of new simple cysts (ages 55–74 years): 8%^**,116^ | Often asymptomatic; pelvic pain | Ovarian mass and/or tenderness on bimanual exam
Other | Pelvic floor dysfunction/Pelvic organ prolapse | Older, obese, hysterectomized, pregnant, labored, or gave birth | ≥1 pelvic floor disorder: 25.0%^117^ Urinary incontinence prevalence: 15.7%^††,118^ Fecal incontinence prevalence: 9.1%^††,118^ Pelvic organ prolapse prevalence: 2.9%^††,118^ | Asymptomatic in early stages; urinary obstruction or incontinence, bowel incontinence | Weak pelvic floor muscles prolapse on internal speculum and/or bimanual exam
Other | Uterine fibroids | Most women diagnosed at ages 30–50 years^119^ | Self-reported prevalence: 6.9% | Dysmenorrhea, menorrhagia, metromenorrhagia | Uterine mass on bimanual exam
Other | Vulvar lichen sclerosis | All ages, but most commonly peri- or postmenopausal women^120^ | True prevalence unknown Ranges from 1/30 (older women) to 1/59 (women in a general gynecologic practice)^120^ | Vulvar pruritus, dyspareunia, dysuria, soreness, irritation are common symptoms; may occur asymptomatically^120^ | Characteristic thin, white, atrophic skin and changes in vulvar architecture

* Cervical cancer, gonorrhea, and chlamydia are not included in this table because there are existing strong recommendations for alternative screening methods from the USPSTF and other guideline groups.

† 2012 rates (per 100,000 women).

‡ 2001–2004.

§ 2006–2010.

¶ Diagnosis rates for women ages 15–44 years enrolled in private insurance plans in 2005.

** 2010 projection.

†† From the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; only women ages 55–74 years were included.

Abbreviations: HPV=human papillomavirus; HSV=herpes simplex virus.

The value of early detection of asymptomatic disease for these gynecologic conditions varies considerably. For example, identifying and treating screen-detected asymptomatic BV or vaginal candidiasis in nonpregnant women may have little clinical benefit compared to diagnosis and treatment during symptomatic stages. Likewise, for asymptomatic atrophic vaginitis, cervical polyps, or uterine fibroids, the clinical significance, and therefore the role for early treatment, is unclear in the absence of symptoms. For some gynecologic conditions, such as cervical cancer, gonorrhea, and chlamydia, there are alternative and well-established evidence-based screening tests with superior accuracy compared to the pelvic examination (i.e., Pap/HPV test for cervical cancer and nucleic acid amplification tests [NAATs] for gonorrhea and chlamydia). In theory, some gynecologic cancers, such as those of the ovaries, vulva, and vagina, might have an improved treatment prognosis if detected in earlier, asymptomatic stages and there is currently no alternative effective screening strategy. In contrast, endometrial cancer is frequently symptomatic in its early stages, and the screening pelvic examination is unlikely to detect early-stage cancer since it is not palpable or visible on examination. Some conditions, like endometriosis, clinically present in the context of dysmenorrhea or infertility diagnostic workup. Likewise, pelvic floor dysfunction or pelvic organ prolapse may be diagnosed and graded for severity only after history taking reveals urinary incontinence or retention. Furthermore, advances in ultrasound technology over the past few decades, which is more sensitive than pelvic examination for detecting pelvic masses,^16^ have transformed the detection and surveillance of pelvic masses.

## Current Clinical Practice in the United States

In 2012, 44.2 million pelvic examinations were performed in outpatient visits in the United States.^17^ Sixty-eight percent of surveyed U.S. obstetrician-gynecologists routinely perform a pelvic examination, and 78 percent of all surveyed physicians (including family/general practitioners and internists) believed that pelvic examination is a useful screening test for gynecologic cancers.^12^ In a nationally representative survey of obstetrician-gynecologists, approximately 50 percent reported that performing a bimanual examination to detect ovarian cancer was very important, and approximately 20 and 25 percent thought it was very important for the detection of uterine and cervical cancer, respectively. For other gynecological conditions, more than 50 percent thought the bimanual examination was very important for detecting benign ovarian conditions, nearly 60 percent thought it was very important to detect benign uterine conditions, and about 30 percent reported it was very important in detecting both subclinical PID and uterine position. Almost all of the surveyed physicians indicated that they would perform a bimanual examination during a routine visit with an asymptomatic patient.^13^

The Centers for Medicare & Medicaid Services cover screening pelvic examinations as a stand-alone billable service, without patient copayment, every 24 months for all asymptomatic women and yearly for high-risk women (i.e., women at high risk for vaginal or cervical cancer or women of childbearing age with a vaginal or cervical abnormality found on pelvic examination in the preceding 3 years).^18^

Unpublished data from 2008 through 2010 indicate that the majority of preventive care visits to obstetrician-gynecologists (76%) included a pelvic examination. In contrast, only a quarter of visits to family medicine physicians (25%) and even fewer to internal medicine physicians (14%) included a pelvic examination (E. Hing, personal communication, January 22, 2015).

## Recommendations of Other Groups

Professional organizations vary in their recommendations regarding routine screening pelvic examinations (Table 2). The American College of Physicians recently released a guideline recommending that practitioners not perform screening pelvic examinations (except for cervical cancer screening by visual inspection of the cervix and cervical swabs) in asymptomatic, average-risk women for the purpose of screening for gynecologic cancers, PID, and other benign gynecologic conditions.^9^ The basis of this recommendation was a systematic review that identified no benefits of pelvic examination but some exposure to unnecessary and avoidable harms. The recommendation does not apply to women who present with symptoms (e.g., abnormal bleeding, pain), in which case the pelvic examination would be an appropriate diagnostic procedure to consider. The guideline is endorsed by the American Academy of Family Physicians.^19^

Table 2 Recommendations on the Periodic Pelvic Examination for Asymptomatic Adult Women

Group or Professional Society | Recommendation
AAFP^19^ | Screening pelvic examination in asymptomatic, nonpregnant, adult women is not recommended. (Based on the ACP recommendation.)
ACOG^10^ | No evidence supports the routine internal examination of the healthy, asymptomatic patient before age 21 years. Recommends that a pelvic examination be performed in all patients age 21 years and older. No evidence supports or refutes the annual pelvic examination or speculum and bimanual examination for the asymptomatic, low-risk patient. The decision whether or not to perform a complete pelvic examination at the time of the periodic health examination for the asymptomatic patient should be a shared decision after a discussion between the patient and her health care provider.
ACP^9^ | Recommends against performing screening pelvic examination in asymptomatic, nonpregnant, adult women (strong recommendation, moderate-quality evidence).
WWTF^20^ | For patients age 21 years and older, recommends speculum and/or bimanual examination for asymptomatic patients with specific indications (e.g., intrauterine device placement, cervical cancer screening). External examinations may be performed annually in healthy patients. The inclusion of speculum, bimanual examination, or both in otherwise well women should evolve from informed decisionmaking between patient and provider. (Qualified) (Based on the ACOG recommendation.)

Abbreviations: AAFP=American Academy of Family Physicians; ACOG=American College of Obstetricians and Gynecologists; ACP=American College of Physicians; WWTF=Well-Woman Task Force.

ACOG recommends an annual pelvic examination for women age 21 years or older but acknowledges there is no evidence in support of or against this recommendation.^8^ Furthermore, it notes that this examination is not necessary to prescribe hormonal contraception in healthy women or to screen for STIs. For females younger than age 21 years, ACOG recommends a pelvic examination if indicated by medical history. For symptomatic patients age 21 years or older, joint decisionmaking with the clinician and patient is advised to determine whether pelvic examination should be performed. In 2015, ACOG convened the Well-Woman Task Force (WWTF) and released recommendations for the well-woman visit.^20^ The WWTF recommended that external examinations may be performed annually in healthy patients age 21 years or older, but the inclusion of speculum and bimanual examination for asymptomatic women without specific indications (e.g., cervical cancer screening) should be a shared, informed decision between the patient and provider. The WWTF categorized its pelvic examination recommendation as “qualified,” meaning that it is based on expert opinion rather than clinical evidence.

Despite the inconsistent recommendations for screening pelvic examinations, the available guidelines from national organizations regarding screening for individual gynecologic conditions are similar (Table 3). Recommendations on the types and timing of tests that are effective for cervical cancer, gonorrhea, or chlamydia screening are consistent, as are recommendations against screening for ovarian cancer using currently available approaches (including the bimanual pelvic examination). Recommendations for other gynecologic conditions are few.

Table 3 U.S. National Guidelines and Statements on Screening for Individual Gynecologic Conditions in Unselected Adult Women Who Are Asymptomatic and Not Pregnant^*^

Condition | | USPSTF | AAFP | ACOG | ACS | CDC | WWTF
Cancers | Endometrial | - | - | No screening test^121^ | No indication that screening is warranted for women with no identified risk factors^122^ | - | -
Cancers | Ovarian | Recommend against screening (D)^123^ | Recommend against screening (D)^124^ | No effective strategy for screening^125^ | Currently no reliable screening tests^126^ | - | Screening for ovarian cancer is not recommended (Strong^†^)
Cancers | Vaginal | - | - | - | - | - | -
Cancers | Vulvar | - | - | - | There is no standard screening for this disease, but pelvic examination can improve chances of detection^127^ | - | -
Infectious disease | Bacterial vaginosis | - | - | - | - | - | -
Infectious disease | Candidiasis | - | - | - | - | - | -
Infectious disease | Genital warts (HPV) | - | - | - | - | - | -
Infectious disease | Herpes (HSV-1, HSV-2) | Recommend against screening (D)^128^ | Recommend against screening (D)^129^ | - | - | - | -
Infectious disease | PID | - | - | - | - | - | -
Infectious disease | Trichomoniasis | - | - | - | - | - | -
Other | Atrophic vaginitis | - | - | - | - | - | -
Other | Cervical polyps | - | - | - | - | - | -
Other | Endometriosis | - | - | - | - | - | -
Other | Ovarian cysts | - | - | - | - | - | -
Other | Pelvic organ prolapse | - | - | - | - | - | -
Other | Uterine fibroids | - | - | - | - | - | -

* Recommendations for cervical cancer, gonorrhea, and chlamydia are not included in this table because there are existing strong recommendations for screening from the USPSTF and other guideline groups.

† Based on evidence-based or evidence-informed guidelines.

Abbreviations: AAFP=American Academy of Family Physicians; ACOG=American College of Obstetricians and Gynecologists; ACS=American Cancer Society; CDC=Centers for Disease Control and Prevention; HPV=human papillomavirus; HSV=herpes simplex virus; USPSTF=U.S. Preventive Services Task Force; WWTF=Well-Woman Task Force.

## Previous Related USPSTF Topics

The USPSTF has not made a prior recommendation regarding the routine use of screening pelvic examinations in unselected asymptomatic women, but it has issued several recommendations for screening for benign and malignant gynecologic conditions, including ovarian cancer, cervical cancer, herpes, chlamydia, gonorrhea, and BV (Table 4).

Table 4 USPSTF Screening Recommendations for Malignant and Benign Gynecologic Conditions

Screening Topic, Year | Recommendation Grade | Recommendation/Statement | Status
Bacterial vaginosis in pregnancy, 2008^130^ | D I | Do not screen pregnant women at low risk of preterm birth. Evidence is insufficient to make a recommendation for women at high risk of preterm birth | --
Cervical cancer, 2012^2^ | A D | Screen women ages 21–65 years using cytology and women ages 30–65 years using cytology and human papillomavirus testing. Do not screen women age <21 years or >65 years who have had adequate prior screening, are not at high risk of cervical cancer, had a hysterectomy with removal of the cervix, or have no history of high-grade precancerous lesion or cervical cancer. | Update in progress
Chlamydia, 2014^91^ | B | Screen sexually active women age <25 years and older women at increased risk of chlamydia | --
Gonorrhea, 2014^91^ | B | Screen sexually active women age <25 years and older women at increased risk of gonorrhea | --
Herpes simplex, genital, 2005^128^ | D | Do not screen asymptomatic pregnant women, adults, and adolescents. | Update in progress
Ovarian cancer, 2012^123^ | D | Do not screen asymptomatic women without known genetic mutations. | Update in progress

A = Strongly Recommended: The USPSTF strongly recommends that clinicians provide [the service] to eligible patients. The USPSTF found good evidence that [the service] improves important health outcomes and concludes that benefits substantially outweigh harms.

B = Recommended: The USPSTF recommends that clinicians provide [the service] to eligible patients. The USPSTF found at least fair evidence that [the service] improves important health outcomes and concludes that benefits outweigh harms.

C = No Recommendation: The USPSTF makes no recommendation for or against routine provision of [the service]. The USPSTF found at least fair evidence that [the service] can improve health outcomes but concludes that the balance of benefits and harms is too close to justify a general recommendation.

D = Not Recommended: The USPSTF recommends against routinely providing [the service] to asymptomatic patients. The USPSTF found at least fair evidence that [the service] is ineffective or that harms outweigh benefits.

I = Insufficient Evidence to Make a Recommendation: The USPSTF concludes that the evidence is insufficient to recommend for or against routinely providing [the service]. Evidence that the [service] is effective is lacking, of poor quality, or conflicting and the balance of benefits and harms.

Abbreviation: USPSTF=U.S. Preventive Services Task Force.