# Appendix B Excluded Studies

Reason for Exclusion
E1. | Irrelevant study
E2. | Not an included study design
E2a. | No use of reference standard (or reference standard applied to a nonrandom subset)
E2b. | Cross-sectional surveys with limited generalizability to current U.S. practice
E3. | Not an included setting
E3a. | Not a country with a very high United Nations Human Development Index
E3b. | Not generalizable to primary care
E4. | Not an included population
E4a. | High-risk or symptomatic patients
E5. | No relevant outcomes, or incomplete outcomes
E5a. | No additional relevant data (primary article included)
E5b. | Measure using an unvalidated scale
E6. | Not an included intervention
E7. | Poor-quality study
E8. | Not an included gynecologic condition (cervical cancer, gonorrhea, chlamydia)

1 United Kingdom collaborative trial of ovarian cancer screening (UKCTOCS): design and characteristics of the study population. Int J Gynecol Cancer. 2004;14(Supp 1):112, Abstract 398. PMID: None. KQ2E6.
2 Ackerson K. A history of interpersonal trauma and the gynecological exam. Qual Health Res. 2012;22(5):679-88. PMID: 22068042. KQ3E6.22068042
3 Adams C, Smith N, Wilbur D, . The relationship of obesity to the frequency of pelvic examinations: do physician and patient attitudes make a difference? Women Health. 1993;20(2):45-57. PMID: 8372479 KQ3E1.8372479
4 Adesanya OO, Colie CF. Evaluating oral contraceptive use at 6 and 12 months. J Reprod Med. 1996;41(6):431-4. PMID: 8799920. KQ2E5.8799920
5 Albrich S, Steetskamp J, Knoechel SL, . Assessment of pelvic floor muscle contractility: digital palpation versus 2D and 3D perineal ultrasound. Arch Gynecol Obstet. 2015. PMID: 26408007. KQ2E4a.26408007
6 Alcazar JL, Royo P, Jurado M, . Triage for surgical management of ovarian tumors in asymptomatic women: assessment of an ultrasound-based scoring system. Ultrasound Obstet Gynecol. 2008;32(2):220-5. PMID: 18618475. KQ2E4a.18618475
7 Almeida CM, Rodriguez MA, Skootsky S, . Cervical cancer screening overuse and underuse: patient and physician factors. Am J Manag Care. 2013;19(6):482-9. PMID: 23844709. KQ3E5.23844709
8 Al-Qutob R, Mawajdeh S, Massad D. Can a home-based pelvic examination be used in assessing reproductive morbidity in population-based studies? A Jordanian experience. J Adv Nurs. 2001;33(5):603-12. PMID: 11298196. KQ2E3a.11298196
9 al-Suleiman SA. Laparoscopy in the management of women with chronic pelvic pain. Aust N Z J Obstet Gynaecol. 1991;31(1):63-5. PMID: 1831347. KQ2E4a.1831347
10 Altman D, Lopez A, Kierkegaard J, . Assessment of posterior vaginal wall prolapse: comparison of physical findings to cystodefecoperitoneography. Int Urogynecol J Pelvic Floor Dysfunct. 2005;16(2):96-103; discussion PMID: 15372142. KQ2E4a.15372142
11 Amy NK, Aalborg A, Lyons P, . Barriers to routine gynecological cancer screening for White and African-American obese women. Int J Obes (Lond). 2006;30(1):147-55. PMID: 16231037. KQ3E2.16231037
12 Andersen MR, Drescher CW, Zheng Y, . Changes in cancer worry associated with participation in ovarian cancer screening. Psychooncology. 2007;16(9):814-20. PMID: 17225260. KQ3E6.17225260
13 Andersen MR, Peacock S, Nelson J, . Worry about ovarian cancer risk and use of ovarian cancer screening by women at risk for ovarian cancer. Gynecol Oncol. 2002;85(1):3-8. PMID: 11925113. KQ3E5.11925113
14 Andolf E, Jorgensen C. A prospective comparison of clinical ultrasound and operative examination of the female pelvis. J Ultrasound Med. 1988;7(11):617-20. PMID: 3062189. KQ2E4a.3062189
15 Andrykowski MA, Pavlik EJ. Response to an abnormal ovarian cancer-screening test result: test of the social cognitive processing and cognitive social health information processing models. Psychol Health. 2011;26(4):383-97. PMID: 20419561. KQ3E6.20419561
16 Anonymous. Determinants of cervical Chlamydia trachomatis infection in Italy. The Italian MEGIC Group. Genitourin Med. 1993;69(2):123-5. PMID: 8509092. KQ1E8.8509092
17 Anonymous. Risk factors for genital prolapse in non-hysterectomized women around menopause. Results from a large cross-sectional study in menopausal clinics in Italy. Progetto Menopausa Italia Study Group. Eur J Obstet Gynecol Reprod Biol. 2000;93(2):135-40. PMID: 11074133. KQ2E5.11074133
18 Aoki S, Hata T, Senoh D, . Parametrial invasion of uterine cervical cancer assessed by transrectal ultrasonography: preliminary report. Gynecol Oncol. 1990;36(1):82-9. PMID: 2403960. KQ2E8.2403960
19 Arab AM, Behbahani RB, Lorestani L, . Correlation of digital palpation and transabdominal ultrasound for assessment of pelvic floor muscle contraction. J Man Manip Ther. 2009;17(3):e75-9. PMID: 20046616. KQ2E6.20046616
20 Argenta PA, Ormsby RR, Downs LS, Jr., . Routine pelvic examination during front-line chemotherapy for ovarian cancer: should it play a role? J Reprod Med. 2008;53(1):3-7. PMID: 18251353. KQ2E4a.18251353
21 Armstrong L, Zabel E, Beydoun H. Evaluation of the usefulness of the ‘hormones with optional pelvic exam’ programme offered at a family planning clinic. Eur J Contracept Reprod Health Care. 2012;17(4):307-13. PMID: 22524280. KQ3E2.22524280
22 Asfaw TS, Greer JA, Ramchandani P, . Utility of preoperative examination and magnetic resonance imaging for diagnosis of anterior vaginal wall masses. Int Urogynecol J. 2012;23(8):1055-61. PMID: 22302079. KQ2E4a.22302079
23 Aubel S, Wozney P, Edwards RP. MRI of female uterine and juxta-uterine masses: clinical application in 25 patients. Magn Reson Imaging. 1991;9(4):485-91. PMID: 1779718. KQ2E4a.1779718
24 Audisio T, Pigini T, de Riutort SV, . Validity of the Papanicolaou Smear in the Diagnosis of Candida spp., Trichomonas vaginalis, and Bacterial Vaginosis. J Low Genit Tract Dis. 2001;5(4):223-5. PMID: 17050980. KQ2E6.17050980
25 Balan P. Ultrasonography, computed tomography and magnetic resonance imaging in the assessment of pelvic pathology. Eur J Radiol. 2006;58(1):147-55. PMID: 16289430. KQ2E4a.16289430
26 Balbi GC, Musone R, Menditto A, . Women with a pelvic mass: indicators of malignancy. Eur J Gynaecol Oncol. 2001;22(6):459-62. PMID: 11874083. KQ2E2.11874083
27 Barber MD, Cundiff GW, Weidner AC, . Accuracy of clinical assessment of paravaginal defects in women with anterior vaginal wall prolapse. Am J Obstet Gynecol. 1999;181(1):87-90. PMID: 10411800. KQ2E4a.10411800
28 Barber MD, Neubauer NL, Klein-Olarte V. Can we screen for pelvic organ prolapse without a physical examination in epidemiologic studies? Am J Obstet Gynecol. 2006;195(4):942-8. PMID: 16681989. KQ2E4a.16681989
29 Barrett J, Jenkins V, Farewell V, . Psychological morbidity associated with ovarian cancer screening: results from more than 23,000 women in the randomised trial of ovarian cancer screening (UKCTOCS). BJOG. 2014;121(9):1071-9. PMID: 24865441. KQ3E6.24865441
30 Barrett J, Jenkins V, Farewell V, . Psychological morbidity associated with ovarian cancer screening: results from more than 23,000 women in the randomised trial of ovarian cancer screening (UKCTOCS). BJOG. 2014;121(9):1071-9. PMID: 24865441. KQ3E6.24865441
31 Baruah FK, Sharma A, Das C, . Role of Gardnerella vaginalis as an etiological agent of bacterial vaginosis. Iran J Microbiol. 2014;6(6):409-14. PMID: 25926959. KQ2E4a.25926959
32 Bazot M, Lafont C, Rouzier R, . Diagnostic accuracy of physical examination, transvaginal sonography, rectal endoscopic sonography, and magnetic resonance imaging to diagnose deep infiltrating endometriosis. Fertil Steril. 2009;92(6):1825-33. PMID: 19019357. KQ2E4a.19019357
33 Bermejo C, Martinez-Ten P, Recio M, . Three-dimensional ultrasound and magnetic resonance imaging assessment of cervix and vagina in women with uterine malformations. Ultrasound Obstet Gynecol. 2014;43(3):336-45. PMID: 23754235. KQ2E4.23754235
34 Bishop GB. Vaginal Discharge. In: Walker HK, Hall WD, Hurst JW, editors. Clinical Methods: The History, Physical, and Laboratory Examinations. Boston: Butterworth Publishers; 1990. KQ1E2, KQ2E2, KQ3E2.
35 Bluth EI, Ferrari BT, Sullivan MA. Real-time pelvic ultrasonography as an adjunct to digital examination. Radiology. 1984;153(3):789-90. PMID: 6387796. KQ1E2, KQ2E2, KQ3E2.6387796
36 Bocca SM, Abuhamad AZ. Use of 3-dimensional sonography to assess uterine anomalies. J Ultrasound Med. 2013;32(1):1-6. PMID: 23269704. KQ2E6.23269704
37 Botelho S, Pereira LC, Marques J, . Is there correlation between electromyography and digital palpation as means of measuring pelvic floor muscle contractility in nulliparous, pregnant, and postpartum women? Neurourol Urodyn. 2013;32(5):420-3. PMID: 23023961. KQ2E3a.23023961
38 Bourne P, Charles C, Francis C, . Perception, attitude and practices of women towards pelvic examination and Pap smear in Jamaica. N Am J Med Sci. 2010;2(10):478-86. PMID: 22558551. KQ3E3a.22558551
39 Bourne TH, Campbell S, Reynolds K, . The potential role of serum CA 125 in an ultrasound-based screening program for familial ovarian cancer. Gynecol Oncol. 1994;52(3):379-85. PMID: 8157195. KQ2E6.8157195
40 Bourne TH, Campbell S, Reynolds KM, . Screening for early familial ovarian cancer with transvaginal ultrasonography and colour blood flow imaging. BMJ. 1993;306(6884):1025-9. PMID: 8490496. KQ2E6.8490496
41 Bourne TH, Whitehead MI, Campbell S, . Ultrasound screening for familial ovarian cancer. Gynecol Oncol. 1991;43(2):92-7. PMID: 1743564. KQ2E6.1743564
42 Boyer SC, Pukall CF. Pelvic examination experiences in women with and without chronic pain during intercourse. J Sex Med. 2014;11(12):3035-50. PMID: 25243968. KQ3E5b.25243968
43 Brain KE, Lifford KJ, Fraser L, . Psychological outcomes of familial ovarian cancer screening: no evidence of long-term harm. Gynecol Oncol. 2012;127(3):556-63. PMID: 22943881. KQ3E4a.22943881
44 Broadmore J, Carr-Gregg M, Hutton JD. Vaginal examinations: women's experiences and preferences. N Z Med J. 1986;99(794):8-10. PMID: 3456108. KQ3E2b.3456108
45 Buchsbaum GM, Duecy E. Is parity in the eye of the beholder?. Int Urogynecol J Pelvic Floor Dysfunct 2008;19(6):753-5. PMID: 18064395. KQ2E5.18064395
46 Buckshee K, Temsu I, Bhatla N, . Pelvic examination, transvaginal ultrasound and transvaginal color Doppler sonography as predictors of ovarian cancer. Int J Gynaecol Obstet. 1998;61(1):51-7. PMID: 9622173. KQ2E4a.9622173
47 Buist M, Golding R, Burger C, . Comparative evaluation of diagnostic methods in ovarian carcinoma with emphasis on CT and MRI. Gynecol Oncol. 1994;52(2):191-8. PMID: 8314138. KQ2E4a.8314138
48 Buys SS, Partridge E, Black A, . Effect of screening on ovarian cancer mortality: the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Randomized Controlled Trial. JAMA. 2011;305(22):2295-303. PMID: 21642681. KQ1E6, KQ2E6, KQ3E6.21642681
49 Campbell KA, Shaughnessy AF. Diagnostic utility of the digital rectal examination as part of the routine pelvic examination. J Fam Pract. 1998;46(2):165-7. PMID: 9487324. KQ2E6.9487324
50 Campbell S, Bhan V, Royston P, . Transabdominal ultrasound screening for early ovarian cancer. BMJ. 1989;299(6712):1363-7. PMID: 2513964. KQ2E6.2513964
51 Campbell S, Bourne T, Bradley E. Screening for ovarian cancer by transvaginal sonography and colour Doppler. Eur j Obstet Gynecol Reprod Biol. 1993;49(1-2):33-4. PMID: 8365513. KQ2E6.8365513
52 Campbell S, Goessens L, Goswamy R, . Real-time ultrasonography for determination of ovarian morphology and volume. A possible early screening test for ovarian cancer? Lancet. 1982;1(8269):425-6. PMID: 6121093. KQ2E6.6121093
53 Campbell S, Royston P, Bhan V, . Novel screening strategies for early ovarian cancer by transabdominal ultrasonography. Br J Obstet Gynaecol. 1990;97(4):304-11. PMID: 2187523. KQ2E6.2187523
54 Carr PL, Rothberg MB, Friedman RH, . “Shotgun” versus sequential testing. Cost-effectiveness of diagnostic strategies for vaginitis. J Gen Intern Med. 2005;20(9):793-9. PMID: 16117745. KQ2E4a.16117745
55 Carter J, Fowler J, Carson L, . How accurate is the pelvic examination as compared to transvaginal sonography? A prospective, comparative study. J Reprod Med. 1994;39(1):32-4. PMID: 8169913. KQ2E7.8169913
56 Carter S, Rad M, Schwarz B, . Creating a more positive patient experience of pelvic examination. J Am Assoc Nurse Pract. 2013;25(11):611-8. PMID: 24170536. KQ3E2.24170536
57 Chadha P, Puri M, Gupta R. A comparative evaluation of clinical examination, pelvic ultrasound and laparoscopy in the diagnosis of pelvic masses. Indian J Med Sci. 1994;48(7):158-60. PMID: 7959976. KQ2E3a.7959976
58 Chang A, Sandweiss L, Bose S. Cytologically benign endometrial cells in the papanicolaou smears of postmenopausal women. Gynecol Oncol. 2001;80(1):37-43. PMID: 11136567. KQ2E6.11136567
59 Cheewadhanaraks S, Peeyananjarassri K, Dhanaworavibul K, . Positive predictive value of clinical diagnosis of endometriosis. J Med Assoc Thai. 2004;87(7):740-4. PMID: 15521226. KQ2E4a.15521226
60 Ciatto S, Cecchini S, Gervasi G, . Association of endometrial thickness assessed at trans-vaginal ultrasonography to endometrial cancer in postmenopausal women asymptomatic or with abnormal uterine bleeding. Radiol Med. 2002;104(5-6):437-42. PMID: 12589265. KQ2E6.12589265
61 Close RJ, Sachs CJ, Dyne PL. Reliability of bimanual pelvic examinations performed in emergency departments. West J Med. 2001;175(4):240-4; discussion 4-5. PMID: 11577050. KQ2E3.11577050
62 Cobb CE. Chief complaints, contraceptive use and diagnoses of female soldiers in ambulatory GYN clinic. Mil Med. 1987;152(2):70-1. PMID: 3103020. KQ1E2, KQ2E2, KQ3E2.3103020
63 Cook C. ‘About as comfortable as a stranger putting their finger up your nose’: speculation about the (extra)ordinary in gynaecological examinations. Cult Health Sex. 2011;13(7):767-80. PMID: 21656407. KQ3E2.21656407
64 Crane AK, Geller EJ, Myers EM, . Implementation of a standardized digital rectal exam to improve the accuracy of rectocele diagnosis. Int Urogynecol J. 2015;26(1):107-11. PMID: 25062655. KQ2E4.25062655
65 Crombie IK, Orbell S, Johnston G, . Women's experiences at cervical screening. Scott Med J. 1995;40(3):81-2. PMID: 7569870. KQ3E8.7569870
66 Davila GW, Singh A, Karapanagiotou I, . Are women with urogenital atrophy symptomatic? Am J Obstet Gynecol. 2003;188(2):382-8. PMID: 12592244. KQ2E6.12592244
67 DePriest PD, Gallion HH, Pavlik EJ, . Transvaginal sonography as a screening method for the detection of early ovarian cancer. Gynecol Oncol. 1997;65(3):408-14. PMID: 9190966. KQ2E6.9190966
68 DePriest PD, van Nagell JR, Jr. Transvaginal ultrasound screening for ovarian cancer. Clin Obstet Gynecol. 1992;35(1):40-4. PMID: 1544248. KQ2E6.1544248
69 DePriest PD, van Nagell JR, Jr., Gallion HH, . Ovarian cancer screening in asymptomatic postmenopausal women. Gynecol Oncol. 1993;51(2):205-9. PMID: 8276295. KQ2E6.8276295
70 Dessole S, Farina M, Rubattu G, . Sonovaginography is a new technique for assessing rectovaginal endometriosis. Fertil Steril. 2003;79(4):1023-7. PMID: 12749448. KQ2E6.12749448
71 Dietz HP, Hyland G, Hay-Smith J. The assessment of levator trauma: a comparison between palpation and 4D pelvic floor ultrasound. Neurourol Urodyn. 2006;25(5):424-7. PMID: 16721815. KQ2E2a.16721815
72 Dietz HP, Jarvis SK, Vancaillie TG. The assessment of levator muscle strength: a validation of three ultrasound techniques. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(3):156-9; discussion 9. PMID: 12140708. KQ2E2.12140708
73 Digesu GA, Khullar V, Cardozo L, . Inter-observer reliability of digital vaginal examination using a four-grade scale in different patient positions. Int Urogynecol J Pelvic Floor Dysfunct. 2008;19(9):1303-7. PMID: 18458801. KQ2E2.18458801
74 Domar AD. Psychological aspects of the pelvic exam: individual needs and physician involvement. Women Health. 1985;10(4):75-90. PMID: 3832651. KQ3E2.4024653
75 Donovan P. Delaying pelvic exams to encourage contraceptive use. Fam Plann Perspect. 1992;24(3):136, 44. PMID: 1628718. KQ3E4.1628718
76 Dragisic KG, Padilla LA, Milad MP. The accuracy of the rectovaginal examination in detecting cul-de-sac disease in patients under general anaesthesia. Hum Reprod. 2003;18(8):1712-5. PMID: 12871888. KQ2E4a.12871888
77 Drescher CW, Nelson J, Peacock S, . Compliance of average- and intermediate-risk women to semiannual ovarian cancer screening. Cancer Epidemiol Biomarkers Prev. 2004;13(4):600-6. PMID: 15066925. KQ1E6, KQ2E6, KQ3E6.15066925
78 Dueholm M, Lundorf E, Hansen ES, . Accuracy of magnetic resonance imaging and transvaginal ultrasonography in the diagnosis, mapping, and measurement of uterine myomas. Am J Obstet Gynecol. 2002;186(3):409-15. PMID: 11904599. KQ2E6.11904599
79 Dunican K. OTC product: Vagisil Screening Kit for vaginal infections. J Am Pharm Assoc. 2008;48(2):e33. PMID: 18359725. KQ2E6.18359725
80 Einhorn N, Bast R, Knapp R, . Long-term follow-up of the Stockholm screening study on ovarian cancer. Gynecol Oncol. 2000;79(3):466-70. PMID: 11104621. KQ1E6.11104621
81 Einhorn N, Sjovall K, Knapp RC, . Prospective evaluation of serum CA 125 levels for early detection of ovarian cancer. Obstet Gynecol. 1992;80(1):14-8. PMID: 1603484. KQ2E6.1603484
82 el-Minawi MF, el-Halafawy AA, Abdel Hadi M, . Laparoscopic, gynecographic and ultrasonographic vs. clinical evaluation of a pelvic mass. J Reprod Med. 1984;29(3):197-9. PMID: 6233422. KQ2E3a.6233422
83 Erlick Robinson G, Rosen BP, Bradley LN, . Psychological impact of screening for familial ovarian cancer: reactions to initial assessment. Gynecol Oncol. 1997;65(2):197-205. PMID: 9159325. KQ3E4a.9159325
84 Farley M, Golding JM, Minkoff JR. Is a history of trauma associated with a reduced likelihood of cervical cancer screening? J Fam Pract. 2002;51(10):827-31. PMID: 12401150. KQ3E8.12401150
85 Fedele L, Portuese A, Bianchi S, . Transrectal ultrasonography in the assessment of congenital vaginal canalization defects. Hum Reprod. 1999;14(2):359-62. PMID: 10099979. KQ2E4a.10099979
86 Feldmann RJ, Driscoll CE. Evaluation of the patient-centered pelvic examination. J Fam Pract. 1982;15(5):990-3. PMID: 7130923. KQ3E2.7130923
87 Ferris AK, Schapira MM, Young MJ. Accuracy of pelvic examination. Ann Intern Med. 1991;114(6):522. PMID: 1994805. KQ2E4.1994805
88 Fiddes P, Scott A, Fletcher J, . Attitudes towards pelvic examination and chaperones: a questionnaire survey of patients and providers. Contraception. 2003;67(4):313-7. PMID: 12684154. KQ3E1.12684154
89 Finkler N, Benacerraf B, Lavin P, . Comparison of serum CA 125, clinical impression, and ultrasound in the preoperative evaluation of ovarian masses. Obest Gynecol. 1988;72(4):659-64. PMID: 3047614. KQ2E4a.3047614
90 Firoozabadi RD, Karimi Zarchi M, Mansurian HR, . Evaluation of diagnostic value of CT scan, physical examination and ultrasound based on pathological findings in patients with pelvic masses. Asian Pac J Cancer Prev. 2011;12(7):1745-7. PMID: 22126557. KQ2E3a.22126557
91 Fischer-Rasmussen W, Hansen RI, Stage P. Predictive values of diagnostic tests in the evaluation of female urinary stress incontinence. Acta Obstet Gynecol Scand. 1986;65(4):291-4. PMID: 3739640. KQ2E4a.3739640
92 Fisher LD, Fletcher KE, Blake DR. Can the diagnosis of pelvic inflammatory disease be excluded without a bimanual examination? Clin Pediatr (Phila). 2004;43(2):153-8. PMID: 15024438. KQ2E2.15024438
93 Floyd A, Steffens RF, Pavlik E, . Receipt of a false positive test result during routine screening for ovarian cancer: a teachable moment? J Clin Psychol Med Settings. 2011;18(1):70-7. PMID: 21373852. KQ3E2.21373852
94 Franchi M, Beretta P, Ghezzi F, . Diagnosis of pelvic masses with transabdominal color Doppler, CA 125 and ultrasonography. Acta Obstet Gynecol Scand. 1995;74(9):734-9. PMID: 7572110. KQ2E6.7572110
95 Frawley H,Galea M,Phillips B, ., editors. Effect of test position, using two different methods of measurement, on reliability of pelvic floor muscle strength assessment (Abstract). Proceedings of the Joint Meeting of the International Continence Society (ICS) (34th Annual Meeting) and the International UroGynecological Association (IUGA); 2004 Aug 23-27; Paris, France. KQ2E2a.
96 Frederick JL, Paulson RJ, Sauer MV. Routine use of vaginal ultrasonography in the preoperative evaluation of gynecologic patients. An adjunct to resident education. J Reprod Med. 1991;36(11):779-82. PMID: 1765955. KQ2E4a.1765955
97 Gaugler JE, Pavlik E, Salsman JM, . Psychological and behavioral impact of receipt of a “normal” ovarian cancer screening test. Prev Med. 2006;42(6):463-70. PMID: 16563482. KQ2E6.16563482
98 Geisler WM, Chow JM, Schachter J, . Pelvic examination findings and Chlamydia trachomatis infection in asymptomatic young women screened with a nucleic acid amplification test. Sex Transm Dis. 2007;34(6):335-8. PMID: 17028510. KQ2E8.17028510
99 Gentry-Maharaj A, Sharma A, Burnell M, . Acceptance of transvaginal sonography by postmenopausal women participating in the United Kingdom Collaborative Trial of Ovarian Cancer Screening. Ultrasound Obstet Gynecol. 2013;41(1):73-9. PMID: 22791597. KQ3E6.22791597
100 Ghaemmaghami F, Fakour F, Karimi Zarchi M, . Clinical assessment, gross examination, frozen section of ovarian masses: do patients benefit? Arch Gynecol Obstet.2008;278(3):209-13. PMID: 18259768. KQ2E3a.18259768
101 Goff B, Lowe K, Kane J, . The safety of symptom based screening for ovarian cancer. Gynecol Oncol. 2012;127(1 Suppl):S10. PMID: 24989514. KQ2E6.
102 Gohagan JK, Prorok PC, Hayes RB, . The Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial of the National Cancer Institute: history, organization, and status. Control Clin Trials. 2000;21(6 Suppl):251S-72S. PMID: 11189683. KQ1E6, KQ2E6, KQ3E6.11189683
103 Gold E, Guthmann R, Plonka C. Clinical inquiry: do annual pelvic exams benefit asymptomatic women who receive regular Pap smears? J Fam Pract. 2015;64(1):51-2, 65. PMID: 25574511. KQ2E2.25574511
104 Gollub EL, Westhoff C, Timor-Tritsch IE. Detection of ovaries by transvaginal sonography in postmenopausal women. Ultrasound Obstet Gynecol. 1993;3(6):422-5. PMID: 12797244. KQ2E6.12797244
105 Golomb D. Attitudes toward pelvic examinations in two primary care settings. R I Med J. 1983;66(7):281-4. PMID: 6577533 KQ3E5.6577533
106 Greendale GA, Zibecchi L, Petersen L, . Development and validation of a physical examination scale to assess vaginal atrophy and inflammation. Climacteric. 1999;2(3):197-204. PMID: 11910597. KQ2E4a.11910597
107 Grover SR, Quinn MA. Is there any value in bimanual pelvic examination as a screening test. Med J Aust. 1995;162(8):408-10. PMID: 7746172. KQ2E5a, KQ3E5a.7746172
108 Gull B, Karlsson B, Milsom I, . Transvaginal sonography of the endometrium in a representative sample of postmenopausal women. Ultrasound Obstet Gynecol. 1996;7(5):322-7. PMID: 8774096. KQ2E6.8774096
109 Haar E, Halitsky V, Stricker G. Patients' attitudes toward gynecologic examination and to gynecologists. Med Care. 1977;15(9):787-95. PMID: 895235. KQ3E5b.895235
110 Hadgu A, Westrom L, Brooks CA, . Predicting acute pelvic inflammatory disease: a multivariate analysis.[Erratum appears in Am J Obstet Gynecol 1987 Jan;156(1):264]. Am J Obstet Gynecol. 1986;155(5):954-60. PMID: 3535519. KQ2E4a.3535519
111 Hagstad A, Janson PO, Lindstedt G. Gynaecological history, complaints and examinations in a middle-aged population. Maturitas. 1985;7(2):115-28. PMID: 3929022. KQ2E5.3929022
112 Hall AF, Theofrastous JP, Cundiff GW, . Interobserver and intraobserver reliability of the proposed International Continence Society, Society of Gynecologic Surgeons, and American Urogynecologic Society pelvic organ prolapse classification system. Am J Obstet Gynecol. 1996;175(6):1467-70; discussion 70-1. PMID: 8987926. KQ2E5.8987926
113 Harper C, Balistreri E, Boggess J, . Provision of hormonal contraceptives without a mandatory pelvic examination: the first stop demonstration project. Fam Plann Perspect. 2001;33(1):13-8. PMID: 11271540 KQ3E5.11271540
114 Harsanyi A, Mott S, Kendall S, . The impact of a history of child sexual assault on women's decisions and experiences of cervical screening. Aust Fam Physician. 2003;32(9):761-2. PMID: 14524223. KQ3E8.14524223
115 Hartge P, Hayes R, Reding D, . Complex ovarian cysts in postmenopausal women are not associated with ovarian cancer risk factors: preliminary data from the prostate, lung, colon, and ovarian cancer screening trial. Am J Obstet Gynecol. 2000;183(5):1232-7. PMID: 11084571. KQ1E2, KQ2E2, KQ3E2.11084571
116 Hartge P, Hayes R, Reding D, . Complex ovarian cysts in postmenopausal women are not associated with ovarian cancer risk factors: preliminary data from the prostate, lung, colon, and ovarian cancer screening trial. Am J Obstet Gynecol. 2000;183(5):1232-7. PMID: 11084571. KQ2E6.11084571
117 Hartge P, Hayes R, Sherman M, . Complex ovarian cysts in postmenopausal women are not associated with ovarian cancer risk factors. Preliminary data from the plco cancer screening trial. Ann Epidemiol. 2000;10(7):465. PMID: 11018385. KQ1E6, KQ2E6, KQ3E6.11018385
118 Hathorn E, Ng A, Page M, . A service evaluation of the Gen-Probe APTIMA nucleic acid amplification test for Trichomonas vaginalis: should it change whom we screen for infection? Sex Transm Infect. 2015;91(2):81-6. PMID: 25170162. KQ2E6.25170162
119 Henderson JT, Sawaya GF, Blum M, . Pelvic examinations and access to oral hormonal contraception. Obstet Gynecol. 2010;116(6):1257-64. PMID: 21099589. KQ3E2.21099589
120 Hermsen BB, Olivier RI, Verheijen RH, . No efficacy of annual gynaecological screening in BRCA1/2 mutation carriers; an observational follow-up study. Br J Cancer. 2007;96(9):1335-42. PMID: 17426707. KQ2E6.17426707
121 Hesselius I, Lisper H, Nordstrom A, . Comparison between participants and non-participants at a gynaecological mass screening. Scand J Soc Med. 1975;3(3):129-38. PMID: 1215854. KQ3E5.1215854
122 Higgins RV, van Nagell JR, Jr., Donaldson ES, . Transvaginal sonography as a screening method for ovarian cancer. Gynecol Oncol. 1989;34(3):402-6. PMID: 2670695. KQ2E6.2670695
123 Hilden M, Sidenius K, Langhoff-Roos J, . Women's experiences of the gynecologic examination: factors associated with discomfort. Acta Obstet Gynecol Scand. 2003;82(11):1030-6. PMID: 14616277. KQ3E5b.14616277
124 Hill DA, Cacciatore ML, Lamvu G. Sheathed versus standard speculum for visualization of the cervix. Int J Gynaecol Obstet. 2014;125(2):116-20. PMID: 24565103. KQ3E6.24565103
125 Hill DA, Lamvu G. Effect of lubricating gel on patient comfort during vaginal speculum examination: a randomized controlled trial. Obstet Gynecol. 2012;119(2 Pt 1):227-31. PMID: 22270273. KQ3E1.22270273
126 Holland TK, Hoo WL, Mavrelos D, . Reproducibility of assessment of severity of pelvic endometriosis using transvaginal ultrasound. Ultrasound Obstet Gynecol. 2013;41(2):210-5. PMID: 22745055. KQ2E6.22745055
127 Holman LL, Lu KH, Bast RC, Jr., . Risk perception, worry, and test acceptance in average-risk women who undergo ovarian cancer screening. Am J Obstet Gynecol. 2014;210(3):257.e1-6. PMID: 24246524. KQ3E6.24246524
128 Hopkins MP, Schmidt RW, Roberts JA, . Gland cell carcinoma (adenocarcinoma) of the cervix. Obstet Gynecol. 1988;72(5):789-95. PMID: 3173931. KQ2E8.3173931
129 Hoyo C, Yamall K, Skinner C, . Pain predicts non-adherence to pap smear screening among middle-aged African American women. Prev Med. 2005;41(2):439-45. PMID: 15917039 KQ3E6.15917039
130 Hudelist G, Ballard K, English J, . Transvaginal sonography vs. clinical examination in the preoperative diagnosis of deep infiltrating endometriosis. Ultrasound Obstet Gynecol. 2011;37(4):480-7. PMID: 21433168. KQ2E4a.21433168
131 Hundley AF, Wu JM, Visco AG. A comparison of perineometer to brink score for assessment of pelvic floor muscle strength. Am J Obstet Gynecol. 2005;192(5):1583-91. PMID: 15902162. KQ2E2.15902162
132 Huppert JS, Hesse EA, Bernard MC, . Accuracy and trust of self-testing for bacterial vaginosis. J Adolesc Health. 2012;51(4):400-5. PMID: 22999842. KQ2E4.22999842
133 Inal MM, Incebiyik A, Sanci M, . Ovarian cysts in tamoxifen-treated women with breast cancer. Aur J Obstet Gynecol Reprod Biol. 2005;120(1):104-6. PMID: 15866095. KQ1E3a, KQ2E3a, KQ3E3a.15866095
134 Isherwood PJ, Rane A. Comparative assessment of pelvic floor strength using a perineometer and digital examination. BJOG. 2000;107(8):1007-11. PMID: 10955433. KQ2E2a.10955433
135 Jacobs I, Davies AP, Bridges J, . Prevalence screening for ovarian cancer in postmenopausal women by CA 125 measurement and ultrasonography. BMJ. 1993;306(6884):1030-4. PMID: 8490497. KQ2E6.8490497
136 Jacobs I, Gentry-Maharaj A, Burnell M, . Sensitivity and specificity of transvaginal ultrasound screening for endometrial cancer in 40,000 women from the UK Collaborative Trial of Ovarian Cancer Screening (UKCTOCS). Int J Gynaecol Cancer. 2006;16(s3):618, Abstract 0066. PMID: None. KQ2E6.
137 Jacobs IJ. The UK collaborative trial of ovarian screening (UKCTOCS): recruitment, randomisation, initial screen [abstract]. Int J Gynaecol Cancer. 2006;16(s3):600, Abstract 0005. PMID: None. KQ1E6, KQ2E6.
138 Jacobs IJ, Jeyerajah A, Davies AP, . High sensitivity of an annual multimodal screening strategy for ovarian cancer. Gynecol Oncol. 1997;64(2):291. PMID: None. KQ1E6, KQ2E6, KQ3E6.
139 Jacobs IJ, Oram DH, Bast RC, Jr. Strategies for improving the specificity of screening for ovarian cancer with tumor-associated antigens CA 125, CA 15-3, and TAG 72.3. Obstet Gynecol. 1992;80(3 Pt 1):396-9. PMID: 1495694. KQ2E6.1495694
140 Jacobs IJ, Skates SJ, MacDonald N, . Screening for ovarian cancer: a pilot randomised controlled trial. Lancet. 1999;353(9160):1207-10. PMID: 10217079. KQ1E2, KQ2E2.10217079
141 Jacobs IJ, Skates SJ, MacDonald N, . Screening for ovarian cancer: a pilot randomised controlled trial. Lancet. 1999;353(9160):1207-10. PMID: 10217079. KQ1E6, KQ2E6.10217079
142 Jokubkiene L, Sladkevicius P, Valentin L. Transvaginal ultrasound examination of the endometrium in postmenopausal women without vaginal bleeding. Ultrasound Obstet Gynecol. 2015. PMID: 26678251. KQ2E6.26678251
143 Jones HE, Brudney K, Sawo DJ, . The acceptability of a self-lavaging device compared to pelvic examination for cervical cancer screening among low-income women. J Womens Health (Larchmt). 2012;21(12):1275-81. PMID: 22906043. KQ3E8.22906043
144 Jundt K, Peschers U, Kentenich H. The investigation and treatment of female pelvic floor dysfunction. Dtsch Arztebl Int. 2015;112(33-34):564-74. PMID: 26356560. KQ2E2.26356560
145 Kampan NC, Suffian SS, Ithnin NS, . Evaluation of BV() Blue Test Kit for the diagnosis of bacterial vaginosis. Sex Reprod Healthc. 2011;2(1):1-5. PMID: 21147452. KQ2E3a.21147452
146 Kauffman RP, Griffin SJ, Lund JD, . Current recommendations for cervical cancer screening: do they render the annual pelvic examination obsolete? Med Princ Pract. 2013;22(4):313-22. PMID: 23328247. KQ2E2.23328247
147 Keskin AE, Onaran Y, Duvan IC, . Topical anesthetic (lidocaine-prilocaine) cream application before speculum examination in postmenopausal women. J Minim Invasive Gynecol. 2012;19(3):350-5. PMID: 22417905. KQ3E1.22417905
148 Khan N, Afroz N, Aqil B, . Neoplastic and nonneoplastic ovarian masses: Diagnosis on cytology. J Cytol. 2009;26(4):129-33. PMID: 21938175. KQ1E3a, KQ2E3a, KQ3E3a.21938175
149 Kisa S, Taskin L. Validity of the symptomatic approach used by nurses in diagnosing vaginal infections. J Clin Nurs. 2009;18(7):1059-68. PMID: 19284438. KQ2E3a.19284438
150 Kobayashi H, Yamada Y, Sado T, . A randomized study of screening for ovarian cancer: a multicenter study in Japan. Int J Gynaecol Cancer. 2008;18(3):414-20. PMID: 17645503. KQ2E6.17645503
151 Kramer BS, Gohagan J, Prorok PC, . A National Cancer Institute sponsored screening trial for prostatic, lung, colorectal, and ovarian cancers. Cancer. 1993;71(2 Suppl):589-93. PMID: 8420681. KQ1E2, KQ2E2, KQ3E2.8420681
152 Kurjak A, Prka M, Arenas JM, . Three-dimensional ultrasonography and power Doppler in ovarian cancer screening of asymptomatic peri- and postmenopausal women. Croat Med J. 2005;46(5):757-64. PMID: 16158468. KQ2E6.16158468
153 Kurjak A, Shalan H, Kupesic S, . An attempt to screen asymptomatic women for ovarian and endometrial cancer with transvaginal color and pulsed Doppler sonography. J Ultrasound Med. 1994;13(4):295-301. PMID: 7932995. KQ2E6.7932995
154 Kuroishi T, Hirose K, Tominaga S. Evaluation of the efficacy of mass screening for uterine cancer in Japan. Jpn J Cancer Res. 1986;77(4):399-405. PMID: 3084430. KQ1E2, KQ2E2, KQ3E2.3084430
155 Kuroishi T, Hirose K, Tominaga S. Evaluation of the effectiveness of mass screening for uterine cancer in Japan: the potential years of life lost. Environ Health Perspect. 1990;87:51-6. PMID: 2269240. KQ2E2.2269240
156 Lacey JV, Jr., Greene MH, Buys SS, . Ovarian cancer screening in women with a family history of breast or ovarian cancer. Obstet Gynecol. 2006;108(5):1176-84. PMID: 17077240. KQ2E6.17077240
157 Lakeman MME, Zijta FM, Peringa J, . Dynamic magnetic resonance imaging to quantify pelvic organ prolapse: Reliability of assessment and correlation with clinical findings and pelvic floor symptoms. Int Urogynecol J. 2012;23(11):1547-54. PMID: 22531955 KQ2E6.22531955
158 Lamerato LE, Marcus PM, Jacobsen G, . Recruitment in the prostate, lung, colorectal, and ovarian (PLCO) cancer screening trial: the first phase of recruitment at Henry Ford Health System. Cancer Epidemiol Biomarkers and Prev. 2008;17(4):827-33. PMID: 18398023. KQ2E5.18398023
159 Lamont RF, Morgan DJ, Wilden SD, . Prevalence of bacterial vaginosis in women attending one of three general practices for routine cervical cytology. Int J STD AIDS. 2000;11(8):495-8. PMID: 10990331. KQ2E5.10990331
160 Lang A, Rodgers C, Laffaye C, . Sexual trauma, posttraumatic stress disorder, and health behavior. Behav Med. 2003;28(4):150-8. PMID: 14663922 KQ3E6.14663922
161 Lee T, Westrup D, Ruzek J, . Impact of clinician gender on examination anxiety among female veterans with sexual trauma: a pilot study. J Womens Health (Larchmt). 2007;16(9):129-9. PMID: 18001185 KQ3E1.18001185
162 Lee TS, Kim JW, Park NH, . Assessing clinical performance of gynecology residents: sonographic evaluation of adnexal masses based on morphological scoring systems. Ultrasound Obstet Gynecol 2005;26(7):776-9. PMID: 16308902. KQ2E6.16308902
163 Leeners B, Stiller R, Block E, . Effect of childhood sexual abuse on gynecologic care as an adult. Psychosomatics. 2007;48(5):385-93. PMID: 17878496. KQ3E2b.17878496
164 Li X, Liu X, Guo SW. Clinical profiles of 710 premenopausal women with adenomyosis who underwent hysterectomy. J Obstet Gynaecol Res. 2014;40(2):485-94. PMID: 24148010. KQ2E3a.24148010
165 Livengood CH, 3rd, Hill GB, Addison WA. Pelvic inflammatory disease: findings during inpatient treatment of clinically severe, laparoscopy-documented disease. Am J Obstet Gynecol. 1992;166(2):519-24. PMID: 1531573. KQ2E4a.1531573
166 Lone FW, Thakar R, Sultan AH, . Accuracy of assessing Pelvic Organ Prolapse Quantification points using dynamic 2D transperineal ultrasound in women with pelvic organ prolapse. Int Urogynecol J Pelvic Floor Dysfunct. 2012;23(11):1555-60. PMID: 22543548. KQ2E2.22543548
167 Long WN. Pelvic Examination. In: Walker HK, Hall WD, Hurst JW, editors. Clinical Methods: The History, Physical, and Laboratory Examinations. Boston: Butterworth Publishers; 1990. KQ1E2, KQ2E2, KQ3E2.
168 Lu KH, Skates S, Hernandez MA, . A 2-stage ovarian cancer screening strategy using the Risk of Ovarian Cancer Algorithm (ROCA) identifies early-stage incident cancers and demonstrates high positive predictive value. Cancer. 2013;119(19):3454-61. PMID: 23983047. KQ2E6.23983047
169 Lyons MS, Lindsell CJ, Trott AT. Emergency department pelvic examination and Pap testing: addressing patient misperceptions. Acad Emerg Med. 2004;11(4):405-8. PMID: 15064218. KQ3E3.15064218
170 Maggino T, Gadducci A, D'Addario V, . Prospective multicenter study on CA 125 in postmenopausal pelvic masses. Gynecol Oncol. 1994;54(2):117-23. PMID: 8063233. KQ2E6.8063233
171 Marchetti M, Zambon A, Lamaina V, . Ultrasound as a possible screening method in ovarian cancer.[Erratum appears in Eur J Gynaecol Oncol. 2002;23(3):172 Note: Marchioro S [corrected to Marchiori S]]. Eur J Gynaecol Oncol. 2002;23(2):123-6. PMID: 12013107. KQ2E6.12013107
172 Mardh PA, Tchoudomirova K, Elshibly S, . Symptoms and signs in single and mixed genital infections. International journal of gynaecology and obstetrics: the official organ of the International Federation of Gynaecology and Obstetrics. 1998;63(2):145-52. PMID: 9856320. KQ2E5.9856320
173 Masse R, Laperriere H, Rousseau H, . Chlamydia trachomatis cervical infection: prevalence and determinants among women presenting for routine gynecologic examination. CMAJ. 1991;145(8):953-61. PMID: 1913429. KQ2E8.1913429
174 Menon U, Gentry-Maharaj A, Hallett R, . Sensitivity and specificity of multimodal and ultrasound screening for ovarian cancer, and stage distribution of detected cancers: results of the prevalence screen of the UK Collaborative Trial of Ovarian Cancer Screening (UKCTOCS). Lancet Oncol. 2009;10(4):327-40. PMID: 19282241. KQ2E6.19282241
175 Menon U, Skates SJ, Lewis S, . Prospective study using the risk of ovarian cancer algorithm to screen for ovarian cancer. J Clin Oncol. 2005;23(31):7919-26. PMID: 16258091. KQ2E6.16258091
176 Menon U, Talaat A, Rosenthal AN, . Performance of ultrasound as a second line test to serum CA125 in ovarian cancer screening. BJOG. 2014;121 Suppl 7: 35-9. PMID: 25488086. KQ2E6.25488086
177 Miller RW, Pavlik EJ, Baldwin LA, . Complications from surgeries prompted by ovarian cancer screening. Gynecol Oncol. 2015;137,Supplement 1:180. PMID: None. KQ3E6.25636459
178 Misawa T, Asai M, Higashide K. How to decrease false-positive cases of ovarian cancer screening by transvaginal sonography. J Exp Clin Cancer Res. 1997;16(2):217-20. PMID: 9261750. KQ2E7, KQ3E7.9261750
179 Moettus A, Sklar D, Tandberg D. The effect of physician gender on women's perceived pain and embarrassment during pelvic examination. Am J Emerg Med. 1999;17(7):635-7. PMID: 10597078. KQ3E1.10597078
180 Moore RG, Hawkins DM, Miller MC, . Combining clinical assessment and the Risk of Ovarian Malignancy Algorithm for the prediction of ovarian cancer. Gynecol Oncol. 2014;135(3):547-51. PMID: 25449569. KQ2E4a.25449569
181 Morgan DJ. Comparison of Gram-stained smears prepared from blind vaginal swabs with those obtained at speculum examination for the assessment of vaginal flora. Genitourinary medicine. 1997;73(2):153. PMID: None. KQ2E4.
182 Morin M, Dumoulin C, Bourbonnais D, . Pelvic floor maximal strength using vaginal digital assessment compared to dynamometric measurements. Neurourol Urodyn. 2004;23(4):336-41. PMID: 15227651. KQ2E2.15227651
183 Mouritsen L, Sander P, Bernstein I, . Comparison of palpation, ultrasonography and perineometry for examination of the pelvic floor (Abstract). Int Urogynecol J Pelvic Floor Dysfunct. 1999;10 Suppl 1:S16-s7. PMID: None. KQ2E4a.
184 Muto MG, Cramer DW, Brown DL, . Screening for ovarian cancer: the preliminary experience of a familial ovarian cancer center. Gynecol Oncol. 1993;51(1):12-20. PMID: 8244166. KQ2E6.8244166
185 Nagata H, Takahashi K, Yamane Y, . Abnormally high values of CA 125 and CA 19-9 in women with benign tumors. Gynecol Obstet Invest. 1989;28(3):165-8. PMID: 2680806. KQ2E2.2680806
186 Nezhat C, Santolaya J, Nezhat FR. Comparison of transvaginal sonography and bimanual pelvic examination in patients with laparoscopically confirmed endometriosis. J Am Assoc Gynecol Laparosc. 1994;1(2):127-30. PMID: 9050474. KQ2E4a.9050474
187 Nishikawa J. An evidence-based review of the rectovaginal examination during well-woman visits. J Am Assoc Nurse Pract. 2015. PMID: 26485216. KQ2E2.26485216
188 Nyante SJ, Black A, Kreimer AR, . Pathologic findings following false-positive screening tests for ovarian cancer in the Prostate, Lung, Colorectal and Ovarian (PLCO) cancer screening trial. Gynecol Oncol. 2011;120(3):474-9. PMID: 21144559. KQ1E6, KQ2E6, KQ3E6.21144559
189 Nygaard IE. Postvoid residual volume cannot be accurately estimated by bimanual examination. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(2):74-6. PMID: 8798090. KQ2E4a.8798090
190 Oboler SK, LaForce FM. The periodic physical examination in asymptomatic adults. Ann Intern Med. 1989;110(3):214-26. PMID: 2643379. KQ1E2, KQ2E2, KQ3E2.2643379
191 O'Brien WF, Buck DR, Nash JD. Evaluation of sonography in the initial assessment of the gynecologic patient. American journal of obstetrics and gynecology. 1984;149(6):598-602. PMID: 6742040. KQ2E4a.6742040
192 Oei AL, Massuger LF, Bulten J, . Surveillance of women at high risk for hereditary ovarian cancer is inefficient. Br J Cancer. 2006;94(6):814-9. PMID: 16495917. KQ2E4a.16495917
193 Olivier RI, Lubsen-Brandsma MA, Verhoef S, . CA125 and transvaginal ultrasound monitoring in high-risk women cannot prevent the diagnosis of advanced ovarian cancer. Gynecol Oncol. 2006;100(1):20-6. PMID: 16188302. KQ2E4a.16188302
194 Olsson HM, Gullberg MT. Role of the woman patient and fear of the pelvic examination. West J Nurs Res. 1987;9(3):357-67. PMID: 3673046. KQ3E2.3673046
195 Orbell S. Cognition and affect after cervical screening: the role of previous test outcome and personal obligation in future uptake expectations. Soc Sci Med. 1996;43(8):1237-43. PMID: 8903128. KQ3E8.8903128
196 Oscarsson M, Benzein E. Women's experiences of pelvic examination: an interview study. J Psychosom Obstet Gynaecol. 2002;23(1):17-25. PMID: 12061033. KQ3E2.12061033
197 Osofsky H. Women's reactions to pelvic examination. Obstet Gynecol. 1967;30(1):146-51. PMID: 6027483. KQ3E2.6027483
198 Ostergaard L, Moller JK, Andersen B, . Diagnosis of urogenital Chlamydia trachomatis infection in women based on mailed samples obtained at home: multipractice comparative study. BMJ. 1996;313(7066):1186-9. PMID: 8916753. KQ2E8.8916753
199 Ou MC, Pang CC, Ou D, . The implications of abdominal palpation with Ou MC manipulation for women with acute abdomen. Am J Emerg Med. 2012;30(3):421-5. PMID: 21354746. KQ2E6.21354746
200 Padilla LA, Radosevich DM, Milad MP. Accuracy of the pelvic examination in detecting adnexal masses. Obstet Gynecol. 2000;96(4):593-8. PMID: 11004365. KQ2E4a.11004365
201 Padilla LA, Radosevich DM, Milad MP. Limitations of the pelvic examination for evaluation of the female pelvic organs. Int J Gynaecol Obstet. 2005;88(1):84-8. PMID: 15617719. KQ2E4a.15617719
202 Parekh M, Swift S, Lemos N, . Multicenter inter-examiner agreement trial for the validation of simplified POPQ system. Int Urogynecol J Pelvic Floor Dysfunct. 2011;22(6):645-50. PMID: 21431391. KQ2E2.21431391
203 Park J, Kim TH, Lee HH, . Endosalpingiosis in postmenopausal elderly women. J Menopausal Med. 2014;20(1):32-4. PMID: 25371889. KQ1E2, KQ2E2, KQ3E2.25371889
204 Parkes CA, Smith D, Wald NJ, . Feasibility study of a randomised trial of ovarian cancer screening among the general population. J Med Screen. 1994;1(4):209-14. PMID: 8790521. KQ2E6.8790521
205 Partridge E, Kreimer AR, Greenlee RT, . Results from four rounds of ovarian cancer screening in a randomized trial. Obstet Gynecol. 2009;113(4):775-82. PMID: 19305319. KQ2E6.19305319
206 Partridge EE, Greenlee RT, Riley TL, . Assessing the risk of ovarian malignancy in asymptomatic women with abnormal CA 125 and transvaginal ultrasound scans in the prostate, lung, colorectal, and ovarian screening trial. Obstet Gynecol. 2013;121(1):25-31. PMID: 23262924. KQ2E6.23262924
207 Partridge EE, Kreimer AR, Buys SS, . Ovarian cancer screening in the Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial: Results from 4 years of annual screening in a randomized trial. Gynecol Oncol. 2007;104(3 Suppl 1):S14-5, Abstract 0. PMID: None. KQ1E6, KQ2E6.
208 Pavlik EJ, Saunders BA, Doran S, . The search for meaning-Symptoms and transvaginal sonography screening for ovarian cancer: predicting malignancy. Cancer. 2009;115(16):3689-98. PMID: 19603478. KQ2E6.19603478
209 Pereira VS, Hirakawa HS, Oliveira AB, . Relationship among vaginal palpation, vaginal squeeze pressure, electromyographic and ultrasonographic variables of female pelvic floor muscles. Braz J Phys Ther. 2014;18(5):428-34. PMID: 25317769. KQ2E4a.25372005
210 Petravage JB, Reynolds LJ, Gardner HJ, . Attitudes of women toward the gynecologic examination. J Fam Pract. 1979;9(6):1039-45. PMID: 521765. KQ3E5b.521765
211 Primrose RB. Taking the tension out of pelvic exams. Am J Nurs. 1984;84(1):72-4. PMID: 6559035. KQ1E2, KQ2E2, KQ3E2.6559035
212 Rabban JT, Garg K, Crawford B, . Early detection of high-grade tubal serous carcinoma in women at low risk for hereditary breast and ovarian cancer syndrome by systematic examination of fallopian tubes incidentally removed during benign surgery. Am J Surg Pathol. 2014;38(6):729-42. PMID: 24820399. KQ2E1.24820399
213 Rampone B, Rampone A, Tirabasso S, . Ovarian cancer screening by transvaginal color Doppler ultrasonography. Minerva Ginecol. 2001;53(1 Suppl 1):125-8. PMID: 11526707. KQ2E6.11526707
214 Reddy DM, Wasserman SA. Patient anxiety during gynecologic examinations. Behavioral indicators. J Reprod Med. 1997;42(10):631-6. PMID: 9350018. KQ3E2.9350018
215 Reeves RD, Drake TS, O'Brien WF. Ultrasonographic versus clinical evaluation of a pelvic mass. Obstet Gynecol. 1980;55(5):551-4. PMID: 7366913. KQ2E4a.7366913
216 Reich A, Kohorst F, Kreienberg R, . Influence of bladder volume on pelvic organ prolapse quantification results. Gynecol Obstet Invest. 2010;70(2):82-6. PMID: 20215766. KQ2E4a.20215766
217 Robohm JS, Buttenheim M. The gynecological care experience of adult survivors of childhood sexual abuse: a preliminary investigation. Women Health. 1996;24(3):59-75. PMID: 9046553. KQ3E2b.9046553
218 Rocconi RP, Scalici JM, Billheimer D, . Early detection of ovarian cancer via a self-sampling screening test of vaginal secretions: Feasibility and patient acceptance. Gynecol Oncol. 2015;137, Supplement 1:172-3. PMID: None. KQ2E6.
219 Roman LD, Muderspach LI, Stein SM, . Pelvic examination, tumor marker level, and gray-scale and Doppler sonography in the prediction of pelvic cancer. Obstet Gynecol. 1997;89(4):493-500. PMID: 9083301. KQ2E4a.9083301
220 Romanzi LJ, Polaneczky M, Glazer HI. Simple test of pelvic muscle contraction during pelvic examination: correlation to surface electromyography. Neurourol Urodyn. 1999;18(6):603-12. PMID: 10529708. KQ2E4a.10529708
221 Rosenthal AN, Fraser L, Manchanda R, . Results of annual screening in phase I of the United Kingdom familial ovarian cancer screening study highlight the need for strict adherence to screening schedule. J Clin Oncol. 2013;31(1):49-57. PMID: 23213100. KQ2E6.23213100
222 Roupa Z, Faros E, Raftopoulos V, . Serum CA 125 combined with transvaginal ultrasonography for ovarian cancer screening. In Vivo. 2004;18(6):831-6. PMID: 15646829. KQ2E6.15646829
223 Rufford BD, Jacobs IJ, Menon U. A randomised controlled trial of targeted screening for ovarian cancer [abstract]. Int J Gynecol Cancer. 2004;14 Suppl 1:116, Abstract 413. PMID: None. KQ2E6.
224 Rulin MC, Preston AL. Adnexal masses in postmenopausal women. Obstet Gynecol. 1987;70(4):578-81. PMID: 3627627. KQ2E4a.3627627
225 Saccardi C, Cosmi E, Borghero A, . Comparison between transvaginal sonography, saline contrast sonovaginography and magnetic resonance imaging in the diagnosis of posterior deep infiltrating endometriosis. Ultrasound Obstet Gynecol. 2012;40(4):464-9. PMID: 22253192. KQ2E4a.22253192
226 Salsman JM, Pavlik E, Boerner LM, . Clinical, demographic, and psychological characteristics of new, asymptomatic participants in a transvaginal ultrasound screening program for ovarian cancer. Prev Med. 2004;39(2):315-22. PMID: 15226040. KQ1E6, KQ2E6, KQ3E6.15226040
227 Sand-Jecklin K. Patient anxiety levels related to gynecologic examinations: use of the color breathwork relaxation method. Arch Psychiatr Nurs. 2008;22(4):240-2. PMID: 18640545. KQ3E2.18640545
228 Sari R, Buyukberber S, Sevinc A, . The effects of abdominal and bimanual pelvic examination and transvaginal ultrasonography on serum CA-125 levels. Clin Exp Obstet Gynecol. 2000;27(1):69-71. PMID: 10758808 KQ2E3a.10758808
229 Sartore A, Pregazzi R, Bortoli P, . Assessment of pelvic floor muscle function after vaginal delivery. Clinical value of different tests. J Reprod Med. 2003;48(3):171-4. PMID: 12698774. KQ2E2.12698774
230 Sato S, Yokoyama Y, Sakamoto T, . Usefulness of mass screening for ovarian carcinoma using transvaginal ultrasonography. Cancer. 2000;89(3):582-8. PMID: 10931457. KQ2E6.10931457
231 Schutter EM, Kenemans P, Sohn C, . Diagnostic value of pelvic examination, ultrasound, and serum CA 125 in postmenopausal women with a pelvic mass. An international multicenter study. Cancer. 1994;74(4):1398-406. PMID: 8055463. KQ2E4a.8055463
232 Schutter EM, Sohn C, Kristen P, . Estimation of probability of malignancy using a logistic model combining physical examination, ultrasound, serum CA 125, and serum CA 72-4 in postmenopausal women with a pelvic mass: an international multicenter study. Gynecol Oncol. 1998;69(1):56-63. PMID: 9570999. KQ2E4a.9570999
233 Schwartz PE, Chambers JT, Taylor KJ. Early detection and screening for ovarian cancer. J Cell Biochem Suppl. 1995;23:233-7. PMID: 8747402. KQ1E2, KQ2E2, KQ3E2.8747402
234 Scott IV. The identification of high risk and practical strategies for a population based randomized trial of ovarian cancer screening. Dis Markers. 1991;9(3-4):133-52. PMID: 1813206. KQ1E2, KQ2E2, KQ3E2.1813206
235 Seehusen DA, Baird DC, Bode DV. Dyspareunia in women. Am Fam Physician. 2014;90(7):465-70. PMID: 25369624. KQ1E2, KQ2E2, KQ3E2.25369624
236 Seehusen DA, Johnson DR, Earwood JS, . Improving women's experience during speculum examinations at routine gynaecological visits: randomised clinical trial. BMJ. 2006;333(7560):171. PMID: 16803941. KQ3E2.16803941
237 Sellors JW, Walter SD, Howard M. A new visual indicator of chlamydial cervicitis? Sex Transm Infect.2000;76(1):46-8. PMID: 10817069. KQ2E8.10817069
238 Seymore C, DuRant RH, Jay MS, . Influence of position during examination, and sex of examiner on patient anxiety during pelvic examination. J Pediatr. 1986;108(2):312-7. PMID: 3944721 KQ3E4.3944721
239 Sharma A, Apostolidou S, Burnell M, . Risk of epithelial ovarian cancer in asymptomatic women with ultrasound-detected ovarian masses: a prospective cohort study within the UK collaborative trial of ovarian cancer screening (UKCTOCS). Ultrasound Obstet Gynecol. 2012;40(3):338-44. PMID: 22911637. KQ1E6, KQ2E6, KQ3E6.22911637
240 Sharma A, Burnell M, Gentry-Maharaj A, . Factors affecting visualization of postmenopausal ovaries: descriptive study from the multicenter United Kingdom Collaborative Trial of Ovarian Cancer Screening (UKCTOCS). Ultrasound Obstet Gynecol. 2013;42(4):472-7. PMID: 23456790 KQ1E6, KQ2E6.23456790
241 Sharma A, Gentry-Maharaj A, Burnell M, . Assessing the malignant potential of ovarian inclusion cysts in postmenopausal women within the UK Collaborative Trial of Ovarian Cancer Screening (UKCTOCS): a prospective cohort study. BJOG. 2012;119(2):207-19. PMID: 21762355. KQ1E6, KQ2E6, KQ3E6.21762355
242 Shipley CF, 3rd, Simmons CL, Nelson GH. Comparison of transvaginal sonography with endometrial biopsy in asymptomatic postmenopausal women. J Ultrasound Med. 1994;13(2):99-104. PMID: 7932969. KQ2E6.7932969
243 Simavli S, Kaygusuz I, Kinay T, . The role of gel application in decreasing pain during speculum examination and its effects on papanicolaou smear results. Arch Gynecol Obstet. 2014;289(4):809-15. PMID: 24121692. KQ3E6.24121692
244 Simms I, Warburton F, Westrom L. Diagnosis of pelvic inflammatory disease: time for a rethink. Sex Transm Infect. 2003;79(6):491-4. PMID: 14663128. KQ2E4a.14663128
245 Singh RH, Erbelding EJ, Zenilman JM, . The role of speculum and bimanual examinations when evaluating attendees at a sexually transmitted diseases clinic. Sex Transm Infect. 2007;83(3):206-10. PMID: 17108005. KQ2E2a.17108005
246 Singh RH, Zenilman JM, Brown KM, . The role of physical examination in diagnosing common causes of vaginitis: a prospective study. Sex Transm Infect. 2013;89(3):185-90. PMID: 23019659. KQ2E6.23019659
247 Sladkevicius P, Valentin L, Marsal K. Transvaginal gray-scale and Doppler ultrasound examinations of the uterus and ovaries in healthy postmenopausal women. Ultrasound Obstet Gynecol. 1995;6(2):81-90. PMID: 8535922. KQ2E6.8535922
248 Smith CA, Witherow R. The assessment of female pelvic floor dysfunction. BJU Int. 2000;85(5):611-3. PMID: 10735937. KQ1E2, KQ2E2, KQ3E2.10735937
249 Smith MS, Smith MT. A stimulus control intervention in the gynecological exam with sexual abuse survivors. Women Health. 1999;30(2):39-51. PMID: 10881757. KQ3E2.10881757
250 Smith PP, O'Connor S, Gupta J, . Recurrent postmenopausal bleeding: a prospective cohort study. J Minim Invasive Gynecol. 2014;21(5):799-803. PMID: 24681065. KQ1E2, KQ2E2, KQ3E2.24681065
251 Stafl A, Mattingly RF, Foley DV, . Clinical diagnosis of vaginal adenosis. Obstet Gynecol. 1974;43(1):118-28. PMID: 4808952. KQ2E4a.4808952
252 Stampler KM, Lieberman A, Fraga M, . Vaginal wet mounts on asymptomatic adolescent females; are they beneficial? J Pediatr Adolesc Gynecol. 2008;21(4):227-30. PMID: 18656077. KQ2E4.18656077
253 Steinberg O. When you need me. Obstet Gynecol. 2015;125(5):1247. PMID: 25932855. KQ2E2.25932855
254 Stirling D, Evans DG, Pichert G, . Screening for familial ovarian cancer: failure of current protocols to detect ovarian cancer at an early stage according to the international Federation of gynecology and obstetrics system. J Clin Oncol. 2005;23(24):5588-96. PMID: 16110018. KQ2E6.16110018
255 Svihrova V, Svihra J, Luptak J, . Disability-adjusted life years (DALYs) in general population with pelvic organ prolapse: a study based on the prolapse quality-of-life questionnaire (P-QOL). Eur J Obstet Gynecol Reprod Biol. 2014;182:22-6. PMID: 25216448. KQ2E5.25216448
256 Swahnberg K, Wijma B, Siwe K. Strong discomfort during vaginal examination: why consider a history of abuse? Eur J Obstet Gynecol Reprod Biol.2011;157(2):200-5. PMID: 21470763. KQ3E5b.21470763
257 Swift S, Woodman P, O'Boyle A, . Pelvic Organ Support Study (POSST): the distribution, clinical definition, and epidemiologic condition of pelvic organ support defects. Am J Obstet Gynecol. 2005;192(3):795-806. PMID: 15746674. KQ2E5.15746674
258 Swift SE, Tate SB, Nicholas J. Correlation of symptoms with degree of pelvic organ support in a general population of women: what is pelvic organ prolapse? Am J Obstet Gynecol. 2003;189(2):372-7; discussion 7-9. PMID: 14520198. KQ2E5.14520198
259 Swygard H, Miller WC, Kaydos-Daniels SC, . Targeted screening for Trichomonas vaginalis with culture using a two-step method in women presenting for STD evaluation. Sex Transm Dis. 2004;31(11):659-64. PMID: 15502673. KQ2E4a.15502673
260 Tabor A, Jensen FR, Bock JE, . Feasibility study of a randomised trial of ovarian cancer screening. J Med Screen. 1994;1(4):215-9. PMID: 8790522. KQ2E6.8790522
261 Tailor A, Bourne TH, Campbell S, . Results from an ultrasound-based familial ovarian cancer screening clinic: a 10-year observational study. Ultrasound Obstet Gynecol. 2003;21(4):378-85. PMID: 12704748. KQ2E6.12704748
262 Tayal VS, Crean CA, Norton HJ, . Prospective comparative trial of endovaginal sonographic bimanual examination versus traditional digital bimanual examination in nonpregnant women with lower abdominal pain with regard to body mass index classification. J Ultrasound Med. 2008;27(8):1171-7. PMID: 18645075. KQ2E2.18645075
263 Taylor V, Yasul Y, Burke N, . Pap testing adherence among Vietnamese American women. Cancer Epidemiol Biomarkers and Prev. 2004;13(4):613-9. PMID: 15066927. KQ3E6.15066927
264 Tehrani FR, Hashemi S, Simbar M, . Screening of the pelvic organ prolapse without a physical examination; (a community based study). BMC women's health. 2011;11:48. PMID: 22082121. KQ2E3a.22082121
265 Thiagamoorthy G, Zacche M, Cardozo L, . Digital assessment and quantification of pelvic organ prolapse (DPOP-Q): a randomised cross-over diagnostic agreement trial. Int Urogynecol J. 2015. PMID: 26423265. KQ2E4a.26423265
266 Thompson JA, O'Sullivan PB, Briffa K, . Assessment of pelvic floor movement using transabdominal and transperineal ultrasound. Int Urogynecol J Pelvic Floor Dysfunct. 2005;16(4):285-92. PMID: 15782286. KQ2E6.15782286
267 Thorp JM, Jones LH, Wells E, . Assessment of pelvic floor function: a series of simple tests in nulliparous women. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(2):94-7. PMID: 8798094. KQ2E6.8798094
268 Tiemstra JD, Chico PD, Pela E. Genitourinary infections after a routine pelvic exam. J Am Board Fam Med. 2011;24(3):296-303. PMID: 21551402. KQ3E7.21551402
269 Tiemstra JD, Sinacore JM. The association of urinary tract infection with a recent pelvic examination in women. Arch Fam Med. 1996;5(6):357-60. PMID: 8640327. KQ3E7.8640327
270 Ueland FR, Depriest PD, Desimone CP, . The accuracy of examination under anesthesia and transvaginal sonography in evaluating ovarian size. Gynecol Oncol. 2005;99(2):400-3. PMID: 16084576. KQ2E2.16084576
271 Urban N, Thorpe JD, Bergan LA, . Potential role of HE4 in multimodal screening for epithelial ovarian cancer. J Natl Cancer Inst. 2011;103(21):1630-4. PMID: 21917606. KQ2E6.21917606
272 Uyar Y, Baytur YB, Inceboz U. Perineometer and digital examination for assessment of pelvic floor strength. Int J Gynaecol Obstet. 2007;98(1):64-5. PMID: 17466302. KQ2E3a.17466302
273 van de Wijgert JH, Kilmarx PH, Jones HE, . Differentiating normal from abnormal rates of genital epithelial findings in vaginal microbicide trials. Contraception. 2008;77(2):122-9. PMID: 18226677. KQ2E3a.18226677
274 van der Burg ME, Lammes FB, Verweij J. The role of CA 125 and conventional examinations in diagnosing progressive carcinoma of the ovary. Surg Gynecol Obstet. 1993;176(4):310-4. PMID: 8460404. KQ2E4a.8460404
275 van der Velde NM, Mourits MJ, Arts HJ, . Time to stop ovarian cancer screening in BRCA1/2 mutation carriers? Int J Cancer. 2009;124(4):919-23. PMID: 19035463. KQ2E4a.19035463
276 van Nagell JR, Jr., DePriest PD, Ueland FR, . Ovarian cancer screening with annual transvaginal sonography: findings of 25,000 women screened. Cancer. 2007;109(9):1887-96. PMID: 17373668. KQ2E6.17373668
277 van Nagell JR, Jr., Gallion HH, Pavlik EJ, . Ovarian cancer screening. Cancer. 1995;76(10 Suppl):2086-91. PMID: 8635005. KQ2E6.8635005
278 van Nagell JR, Jr., Higgins RV, Donaldson ES, . Transvaginal sonography as a screening method for ovarian cancer. A report of the first 1000 cases screened. Cancer. 1990;65(3):573-7. PMID: 2404560. KQ2E6.2404560
279 van Nagell JR, Jr., Miller RW, DeSimone CP, . Long-term survival of women with epithelial ovarian cancer detected by ultrasonographic screening. Obstet Gynecol. 2011;118(6):1212-21. PMID: 22105249. KQ1E6, KQ2E6, KQ3E6.22105249
280 van Nagell JR, Jr., Pavlik EJ. Ovarian cancer screening. Clin Obstet Gynecol. 2012;55(1):43-51. PMID: 22343228. KQ1E2, KQ2E2, KQ3E2.22343228
281 Vella PV. A survey of women undergoing a pelvic examination. Aust N Z J Obstet Gynaecol. 1991;31(4):355-7. PMID: 1799352. KQ3E5b.1799352
282 Volloyhaug I, Morkved S, Salvesen O, . Assessment of pelvic floor muscle contraction with palpation, perineometry and transperineal ultrasound: a cross-sectional study. Ultrasound Obstet Gynecol. 2015. PMID: 26300128. KQ2E5.26300128
283 Voss SC, Lacey CG, Pupkin M, . Ultrasound and the pelvic mass. J Reprod Med. 1983;28(12):833-7. PMID: 6229631. KQ2E4a.6229631
284 Vuento MH, Pirhonen JP, Makinen JI, . Evaluation of ovarian findings in asymptomatic postmenopausal women with color Doppler ultrasound. Cancer. 1995;76(7):1214-8. PMID: 8630900. KQ2E6.8630900
285 Vuento MH, Pirhonen JP, Makinen JI, . Screening for endometrial cancer in asymptomatic postmenopausal women with conventional and colour Doppler sonography. Br J Obstet Gynaecol. 1999;106(1):14-20. PMID: 10426254. KQ2E6.10426254
286 Wagstaff B. Rectal exam during routine pelvic exam. J Fam Med. 1998;46(5):357. PMID: 9597988. KQ2E6.9597988
287 Warnecke RB, Graham S. Characteristics of blacks obtaining Papanicolaou smears. Cancer. 1976;37(4):2015-25. PMID: 1260699. KQ2E6.1260699
288 Wasim T, Majrroh A, Siddiq S. Comparison of clinical presentation of benign and malignant ovarian tumours. J Pak Med Assoc. 2009;59(1):18-21. PMID: 19213371. KQ2E3a.19213371
289 Watson-Johnson L, JS T, Basile K, . Cancer screening and history of sexual violence victimization among U.S. adults. J Womens Health (Larchmt). 2012;21(1):17-25. PMID: 22011207 KQ3E6.22011207
290 Webb R, Opdahl M. Breast and pelvic examinations: easing women's discomfort. Can Fam Physician. 1996;42:54-8. PMID: 8924814. KQ3E5.8924814
291 Weerakiet S, Wongkularb A, Rochanawutanon M, . Transvaginal ultrasonography combined with pelvic examination in the diagnosis of ovarian endometrioma. J Med Assoc Thai. 2000;83(5):523-8. PMID: 10863898. KQ2E4a.10863898
292 Weiss L, Meadow R. Women's attitudes toward gynecologic practices. Obstet Gynecol. 1979;54(1):110-4. PMID: 450352. KQ3E5b.450352
293 Weissfeld JL, Fagerstrom RM, O'Brien B, . Quality control of cancer screening examination procedures in the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial. Control Clin Trials. 2000;21(6 Suppl):390S-9S. PMID: 11189690. KQ1E6, KQ2E6, KQ3E6.11189690
294 Weitlauf JC, Finney JW, Ruzek JI, . Distress and pain during pelvic examinations: effect of sexual violence. Obstet Gynecol. 2008;112(6):1343-50. PMID: 19037045. KQ3E2b.19037045
295 Weitlauf JC, Frayne SM, Finney JW, . Sexual violence, posttraumatic stress disorder, and the pelvic examination: how do beliefs about the safety, necessity, and utility of the examination influence patient experiences? J Womens Health (Larchmt). 2010;19(7):1271-80. PMID: 20509787. KQ3E2b.20509787
296 Wijma B, Gullberg M, Kjessler B. Attitudes towards pelvic examination in a random sample of Swedish women. Acta Obstet Gynecol Scand. 1998;77(4):422-8. PMID: 9598951. KQ3E2b.9598951
297 Willard MD, Heaberg GL, Pack JB. The educational pelvic examination. Women's responses to a new approach. J Obstet Gynecol Neonatal Nurs. 1986;15(2):135-40. PMID: 3634793. KQ3E2.3634793
298 Williams JG, Park LI, Kline J. Reducing distress associated with pelvic examinations: a replication. Women Health. 1992;19(2-3):107-15. PMID: 1345040 KQ3E4.1345040
299 Willis FL, Fanning J. Digital rectal fecal occult blood screening during gynecologic examination. Am J Obstet Gynecol. 2004;190(5):1422-3. PMID: 15167856. KQ2E6.15167856
300 Willson JR. Ultrasonography in the diagnosis of gynecologic disorders. Am J Obstet Gynecol. 1991;164(4):1064-7;discussion 7-71. PMID: 2014827. KQ2E2.2014827
301 Woodman R. Ovarian cancer screening may increase survival. BMJ. 1999;318(7190):1027a. PMID: 10205091. KQ1E2, KQ2E2, KQ3E2.10205090
302 Yanikkerem E, Ozdemir M, Bingol H, . Women's attitudes and expectations regarding gynaecological examination. Midwifery. 2009;25(5):500-8. PMID: 18086509. KQ3E3a.18086509
303 Yen S, Shafer MA, Moncada J, . Bacterial vaginosis in sexually experienced and non-sexually experienced young women entering the military. Obstet Gynecol. 2003;102(5 Pt 1):927-33. PMID: 14672465. KQ2E6.14672465
304 Yu C, Rymer J. Women's attitudes to and awareness of smear testing and cervical cancer. Br J Fam Plann. 1998;23(4):127-33. PMID: 9882766. KQ3E6.9882766
305 Zarcone R, Bellini P, Carfora E, . Role of ultrasonography in the early diagnosis of ovarian cancer. Eur J Gynaecol Oncol. 1997;18(5):418-9. PMID: 9378167. KQ2E6.9378167
306 Zurawski VR, Jr., Sjovall K, Schoenfeld DA, . Prospective evaluation of serum CA 125 levels in a normal population, phase I: the specificities of single and serial determinations in testing for ovarian cancer. Gynecol Oncol. 1990;36(3):299-305. PMID: 2318438. KQ2E22318438