# References

1 Balk EM, Moorthy D, Obadan NO, et al. (2011). Diagnosis and Treatment of Obstructive Sleep Apnea in Adults.
2 Centers for Medicare & Medicaid Services. National Coverage Determination (NCD) for Continuous Positive Airway Pressure (CPAP) Therapy for Obstructive Sleep Apnea (OSA) (240.4).
3 American Academy of Sleep Medicine. (2005). Diagnostic and Coding Manual.
4 Lowe AA, Ono T, Ferguson KA, et al. (1996). Cephalometric comparisons of craniofacial and upper airway structure by skeletal subtype and gender in patients with obstructive sleep apnea. Am J Orthod Dentofacial Orthop.
5 Victor LD. (1999). Obstructive sleep apnea. Am Fam Physician.
6 Horner RL, Mohiaddin RH, Lowell DG, et al. (1989). Sites and sizes of fat deposits around the pharynx in obese patients with obstructive sleep apnoea and weight matched controls. Eur Respir J.
7 Peppard PE, Young T, Palta M, et al. (2000). Longitudinal study of moderate weight change and sleep-disordered breathing. JAMA.
8 Myers KA, Mrkobrada M, Simel DL. (2013). Does this patient have obstructive sleep apnea? The Rational Clinical Examination systematic review. JAMA.
9 Duran J, Esnaola S, Rubio R, et al. (2001). Obstructive sleep apnea-hypopnea and related clinical features in a population-based sample of subjects aged 30 to 70 yr. Am J Respir Crit Care Med.
10 Newman AB, Foster G, Givelber R, et al. (2005). Progression and regression of sleep-disordered breathing with changes in weight: the Sleep Heart Health Study. Arch Intern Med.
11 Young T, Peppard PE, Taheri S. (2005). Excess weight and sleep-disordered breathing. J Appl Physiol (1985).
12 Somers VK, White DP, Amin R, et al. (2008). Sleep apnea and cardiovascular disease: an American Heart Association/american College Of Cardiology Foundation Scientific Statement from the American Heart Association Council for High Blood Pressure Research Professional Education Committee, Council on Clinical Cardiology, Stroke Council, and Council On Cardiovascular Nursing. In collaboration with the National Heart, Lung, and Blood Institute National Center on Sleep Disorders Research (National Institutes of Health). Circulation.
13 Young T, Peppard PE, Gottlieb DJ. (2002). Epidemiology of obstructive sleep apnea: a population health perspective. Am J Respir Crit Care Med.
14 Young T, Shahar E, Nieto FJ, et al. (2002). Predictors of sleep-disordered breathing in community-dwelling adults: the Sleep Heart Health Study. Arch Intern Med.
15 Young T, Palta M, Dempsey J, et al. (1993). The occurrence of sleep-disordered breathing among middle-aged adults. N Engl J Med.
16 Bixler EO, Vgontzas AN, Ten Have T, et al. (1998). Effects of age on sleep apnea in men: I. Prevalence and severity. Am J Respir Crit Care Med.
17 Bixler EO, Vgontzas AN, Lin HM, et al. (2001). Prevalence of sleep-disordered breathing in women: effects of gender. Am J Respir Crit Care Med.
18 Tishler PV, Larkin EK, Schluchter MD, et al. (2003). Incidence of sleep-disordered breathing in an urban adult population: the relative importance of risk factors in the development of sleep-disordered breathing. JAMA.
19 Banhiran W, Junlapan A, Assanasen P, et al. (2014). Physical predictors for moderate to severe obstructive sleep apnea in snoring patients. Sleep Breath.
20 White DP, Younes MK. (2012). Obstructive sleep apnea. Compr Physiol.
21 Gungor AY, Turkkahraman H, Yilmaz HH, et al. (2013). Cephalometric comparison of obstructive sleep apnea patients and healthy controls. Eur J Dent.
22 Young T, Finn L, Austin D, et al. (2003). Menopausal status and sleep-disordered breathing in the Wisconsin Sleep Cohort Study. Am J Respir Crit Care Med.
23 Wetter DW, Young TB, Bidwell TR, et al. (1994). Smoking as a risk factor for sleep-disordered breathing. Arch Intern Med.
24 Kashyap R, Hock LM, Bowman TJ. (2001). Higher prevalence of smoking in patients diagnosed as having obstructive sleep apnea. Sleep Breath.
25 Hoflstein V. (2002). Relationship between smoking and sleep apnea in clinic population. Sleep.
26 Conway SG, Roizenblatt SS, Palombini L, et al. (2008). Effect of smoking habits on sleep. Braz J Med Biol Res.
27 Peppard PE, Austin D, Brown RL. (2007). Association of alcohol consumption and sleep disordered breathing in men and women. J Clin Sleep Med.
28 Kang K, Seo JG, Seo SH, et al. (2014). Prevalence and related factors for high-risk of obstructive sleep apnea in a large korean population: results of a questionnaire-based study. J Clin Neurol.
29 Scanlan MF, Roebuck T, Little PJ, et al. (2000). Effect of moderate alcohol upon obstructive sleep apnoea. Eur Respir J.
30 Lofaso F, Coste A, d'Ortho MP, et al. (2000). Nasal obstruction as a risk factor for sleep apnoea syndrome. Eur Respir J.
31 Caples SM, Gami AS, Somers VK. (2005). Obstructive sleep apnea. Ann Intern Med.
32 Bixler EO, Vgontzas AN, Lin HM, et al. (2000). Association of hypertension and sleep-disordered breathing. Arch Intern Med.
33 Peppard PE, Young T, Barnet JH, et al. (2013). Increased prevalence of sleep-disordered breathing in adults. Am J Epidemiol.
34 Young T, Palta M, Dempsey J, et al. (2009). Burden of sleep apnea: rationale, design, and major findings of the Wisconsin Sleep Cohort study. WMJ.
35 Young T, Skatrud J, Peppard PE. (2004). Risk factors for obstructive sleep apnea in adults. JAMA.
36 Horstmann S, Hess CW, Bassetti C, et al. (2000). Sleepiness-related accidents in sleep apnea patients. Sleep.
37 Young T, Blustein J, Finn L, et al. (1997). Sleep-disordered breathing and motor vehicle accidents in a population-based sample of employed adults. Sleep.
38 Wu H, Yan-Go F. (1996). Self-reported automobile accidents involving patients with obstructive sleep apnea. Neurology.
39 Teran-Santos J, Jimenez-Gomez A, Cordero-Guevara J. (1999). The association between sleep apnea and the risk of traffic accidents. Cooperative Group Burgos-Santander. N Engl J Med.
40 George CF, Nickerson PW, Hanly PJ, et al. (1987). Sleep apnoea patients have more automobile accidents. Lancet.
41 Findley LJ, Unverzagt ME, Suratt PM. (1988). Automobile accidents involving patients with obstructive sleep apnea. Am Rev Respir Dis.
42 George CF, Smiley A. (1999). Sleep apnea and automobile crashes. Sleep.
43 Quan SF, Wright R, Baldwin CM, et al. (2006). Obstructive sleep apnea-hypopnea and neurocognitive functioning in the Sleep Heart Health Study. Sleep Med.
44 Sjosten N, Vahtera J, Salo P, et al. (2009). Increased risk of lost workdays prior to the diagnosis of sleep apnea. Chest.
45 Omachi TA, Claman DM, Blanc PD, et al. (2009). Obstructive sleep apnea: a risk factor for work disability. Sleep.
46 Accattoli MP, Muzi G, dell'Omo M, et al. (2008). G Ital Med Lav Ergon.
47 Moyer CA, Sonnad SS, Garetz SL, et al. (2001). Quality of life in obstructive sleep apnea: a systematic review of the literature. Sleep Med.
48 Yeboah J, Redline S, Johnson C, et al. (2011). Association between sleep apnea, snoring, incident cardiovascular events and all-cause mortality in an adult population: MESA. Atherosclerosis.
49 Shahar E, Whitney CW, Redline S, et al. (2001). Sleep-disordered breathing and cardiovascular disease: cross-sectional results of the Sleep Heart Health Study. Am J Respir Crit Care Med.
50 Marin JM, Carrizo SJ, Vicente E, et al. (2005). Long-term cardiovascular outcomes in men with obstructive sleep apnoea-hypopnoea with or without treatment with continuous positive airway pressure: an observational study. Lancet.
51 Javaheri S, Parker TJ, Liming JD, et al. (1998). Sleep apnea in 81 ambulatory male patients with stable heart failure. Types and their prevalences, consequences, and presentations. Circulation.
52 Le Jemtel TH, Jelic S. (2007). Seek and treat obstructive sleep apnea in heart failure. J Am Coll Cardiol.
53 Sin DD, Fitzgerald F, Parker JD, et al. (1999). Risk factors for central and obstructive sleep apnea in 450 men and women with congestive heart failure. Am J Respir Crit Care Med.
54 Ferrier K, Campbell A, Yee B, et al. (2005). Sleep-disordered breathing occurs frequently in stable outpatients with congestive heart failure. Chest.
55 Schafer H, Koehler U, Ewig S, et al. (1999). Obstructive sleep apnea as a risk marker in coronary artery disease. Cardiology.
56 Phillips BG, Somers VK. (2002). Sleep disordered breathing and risk factors for cardiovascular disease. Curr Opin Pulm Med.
57 Sanner BM, Konermann M, Doberauer C, et al. (2001). Sleep-Disordered breathing in patients referred for angina evaluation--association with left ventricular dysfunction. Clin Cardiol.
58 Gami AS, Pressman G, Caples SM, et al. (2004). Association of atrial fibrillation and obstructive sleep apnea. Circulation.
59 Yaggi HK, Concato J, Kernan WN, et al. (2005). Obstructive sleep apnea as a risk factor for stroke and death. N Engl J Med.
60 Sjostrom C, Lindberg E, Elmasry A, et al. (2002). Prevalence of sleep apnoea and snoring in hypertensive men: a population based study. Thorax.
61 Ruttanaumpawan P, Nopmaneejumruslers C, Logan AG, et al. (2009). Association between refractory hypertension and obstructive sleep apnea. J Hypertens.
62 Nieto FJ, Young TB, Lind BK, et al. (2000). Association of sleep-disordered breathing, sleep apnea, and hypertension in a large community-based study. Sleep Heart Health Study. JAMA.
63 Richert A, Ansarin K, Baran AS. (2002). Sleep apnea and hypertension: pathophysiologic mechanisms. Semin Nephrol.
64 Punjabi NM, Shahar E, Redline S, et al. (2004). Sleep-disordered breathing, glucose intolerance, and insulin resistance: the Sleep Heart Health Study. Am J Epidemiol.
65 Vgontzas AN, Bixler EO, Chrousos GP. (2003). Metabolic disturbances in obesity versus sleep apnoea: the importance of visceral obesity and insulin resistance. J Intern Med.
66 Shaw JE, Punjabi NM, Wilding JP, et al. (2008). Sleep-disordered breathing and type 2 diabetes: a report from the International Diabetes Federation Taskforce on Epidemiology and Prevention. Diabetes Res Clin Pract.
67 Einhorn D, Stewart DA, Erman MK, et al. (2007). Prevalence of sleep apnea in a population of adults with type 2 diabetes mellitus. Endocr Pract.
68 Johns MW. (1991). A new method for measuring daytime sleepiness: the Epworth Sleepiness Scale. Sleep.
69 Chung F, Yegneswaran B, Liao P, et al. (2008). STOP questionnaire: a tool to screen patients for obstructive sleep apnea. Anesthesiology.
70 Chung F, Subramanyam R, Liao P, et al. (2012). High STOP-Bang score indicates a high probability of obstructive sleep apnoea. Br J Anaesth.
71 Netzer NC, Stoohs RA, Netzer CM, et al. (1999). Using the Berlin Questionnaire to identify patients at risk for the sleep apnea syndrome. Ann Intern Med.
72 Kushida CA, Littner MR, Morgenthaler T, et al. (2005). Practice parameters for the indications for polysomnography and related procedures: an update for 2005. Sleep.
73 Iber C, Ancoli-Israel S, Chesson AL, et al. (2007). The AASM manual for the scoring of sleep and associated events: rules, terminology and technical specifications.
74 Collop NA, Anderson WM, Boehlecke B, et al. (2007). Clinical guidelines for the use of unattended portable monitors in the diagnosis of obstructive sleep apnea in adult patients. Portable Monitoring Task Force of the American Academy of Sleep Medicine. J Clin Sleep Med.
75 Trikalinos TA, Ip S, Raman G, et al. (2007). Home Diagnosis of Obstructive Sleep Apnea-Hypopnea Syndrome.
76 Qaseem A, Holty JE, Owens DK, et al. (2013). Management of obstructive sleep apnea in adults: a clinical practice guideline from the American College of Physicians. Ann Intern Med.
77 Lettieri CJ, Eliasson AH, Greenburg DL. (2008). Persistence of obstructive sleep apnea after surgical weight loss. J Clin Sleep Med.
78 Randerath WJ, Verbraecken J, Andreas S, et al. (2011). Non-CPAP therapies in obstructive sleep apnoea. Eur Respir J.
79 Buchwald H, Avidor Y, Braunwald E, et al. (2004). Bariatric surgery: a systematic review and meta-analysis. JAMA.
80 Javaheri S, Caref EB, Chen E, et al. (2011). Sleep apnea testing and outcomes in a large cohort of Medicare beneficiaries with newly diagnosed heart failure. Am J Respir Crit Care Med.
81 Kezirian EJ, Maselli J, Vittinghoff E, et al. (2010). Obstructive sleep apnea surgery practice patterns in the United States: 2000 to 2006. Otolaryngol Head Neck Surg.
82 Mold JW, Quattlebaum C, Schinnerer E, et al. (2011). Identification by primary care clinicians of patients with obstructive sleep apnea: a practice-based research network (PBRN) study. J Am Board Fam Med.
83 Kramer NR, Cook TE, Carlisle CC, et al. (1999). The role of the primary care physician in recognizing obstructive sleep apnea. Arch Intern Med.
84 Palmer EL, Wingfield D, Jamrozik K, et al. (2005). A pilot study to assess the possible methods of determining the burden of obstructive sleep apnoea syndrome in primary care. Prim Care Respir J.
85 Senthilvel E, Auckley D, Dasarathy J. (2011). Evaluation of sleep disorders in the primary care setting: history taking compared to questionnaires. J Clin Sleep Med.
86 Grover M, Mookadam M, Armas D, et al. (2011). Identifying patients at risk for obstructive sleep apnea in a primary care practice. J Am Board Fam Med.
87 Chung SA, Jairam S, Hussain MR, et al. (2001). Knowledge of sleep apnea in a sample grouping of primary care physicians. Sleep Breath.
88 Reuveni H, Tarasiuk A, Wainstock T, et al. (2004). Awareness level of obstructive sleep apnea syndrome during routine unstructured interviews of a standardized patient by primary care physicians. Sleep.
89 Papp KK, Penrod CE, Strohl KP. (2002). Knowledge and attitudes of primary care physicians toward sleep and sleep disorders. Sleep Breath.
90 Hayes SM, Murray S, Castriotta RJ, et al. (2012). (Mis) perceptions and interactions of sleep specialists and generalists: obstacles to referrals to sleep specialists and the multidisciplinary team management of sleep disorders. J Clin Sleep Med.
91 Ge X, Han F, Huang Y, et al. (2013). Is obstructive sleep apnea associated with cardiovascular and all-cause mortality?. PLoS One.
92 Kendzerska T, Mollayeva T, Gershon AS, et al. (2014). Untreated obstructive sleep apnea and the risk for serious long-term adverse outcomes: a systematic review. Sleep Med Rev.
93 Harris RP, Helfand M, Woolf SH, et al. (2001). Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med.
94 West SL, Gartlehner G, Mansfield AJ, et al. (2010). Comparative Effectiveness Review Methods: Clinical Heterogeneity.
95 Deeks JJ, Altman DG. (2004). Statistics notes - Diagnostic tests 4: likelihood ratios. Brit Med J.
96 Guyatt G, Rennie D, Jaeschke R, et al. (2002). Diagnostic tests. Guyatt G, Rennie D, editors. Users' guides to the medical literature.
97 Nyaga VN, Arbyn M, Aerts M. (2014). Metaprop: a Stata command to perform meta-analysis of binomial data. Arch Public Health.
98 Cohen J. (1988). Statistical Power Analysis for the Behavioral Sciences.
99 Higgins JP, Thompson SG. (2002). Quantifying heterogeneity in a meta-analysis. Stat Med.
100 Higgins JP, Thompson SG, Deeks JJ, et al. (2003). Measuring inconsistency in meta-analyses. BMJ.
101 Higgins JPT, Green S. (2011). Cochrane Handbook for Systematic Reviews of Interventions: The Cochrane Collaboration.
102 Hrubos-Strom H, Randby A, Namtvedt SK, et al. (2011). A Norwegian population-based study on the risk and prevalence of obstructive sleep apnea. The Akershus Sleep Apnea Project (ASAP). J Sleep Res.
103 Morales CR, Hurley S, Wick LC, et al. (2012). In-home, self-assembled sleep studies are useful in diagnosing sleep apnea in the elderly. Sleep.
104 Gurubhagavatula I, Fields BG, Morales CR, et al. (2013). Screening for severe obstructive sleep apnea syndrome in hypertensive outpatients. J Clin Hypertens (Greenwich).
105 Gurubhagavatula I, Maislin G, Nkwuo JE, et al. (2004). Occupational screening for obstructive sleep apnea in commercial drivers. Am J Respir Crit Care Med.
106 Maislin G, Pack AI, Kribbs NB, et al. (1995). A survey screen for prediction of apnea. Sleep.
107 Lloyd-Jones DM. (2010). Cardiovascular risk prediction: basic concepts, current status, and future directions. Circulation.
108 Hosmer DW, Lemeshow S. (2000). Applied Logistic Regression.
109 Ferre A, Sampol G, Jurado MJ, et al. (2012). Neurophysiological two-channel polysomnographic device in the diagnosis of sleep apnea. J Clin Sleep Med.
110 Bruyneel M, Sanida C, Art G, et al. (2011). Sleep efficiency during sleep studies: results of a prospective study comparing home-based and in-hospital polysomnography. J Sleep Res.
111 Campbell AJ, Neill AM. (2011). Home set-up polysomnography in the assessment of suspected obstructive sleep apnea. J Sleep Res.
112 El Shayeb M, Topfer LA, Stafinski T, et al. (2014). Diagnostic accuracy of level 3 portable sleep tests versus level 1 polysomnography for sleep-disordered breathing: a systematic review and meta-analysis. CMAJ.
113 Guerrero A, Embid C, Isetta V, et al. (2014). Management of sleep apnea without high pretest probability or with comorbidities by three nights of portable sleep monitoring. Sleep.
114 Pereira EJ, Driver HS, Stewart SC, et al. (2013). Comparing a combination of validated questionnaires and level III portable monitor with polysomnography to diagnose and exclude sleep apnea. J Clin Sleep Med.
115 Barak-Shinar D, Amos Y, Bogan RK. (2013). Sleep disordered breathing analysis in a general population using standard pulse oximeter signals. Sleep Breath.
116 Morillo DS, Gross N. (2013). Probabilistic neural network approach for the detection of SAHS from overnight pulse oximetry. Med Biol Eng Comput.
117 Nigro CA, Dibur E, Malnis S, et al. (2013). Validation of ApneaLink Ox for the diagnosis of obstructive sleep apnea. Sleep Breath.
118 Alvarez D, Hornero R, Marcos JV, et al. (2012). Feature selection from nocturnal oximetry using genetic algorithms to assist in obstructive sleep apnoea diagnosis. Med Eng Phys.
119 Masa JF, Corral J, Pereira R, et al. (2011). Effectiveness of home respiratory polygraphy for the diagnosis of sleep apnoea and hypopnoea syndrome. Thorax.
120 Poupard L, Philippe C, Goldman MD, et al. (2012). Novel mathematical processing method of nocturnal oximetry for screening patients with suspected sleep apnoea syndrome. Sleep Breath.
121 Bohning N, Zucchini W, Horstmeier O, et al. (2011). Sensitivity and specificity of telemedicine-based long-term pulse-oximetry in comparison with cardiorespiratory polygraphy and polysomnography in patients with obstructive sleep apnoea syndrome. J Telemed Telecare.
122 Rofail LM, Wong KK, Unger G, et al. (2010). Comparison between a single-channel nasal airflow device and oximetry for the diagnosis of obstructive sleep apnea. Sleep.
123 Yadollahi A, Giannouli E, Moussavi Z. (2010). Sleep apnea monitoring and diagnosis based on pulse oximetry and tracheal sound signals. Med Biol Eng Comput.
124 Nigro CA, Serrano F, Aimaretti S, et al. (2010). Utility of ApneaLink for the diagnosis of sleep apnea-hypopnea syndrome. Medicina (B Aires).
125 Choi JH, Kim EJ, Kim YS, et al. (2010). Validation study of portable device for the diagnosis of obstructive sleep apnea according to the new AASM scoring criteria: Watch-PAT 100. Acta Otolaryngol.
126 Alvarez D, Hornero R, Abasolo D, et al. (2009). Nonlinear measure of synchrony between blood oxygen saturation and heart rate from nocturnal pulse oximetry in obstructive sleep apnoea syndrome. Physiol Meas.
127 Garg N, Rolle AJ, Lee TA, et al. (2014). Home-based diagnosis of obstructive sleep apnea in an urban population. J Clin Sleep Med.
128 Arias MA, Garcia-Rio F, Alonso-Fernandez A, et al. (2005). Obstructive sleep apnea syndrome affects left ventricular diastolic function: effects of nasal continuous positive airway pressure in men. Circulation.
129 Arias MA, García-Río F, Alonso-Fernández A, et al. (2008). CPAP decreases plasma levels of soluble tumour necrosis factor-alpha receptor 1 in obstructive sleep apnoea. Eur Respir J.
130 Barbe F, Mayoralas LR, Duran J, et al. (2001). Treatment with continuous positive airway pressure is not effective in patients with sleep apnea but no daytime sleepiness. a randomized, controlled trial. Ann Intern Med.
131 Bardwell WA, Norman D, Ancoli-Israel S, et al. (2007). Effects of 2-week nocturnal oxygen supplementation and continuous positive airway pressure treatment on psychological symptoms in patients with obstructive sleep apnea: a randomized placebo-controlled study. Behav Sleep Med.
132 Campos-Rodriguez F, Grilo-Reina A, Perez-Ronchel J, et al. (2006). Effect of continuous positive airway pressure on ambulatory BP in patients with sleep apnea and hypertension: a placebo-controlled trial. Chest.
133 Chasens ER, Korytkowski M, Sereika SM, et al. (2014). Improving activity in adults with diabetes and coexisting obstructive sleep apnea. West J Nurs Res.
134 Chong MS, Ayalon L, Marler M, et al. (2006). Continuous positive airway pressure reduces subjective daytime sleepiness in patients with mild to moderate Alzheimer's disease with sleep disordered breathing. J Am Geriatr Soc.
135 Coughlin SR, Mawdsley L, Mugarza JA, et al. (2007). Cardiovascular and metabolic effects of CPAP in obese males with OSA. Eur Respir J.
136 Cross MD, Mills NL, Al-Abri M, et al. (2008). Continuous positive airway pressure improves vascular function in obstructive sleep apnoea/hypopnoea syndrome: a randomised controlled trial. Thorax.
137 Duran-Cantolla J, Aizpuru F, Montserrat JM, et al. (2010). Continuous positive airway pressure as treatment for systemic hypertension in people with obstructive sleep apnoea: randomised controlled trial. BMJ.
138 Egea CJ, Aizpuru F, Pinto JA, et al. (2008). Cardiac function after CPAP therapy in patients with chronic heart failure and sleep apnea: a multicenter study. Sleep Med.
139 Haensel A, Norman D, Natarajan L, et al. (2007). Effect of a 2 week CPAP treatment on mood states in patients with obstructive sleep apnea: a double-blind trial. Sleep Breath.
140 Hoyos CM, Killick R, Yee BJ, et al. (2012). Cardiometabolic changes after continuous positive airway pressure for obstructive sleep apnoea: a randomised sham-controlled study. Thorax.
141 Hui DS, To KW, Ko FW, et al. (2006). Nasal CPAP reduces systemic blood pressure in patients with obstructive sleep apnoea and mild sleepiness. Thorax.
142 Jenkinson C, Davies RJ, Mullins R, et al. (1999). Comparison of therapeutic and subtherapeutic nasal continuous positive airway pressure for obstructive sleep apnoea: a randomised prospective parallel trial. Lancet.
143 Hack M, Davies RJ, Mullins R, et al. (2000). Randomised prospective parallel trial of therapeutic versus subtherapeutic nasal continuous positive airway pressure on simulated steering performance in patients with obstructive sleep apnoea. Thorax.
144 Jones A, Vennelle M, Connell M, et al. (2013). The effect of continuous positive airway pressure therapy on arterial stiffness and endothelial function in obstructive sleep apnea: a randomized controlled trial in patients without cardiovascular disease. Sleep Med.
145 Kushida CA, Nichols DA, Holmes TH, et al. (2012). Effects of continuous positive airway pressure on neurocognitive function in obstructive sleep apnea patients: The Apnea Positive Pressure Long-term Efficacy Study (APPLES). Sleep.
146 Lam JC, Lam B, Yao TJ, et al. (2010). A randomised controlled trial of nasal continuous positive airway pressure on insulin sensitivity in obstructive sleep apnoea. Eur Respir J.
147 Lee IS, Bardwell WA, Kamat R, et al. (2011). A model for studying neuropsychological effects of sleep intervention: the effect of 3-week continuous positive airway pressure treatment. Drug Discov Today Dis Models.
148 Loredo JS, Ancoli-Israel S, Dimsdale JE. (1999). Effect of continuous positive airway pressure vs placebo continuous positive airway pressure on sleep quality in obstructive sleep apnea. Chest.
149 Loredo JS, Ancoli-Israel S, Kim EJ, et al. (2006). Effect of continuous positive airway pressure versus supplemental oxygen on sleep quality in obstructive sleep apnea: a placebo-CPAP-controlled study. Sleep.
150 Malow BA, Foldvary-Schaefer N, Vaughn BV, et al. (2008). Treating obstructive sleep apnea in adults with epilepsy: a randomized pilot trial. Neurology.
151 Marshall NS, Neill AM, Campbell AJ, et al. (2005). Randomised controlled crossover trial of humidified continuous positive airway pressure in mild obstructive sleep apnoea. Thorax.
152 McArdle N, Douglas NJ. (2001). Effect of continuous positive airway pressure on sleep architecture in the sleep apnea-hypopnea syndrome: a randomized controlled trial. Am J Respir Crit Care Med.
153 Mills PJ, Kennedy BP, Loredo JS, et al. (2006). Effects of nasal continuous positive airway pressure and oxygen supplementation on norepinephrine kinetics and cardiovascular responses in obstructive sleep apnea. J Appl Physiol (1985).
154 Montserrat JM, Ferrer M, Hernandez L, et al. (2001). Effectiveness of CPAP treatment in daytime function in sleep apnea syndrome: a randomized controlled study with an optimized placebo. Am J Respir Crit Care Med.
155 Neikrug AB, Liu L, Avanzino JA, et al. (2014). Continuous positive airway pressure improves sleep and daytime sleepiness in patients with Parkinson disease and sleep apnea. Sleep.
156 Norman D, Loredo JS, Nelesen RA, et al. (2006). Effects of continuous positive airway pressure versus supplemental oxygen on 24-hour ambulatory blood pressure. Hypertension.
157 Nguyen PK, Katikireddy CK, McConnell MV, et al. (2010). Nasal continuous positive airway pressure improves myocardial perfusion reserve and endothelial-dependent vasodilation in patients with obstructive sleep apnea. J Cardiovasc Magn Reson.
158 Pamidi S, Wroblewski K, Stepien M, et al. (2015). Eight hours of nightly continuous positive airway pressure treatment of obstructive sleep apnea improves glucose metabolism in patients with prediabetes. a randomized controlled trial. Am J Respir Crit Care Med.
159 Pepperell JC, Ramdassingh-Dow S, Crosthwaite N, et al. (2002). Ambulatory blood pressure after therapeutic and subtherapeutic nasal continuous positive airway pressure for obstructive sleep apnoea: a randomised parallel trial. Lancet.
160 Kohler M, Pepperell JC, Casadei B, et al. (2008). CPAP and measures of cardiovascular risk in males with OSAS. Eur Resp J.
161 Phillips CL, Yee BJ, Marshall NS, et al. (2011). Continuous positive airway pressure reduces postprandial lipidemia in obstructive sleep apnea: a randomized, placebo-controlled crossover trial. Am J Respir Crit Care Med.
162 Robinson GV, Smith DM, Langford BA, et al. (2006). Continuous positive airway pressure does not reduce blood pressure in nonsleepy hypertensive OSA patients. Eur Respir J.
163 Smith LA, Vennelle M, Gardner RS, et al. (2007). Auto-titrating continuous positive airway pressure therapy in patients with chronic heart failure and obstructive sleep apnoea: a randomized placebo-controlled trial. Eur Heart J.
164 Siccoli MM, Pepperell JC, Kohler M, et al. (2008). Effects of continuous positive airway pressure on quality of life in patients with moderate to severe obstructive sleep apnea: data from a randomized controlled trial. Sleep.
165 Toukh M, Pereira EJ, Falcon BJ, et al. (2012). CPAP reduces hypercoagulability, as assessed by thromboelastography, in severe obstructive sleep apnoea. Respir Physiol Neurobiol.
166 Weaver TE, Mancini C, Maislin G, et al. (2012). Continuous positive airway pressure treatment of sleepy patients with milder obstructive sleep apnea: results of the CPAP Apnea Trial North American Program (CATNAP) randomized clinical trial. Am J Respir Crit Care Med.
167 Weinstock TG, Wang X, Rueschman M, et al. (2012). A controlled trial of CPAP therapy on metabolic control in individuals with impaired glucose tolerance and sleep apnea. Sleep.
168 West SD, Nicoll DJ, Wallace TM, et al. (2007). Effect of CPAP on insulin resistance and HbA1c in men with obstructive sleep apnoea and type 2 diabetes. Thorax.
169 West SD, Kohler M, Nicoll DJ, et al. (2009). The effect of continuous positive airway pressure treatment on physical activity in patients with obstructive sleep apnoea: A randomised controlled trial. Sleep Med.
170 Ballester E, Badia JR, Hernandez L, et al. (1999). Evidence of the effectiveness of continuous positive airway pressure in the treatment of sleep apnea/hypopnea syndrome. Am J Respir Crit Care Med.
171 Barbe F, Duran-Cantolla J, Capote F, et al. (2010). Long-term effect of continuous positive airway pressure in hypertensive patients with sleep apnea. Am J Respir Crit Care Med.
172 Barbe F, Duran-Cantolla J, Sanchez-de-la-Torre M, et al. (2012). Effect of continuous positive airway pressure on the incidence of hypertension and cardiovascular events in nonsleepy patients with obstructive sleep apnea: a randomized controlled trial. JAMA.
173 Barnes M, McEvoy RD, Banks S, et al. (2004). Efficacy of positive airway pressure and oral appliance in mild to moderate obstructive sleep apnea. Am J Respir Crit Care Med.
174 Craig SE, Kohler M, Nicoll D, et al. (2012). Continuous positive airway pressure improves sleepiness but not calculated vascular risk in patients with minimally symptomatic obstructive sleep apnoea: the MOSAIC randomised controlled trial. Thorax.
175 Engleman HM, Martin SE, Kingshott RN, et al. (1998). Randomised placebo controlled trial of daytime function after continuous positive airway pressure (CPAP) therapy for the sleep apnoea/hypopnoea syndrome. Thorax.
176 Engleman HM, Kingshott RN, Wraith PK, et al. (1999). Randomized placebo-controlled crossover trial of continuous positive airway pressure for mild sleep Apnea/Hypopnea syndrome. Am J Respir Crit Care Med.
177 Faccenda JF, Mackay TW, Boon NA, et al. (2001). Randomized placebo-controlled trial of continuous positive airway pressure on blood pressure in the sleep apnea-hypopnea syndrome. Am J Respir Crit Care Med.
178 Gottlieb DJ, Punjabi NM, Mehra R, et al. (2014). CPAP versus oxygen in obstructive sleep apnea. N Engl J Med.
179 Ip MS, Tse HF, Lam B, et al. (2004). Endothelial function in obstructive sleep apnea and response to treatment. Am J Respir Crit Care Med.
180 Lam B, Sam K, Mok WY, et al. (2007). Randomised study of three non-surgical treatments in mild to moderate obstructive sleep apnoea. Thorax.
181 Martinez-Garcia MA, Capote F, Campos-Rodriguez F, et al. (2013). Effect of CPAP on blood pressure in patients with obstructive sleep apnea and resistant hypertension: the HIPARCO randomized clinical trial. JAMA.
182 McMillan A, Bratton DJ, Faria R, et al. (2014). Continuous positive airway pressure in older people with obstructive sleep apnoea syndrome (PREDICT): a 12-month, multicentre, randomised trial. Lancet Respir Med.
183 Redline S, Adams N, Strauss ME, et al. (1998). Improvement of mild sleep-disordered breathing with CPAP compared with conservative therapy. Am J Respir Crit Care Med.
184 Ruttanaumpawan P, Gilman MP, Usui K, et al. (2008). Sustained effect of continuous positive airway pressure on baroreflex sensitivity in congestive heart failure patients with obstructive sleep apnea. J Hypertens.
185 Kaneko Y, Floras JS, Usui K, et al. (2003). Cardiovascular effects of continuous positive airway pressure in patients with heart failure and obstructive sleep apnea. N Engl J Med.
186 Tomfohr LM, Ancoli-Israel S, Loredo JS, et al. (2011). Effects of continuous positive airway pressure on fatigue and sleepiness in patients with obstructive sleep apnea: data from a randomized controlled trial. Sleep.
187 Usui K, Bradley TD, Spaak J, et al. (2005). Inhibition of awake sympathetic nerve activity of heart failure patients with obstructive sleep apnea by nocturnal continuous positive airway pressure. J Am Coll Cardiol.
188 Andren A, Hedberg P, Walker-Engstrom ML, et al. (2013). Effects of treatment with oral appliance on 24-h blood pressure in patients with obstructive sleep apnea and hypertension: a randomized clinical trial. Sleep Breath.
189 Aarab G, Lobbezoo F, Hamburger HL, et al. (2011). Oral appliance therapy versus nasal continuous positive airway pressure in obstructive sleep apnea: a randomized, placebo-controlled trial. Respiration.
190 Durán-Cantolla J, Crovetto-Martínez R, Alkhraisat MH, et al. (2015). Efficacy of mandibular advancement device in the treatment of obstructive sleep apnea syndrome: a randomized controlled crossover clinical trial. Med Oral Patol Oral Cir Bucal.
191 Petri N, Svanholt P, Solow B, et al. (2008). Mandibular advancement appliance for obstructive sleep apnoea: results of a randomised placebo controlled trial using parallel group design. J Sleep Res.
192 Naismith SL, Winter VR, Hickie IB, et al. (2005). Effect of oral appliance therapy on neurobehavioral functioning in obstructive sleep apnea: a randomized controlled trial. J Clin Sleep Med.
193 Gotsopoulos H, Chen C, Qian J, et al. (2002). Oral appliance therapy improves symptoms in obstructive sleep apnea: a randomized, controlled trial. Am J Respir Crit Care Med.
194 Gotsopoulos H, Kelly JJ, Cistulli PA. (2004). Oral appliance therapy reduces blood pressure in obstructive sleep apnea: a randomized, controlled trial. Sleep.
195 Johnston CD, Gleadhill IC, Cinnamond MJ, et al. (2002). Mandibular advancement appliances and obstructive sleep apnoea: a randomized clinical trial. Eur J Orthod.
196 Bloch KE, Schoch OD, Zhang JN, et al. (1999). German version of the Epworth Sleepiness Scale. Respiration.
197 Quinnell TG, Bennett M, Jordan J, et al. (2014). A crossover randomised controlled trial of oral mandibular advancement devices for obstructive sleep apnoea-hypopnoea (TOMADO). Thorax.
198 Back LJ, Liukko T, Rantanen I, et al. (2009). Radiofrequency surgery of the soft palate in the treatment of mild obstructive sleep apnea is not effective as a single-stage procedure: a randomized single-blinded placebo-controlled trial. Laryngoscope.
199 Browaldh N, Nerfeldt P, Lysdahl M, et al. (2013). SKUP3 randomised controlled trial: polysomnographic results after uvulopalatopharyngoplasty in selected patients with obstructive sleep apnoea. Thorax.
200 Dixon JB, Schachter LM, O'Brien PE, et al. (2012). Surgical vs conventional therapy for weight loss treatment of obstructive sleep apnea: a randomized controlled trial. JAMA.
201 Ferguson KA, Heighway K, Ruby RR. (2003). A randomized trial of laser-assisted uvulopalatoplasty in the treatment of mild obstructive sleep apnea. Am J Respir Crit Care Med.
202 Koutsourelakis I, Georgoulopoulos G, Perraki E, et al. (2008). Randomised trial of nasal surgery for fixed nasal obstruction in obstructive sleep apnoea. Eur Respir J.
203 Woodson BT, Steward DL, Weaver EM, et al. (2003). A randomized trial of temperature-controlled radiofrequency, continuous positive airway pressure, and placebo for obstructive sleep apnea syndrome. Otolaryngol Head Neck Surg.
204 Desplan M, Mercier J, Sabate M, et al. (2014). A comprehensive rehabilitation program improves disease severity in patients with obstructive sleep apnea syndrome: a pilot randomized controlled study. Sleep Med.
205 Foster GD, Borradaile KE, Sanders MH, et al. (2009). A randomized study on the effect of weight loss on obstructive sleep apnea among obese patients with type 2 diabetes: the Sleep AHEAD study. Arch Intern Med.
206 Kuna ST, Reboussin DM, Borradaile KE, et al. (2013). Long-term effect of weight loss on obstructive sleep apnea severity in obese patients with type 2 diabetes. Sleep.
207 Johansson K, Neovius M, Lagerros YT, et al. (2009). Effect of a very low energy diet on moderate and severe obstructive sleep apnoea in obese men: a randomised controlled trial. BMJ.
208 Kline CE, Ewing GB, Burch JB, et al. (2012). Exercise training improves selected aspects of daytime functioning in adults with obstructive sleep apnea. J Clin Sleep Med.
209 Kline CE, Crowley EP, Ewing GB, et al. (2013). Blunted heart rate recovery is improved following exercise training in overweight adults with obstructive sleep apnea. Int J Cardiol.
210 Moss J, Tew GA, Copeland RJ, et al. (2014). Effects of a pragmatic lifestyle intervention for reducing body mass in obese adults with obstructive sleep apnoea: a randomised controlled trial. Biomed Res Int.
211 Tuomilehto HP, Seppa JM, Partinen MM, et al. (2009). Lifestyle intervention with weight reduction: first-line treatment in mild obstructive sleep apnea. Am J Respir Crit Care Med.
212 Tuomilehto H, Gylling H, Peltonen M, et al. (2010). Sustained improvement in mild obstructive sleep apnea after a diet- and physical activity-based lifestyle intervention: postinterventional follow-up. Am J Clin Nutr.
213 Tuomilehto H, Seppa J, Uusitupa M, et al. (2013). Weight reduction and increased physical activity to prevent the progression of obstructive sleep apnea: a 4-year observational postintervention follow-up of a randomized clinical trial. [corrected]. JAMA Intern Med.
214 Bloch KE, Iseli A, Zhang JN, et al. (2000). A randomized, controlled crossover trial of two oral appliances for sleep apnea treatment. Am J Respir Crit Care Med.
215 Lim W, Bardwell WA, Loredo JS, et al. (2007). Neuropsychological effects of 2-week continuous positive airway pressure treatment and supplemental oxygen in patients with obstructive sleep apnea: a randomized placebo-controlled study. J Clin Sleep Med.
216 Engleman HM, Martin SE, Deary IJ, et al. (1994). Effect of continuous positive airway pressure treatment on daytime function in sleep apnoea/hypopnoea syndrome. Lancet.
217 Engleman HM, Martin SE, Deary IJ, et al. (1997). Effect of CPAP therapy on daytime function in patients with mild sleep apnoea/hypopnoea syndrome. Thorax.
218 Batool-Anwar S, Goodwin JL, Kushida CA, et al. (2016). Impact of continuous positive airway pressure (CPAP) on quality of life in patients with obstructive sleep apnea (OSA). J Sleep Res.
219 Blackwell T, Yaffe K, Laffan A, et al. (2015). Associations between sleep-disordered breathing, nocturnal hypoxemia, and subsequent cognitive decline in older community-dwelling men: the Osteoporotic Fractures in Men Sleep Study. J Am Geriatr Soc.
220 Ensrud KE, Blackwell TL, Ancoli-Israel S, et al. (2012). Sleep disturbances and risk of frailty and mortality in older men. Sleep Med.
221 Nieto FJ, Peppard PE, Young T, et al. (2012). Sleep-disordered breathing and cancer mortality: results from the Wisconsin Sleep Cohort Study. Am J Respir Crit Care Med.
222 Yaffe K, Laffan AM, Harrison SL, et al. (2011). Sleep-disordered breathing, hypoxia, and risk of mild cognitive impairment and dementia in older women. JAMA.
223 Gooneratne NS, Richards KC, Joffe M, et al. (2011). Sleep disordered breathing with excessive daytime sleepiness is a risk factor for mortality in older adults. Sleep.
224 Gottlieb DJ, Yenokyan G, Newman AB, et al. (2010). Prospective study of obstructive sleep apnea and incident coronary heart disease and heart failure: the sleep heart health study. Circulation.
225 Redline S, Yenokyan G, Gottlieb DJ, et al. (2010). Obstructive sleep apnea-hypopnea and incident stroke: the sleep heart health study. Am J Respir Crit Care Med.
226 Young T, Finn L, Peppard PE, et al. (2008). Sleep disordered breathing and mortality: eighteen-year follow-up of the Wisconsin sleep cohort. Sleep.
227 Punjabi NM, Caffo BS, Goodwin JL, et al. (2009). Sleep-disordered breathing and mortality: a prospective cohort study. PLoS Med.
228 Marshall NS, Wong KK, Liu PY, et al. (2008). Sleep apnea as an independent risk factor for all-cause mortality: the Busselton Health Study. Sleep.
229 Marshall NS, Wong KK, Cullen SR, et al. (2014). Sleep apnea and 20-year follow-up for all-cause mortality, stroke, and cancer incidence and mortality in the Busselton Health Study cohort. J Clin Sleep Med.
230 Arzt M, Young T, Finn L, et al. (2005). Association of sleep-disordered breathing and the occurrence of stroke. Am J Respir Crit Care Med.
231 Munoz R, Duran-Cantolla J, Martinez-Vila E, et al. (2006). Severe sleep apnea and risk of ischemic stroke in the elderly. Stroke.
232 Saint Martin M, Sforza E, Roche F, et al. (2015). Sleep breathing disorders and cognitive function in the elderly: an 8-year follow-up study. the proof-synapse cohort. Sleep.
233 Goehring C, Perrier A, Morabia A. (2004). Spectrum bias: a quantitative and graphical analysis of the variability of medical diagnostic test performance. Stat Med.
234 Mulherin SA, Miller WC. (2002). Spectrum bias or spectrum effect? Subgroup variation in diagnostic test evaluation. Ann Intern Med.
235 Jelinek M. (2008). Spectrum bias: why generalists and specialists do not connect. Evid Based Med.
236 Lachs MS, Nachamkin I, Edelstein PH, et al. (1992). Spectrum bias in the evaluation of diagnostic tests: lessons from the rapid dipstick test for urinary tract infection. Ann Intern Med.
237 Willis BH. (2008). Spectrum bias-why clinicians need to be cautious when applying diagnostic test studies. Fam Pract.
238 Qaseem A, Dallas P, Owens DK, et al. (2014). Diagnosis of obstructive sleep apnea in adults: a clinical practice guideline from the American College of Physicians. Ann Intern Med.
239 Flemons WW, Douglas NJ, Kuna ST, et al. (2004). Access to diagnosis and treatment of patients with suspected sleep apnea. Am J Respir Crit Care Med.
240 Johns M, Hocking B. (1997). Daytime sleepiness and sleep habits of Australian workers. Sleep.
241 Johns MW. (2000). Sensitivity and specificity of the multiple sleep latency test (MSLT), the maintenance of wakefulness test and the Epworth Sleepiness Scale: failure of the MSLT as a gold standard. J Sleep Res.
242 (1998). Randomized trial of modafinil for the treatment of pathological somnolence in narcolepsy. US Modafinil in Narcolepsy Multicenter Study Group. Ann Neurol.
243 Kingshott RN, Vennelle M, Coleman EL, et al. (2001). Randomized, double-blind, placebo-controlled crossover trial of modafinil in the treatment of residual excessive daytime sleepiness in the sleep apnea/hypopnea syndrome. Am J Respir Crit Care Med.
244 Puhan MA, Suarez A, Lo Cascio C, et al. (2006). Didgeridoo playing as alternative treatment for obstructive sleep apnoea syndrome: randomised controlled trial. BMJ.
245 Holty JE. (2015). External expert review of screening for obstructive sleep apnea in adults draft report; discussion section. Electronic correspondence with USPSTF and RTI UNC-EPC.
246 Medical Advisory Secretariat. (2009). Oral appliances for obstructive sleep apnea: an evidence-based analysis. Ontario Health Technology Assessment Series.
247 Miletin MS, Hanly PJ. (2003). Measurement properties of the Epworth Sleepiness Scale. Sleep Med.
248 Smith SS, Oei TP, Douglas JA, et al. (2008). Confirmatory factor analysis of the Epworth Sleepiness Scale (ESS) in patients with obstructive sleep apnoea. Sleep Med.
249 Baldwin CM, Griffith KA, Nieto FJ, et al. (2001). The association of sleep-disordered breathing and sleep symptoms with quality of life in the Sleep Heart Health Study. Sleep.
250 Howard ME, Desai AV, Grunstein RR, et al. (2004). Sleepiness, sleep-disordered breathing, and accident risk factors in commercial vehicle drivers. Am J Respir Crit Care Med.
251 Vongpatanasin W. (2014). Resistant hypertension: a review of diagnosis and management. JAMA.
252 Bisognano JD, Bakris G, Nadim MK, et al. (2011). Baroreflex activation therapy lowers blood pressure in patients with resistant hypertension: results from the double-blind, randomized, placebo-controlled rheos pivotal trial. J Am Coll Cardiol.
253 Esler MD, Krum H, Sobotka PA, et al. (2010). Renal sympathetic denervation in patients with treatment-resistant hypertension (The Symplicity HTN-2 Trial): a randomised controlled trial. Lancet.
254 Chobanian AV, Bakris GL, Black HR, et al., National Heart, Lung, and Blood Institute Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure, National High Blood Pressure Education Program Coordinating Committee. (2003). The Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report. JAMA.
255 Wozniak DR, Lasserson TJ, Smith I. (2014). Educational, supportive and behavioural interventions to improve usage of continuous positive airway pressure machines in adults with obstructive sleep apnoea. Cochrane Database Syst Rev.
256 Silva GE, Vana KD, Goodwin JL, et al. (2011). Identification of patients with sleep disordered breathing: comparing the four-variable screening tool, STOP, STOP-Bang, and Epworth Sleepiness Scales. J Clin Sleep Med.
257 Villa MP, Brasili L, Ferretti A, et al. (2015). Oropharyngeal exercises to reduce symptoms of OSA after AT. Sleep Breath.
258 Guimaraes KC, Drager LF, Genta PR, et al. (2009). Effects of oropharyngeal exercises on patients with moderate obstructive sleep apnea syndrome. Am J Respir Crit Care Med.
259 Kohler M, Bloch KE, Stradling JR. (2007). The role of the nose in the pathogenesis of obstructive sleep apnoea and snoring. Eur Respir J.
260 Koutsourelakis I, Minaritzoglou A, Zakynthinos G, et al. (2013). The effect of nasal tramazoline with dexamethasone in obstructive sleep apnoea patients. Eur Respir J.
261 Acar M, Cingi C, Sakallioglu O, et al. (2013). The effects of mometasone furoate and desloratadine in obstructive sleep apnea syndrome patients with allergic rhinitis. Am J Rhinol Allergy.
262 Grunstein RR, Stenlof K, Hedner JA, et al. (2007). Two year reduction in sleep apnea symptoms and associated diabetes incidence after weight loss in severe obesity. Sleep.
263 Tregear S, Reston J, Schoelles K, et al. (2010). Continuous positive airway pressure reduces risk of motor vehicle crash among drivers with obstructive sleep apnea: systematic review and meta-analysis. Sleep.
264 Karimi M, Hedner J, Habel H, et al. (2015). Sleep apnea-related risk of motor vehicle accidents is reduced by continuous positive airway pressure: Swedish Traffic Accident Registry data. Sleep.
265 Ho V, Crainiceanu CM, Punjabi NM, et al. (2015). Calibration model for apnea-hypopnea indices: impact of alternative criteria for hypopneas. Sleep.
266 Redline S, Kapur VK, Sanders MH, et al. (2000). Effects of varying approaches for identifying respiratory disturbances on sleep apnea assessment. Am J Respir Crit Care Med.
267 Chami HA, Resnick HE, Quan SF, et al. (2011). Association of incident cardiovascular disease with progression of sleep-disordered breathing. Circulation.
268 Kezirian EJ, Weaver EM, Yueh B, et al. (2004). Incidence of serious complications after uvulopalatopharyngoplasty. Laryngoscope.
269 Nagappa M, Liao P, Wong J, et al. (2015). Validation of the STOP-Bang Questionnaire as a Screening Tool for Obstructive Sleep Apnea among Different Populations: A Systematic Review and Meta-Analysis. PLoS One.
270 Nunes FS, Danzi-Soares NJ, Genta PR, et al. (2015). Critical evaluation of screening questionnaires for obstructive sleep apnea in patients undergoing coronary artery bypass grafting and abdominal surgery. Sleep Breath.
271 Firat H, Yuceege M, Demir A, et al. (2012). Comparison of four established questionnaires to identify highway bus drivers at risk for obstructive sleep apnea in Turkey. Sleep Biol Rhythms.
272 Nicholl DD, Ahmed SB, Loewen AH, et al. (2013). Diagnostic value of screening instruments for identifying obstructive sleep apnea in kidney failure. J Clin Sleep Med.
273 Balk EM, Chung M, Moorthy D, et al. (2012). Future Research Needs for Diagnosis of Obstructive Sleep Apnea.
274 Balk EM, Chung M, Chan JA, et al. (2012). Future Research Needs for Treatment of Obstructive Sleep Apnea.
275 Berry RB, Budhiraja R, Gottlieb DJ, et al. (2012). Rules for scoring respiratory events in sleep: update of the 2007 AASM Manual for the Scoring of Sleep and Associated Events. Deliberations of the Sleep Apnea Definitions Task Force of the American Academy of Sleep Medicine. J Clin Sleep Med.
276 (1999). Continuous positive airway pressure (CPAP) in sleep apnea syndrome - primary research. Health Technology Assessment Database.
277 Punjabi NM. (2008). The epidemiology of adult obstructive sleep apnea. Proc Am Thorac Soc.
278 Wright J, Johns R, Watt I, et al. (1997). Health effects of obstructive sleep apnoea and the effectiveness of continuous positive airways pressure: a systematic review of the research evidence. BMJ.
279 Tregear S, Reston J, Schoelles K, et al. (2009). Obstructive sleep apnea and risk of motor vehicle crash: systematic review and meta-analysis. J Clin Sleep Med.
280 Loke YK, Brown JW, Kwok CS, et al. (2012). Association of obstructive sleep apnea with risk of serious cardiovascular events: a systematic review and meta-analysis. Circ Cardiovasc Qual Outcomes.
281 Dong JY, Zhang YH, Qin LQ. (2013). Obstructive sleep apnea and cardiovascular risk: meta-analysis of prospective cohort studies. Atherosclerosis.
282 Epstein LJ, Kristo D, Strollo PJ, et al. (2009). Clinical guideline for the evaluation, management and long-term care of obstructive sleep apnea in adults. J Clin Sleep Med.
283 Institute for Clinical Systems Improvement. (2008). Health Care Guideline: Diagnosis and Treatment of Obstructive Sleep Apnea.
284 (2008). NICE technology appraisal guidance 139: Continuous positive airway pressure for the treatment of obstructive sleep apnoea/hypopnoea syndrome.
285 Harris RP, Helfand M, Woolf SH, et al. (2001). Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med.
286 Crawford-Achour E, Dauphinot V, Martin MS, et al. (2015). Protective effect of long-term CPAP therapy on cognitive performance in elderly patients with severe OSA: The PROOF study. J Clin Sleep Med.
287 Muxfeldt ES, Margallo V, Costa LM, et al. (2015). Effects of continuous positive airway pressure treatment on clinic and ambulatory blood pressures in patients with obstructive sleep apnea and resistant hypertension: a randomized controlled trial. Hypertension.
288 U.S. Preventive Services Task Force. (2015). Procedure Manual, Appendix VI.
289 Redline S. (2014). Effects of Treatment of Sleep Apnea on Metabolic Syndrome.
290 Mesarwi OA, Shin MK, Drager LF, et al. (2015). Lysyl oxidase as a serum biomarker of liver fibrosis in patients with severe obesity and obstructive sleep Apnea. Sleep.
291 Masa JF, Corral J, Pereira R, et al. (2013). Effectiveness of sequential automatic-manual home respiratory polygraphy scoring. Eur Respir J.
292 Bardwell WA, Ancoli-Israel S, Berry CC, et al. (2001). Neuropsychological effects of one-week continuous positive airway pressure treatment in patients with obstructive sleep apnea: a placebo-controlled study. Psychosom Med.
293 Profant J, Ancoli-Israel S, Dimsdale JE. (2003). A randomized, controlled trial of 1 week of continuous positive airway pressure treatment on quality of life. Heart Lung.
294 Blanco J, Zamarron C, Abeleira Pazos MT, et al. (2005). Prospective evaluation of an oral appliance in the treatment of obstructive sleep apnea syndrome. Sleep Breath.
295 Mehta A, Qian J, Petocz P, et al. (2001). A randomized, controlled study of a mandibular advancement splint for obstructive sleep apnea. Am J Respir Crit Care Med.
296 Lemacks J, Wells BA, Ilich JZ, et al. (2013). Interventions for improving nutrition and physical activity behaviors in adult African American populations: a systematic review, January 2000 through December 2011. Prev Chronic Dis.
297 Lin JS, O'Connor E, Whitlock EP, et al. (2010). Behavioral Counseling to Promote Physical Activity and a Healthful Diet to Prevent Cardiovascular Disease in Adults: Update of the Evidence for the U.S. Preventive Services Task Force.
298 Lin JS, O'Connor EA, Evans CV, et al. (2014). Behavioral Counseling to Promote a Healthy Lifestyle for Cardiovascular Disease Prevention in Persons With Cardiovascular Risk Factors: An Evidence Update for the U.S. Preventive Services Task Force.
299 Burke LE, Wang J, Sevick MA. (2011). Self-monitoring in weight loss: a systematic review of the literature. J Am Diet Assoc.