# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project and deeply appreciate their considerable support, commitment, and contributions: Tina Fan, MD, MPH, AHRQ Medical Officer; Tracy Wolff, MD, MPH, AHRQ Associate Scientific Director; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; expert reviewers Ethan M. Balk, MD, MPH, Brown University, Indira Gurubhagavatula, MD, University of Pennsylvania, Jon-Erik C. Holty, MD, MS, Stanford University, and VA Palo Alto Health Care System, David Hostler, MD, MPH, Walter Reed National Military Medical Center, and Paul E. Peppard, PhD, University of Wisconsin-Madison; federal partners from the National Institute on Aging, National Institute of Neurological Disorders and Stroke, and National Heart, Lung, and Blood Institute (National Institutes of Health), National Center for Health Promotion and Disease Prevention (U.S. Department of Veterans Affairs), and the Center for Devices and Radiological Health (U.S. Food and Drug Administration); Evelyn Whitlock, MD, MPH, former Kaiser Permanente Research Affiliates EPC Director; and EPC staff, Meera Viswanathan, PhD, Director, Sharon Barrell, MA, editor, and Loraine Monroe, publications specialist.