# Chapter 4 Discussion

## Summary of Evidence

Table 6 provides a summary of findings in this evidence review. This table is organized by KQ, then by questionnaire, prediction tool, test, or intervention and provides a summary of outcomes along with a description of precision, quality, and applicability.

Table 6 Summary of Evidence for Screening and Treatment of Obstructive Sleep Apnea

Questionnaire/Tool (KQ 2), Test (KQ 3), Intervention (KQs 4, 5, 8), or Outcome (KQ 6) | No. of Studies and Design (Total Sample Size) by Test or Outcome | Summary of Findings by Test or Outcome | Consistency Precision | Reporting Bias | Overall Quality | Body of Evidence Limitations | Applicability
KQ 1. Does screening for OSA in adults improve health outcomes?
No studies identified
KQ 2a. What is the accuracy of currently existing clinical prediction tools or screening questionnaires in identifying persons in the general population who are more or less likely to have OSA?
Berlin Questionnaire | 1 cross-sectional (16,302 completed Berlin; 518 had PSG) | Sn and Sp (95% CI), estimated for the general population (adjusted for oversampling high-risk participants): AHI ≥5: 37.2% (36.0 to 38.4); 84% (83.2 to 84.7) AHI ≥15: 43% (41.2 to 44.8); 79.7% (79.0 to 80.5) | Unknown, single study Precise | Undetected | Fair | Single study that has not been externally validated; moderate risk of bias due to missing data, attrition bias, spectrum bias | General population of Norway
MVAP score | 2 cross-sectional (702) | For severe OSAS (AHI ≥30 and ESS >10) using MVAP cutoff 0.48 to 0.49: Sn (95% CI): 90% (NR) to 91.5% (NR) Sp (95% CI): 43.9% (NR) to 64.4% (NR) AUC (95% CI): 0.68 (0.67 to 0.70) to 0.78 (0.71 to 0.85) | Inconsistent (one with inadequate discrimination; one with reasonable discrimination) Imprecise | Undetected | Fair | Concern for spectrum bias in both studies; risk of attrition bias in one | Populations with high prevalence of OSAS (≥25%); only one of the studies reported % with any OSA (80%); studies included Medicare recipients and adults with hypertension
MVAP score | 1 cross-sectional (250) | For any OSAS (AHI ≥5 and ESS >10) Sn (95% CI): 69.4% (NR) Sp (95% CI): 56.5% (NR) AUC (95% CI): 0.614 (NR) | Unknown Imprecise | Undetected | Fair | Concern for spectrum bias; risk of attrition bias | Populations with high prevalence of OSAS; studies included Medicare recipients and adults with hypertension
KQ 2b. What is the accuracy of multistep screening approaches, such as using a questionnaire or prediction tool followed by overnight home-based testing, in identifying persons in the general population who are more or less likely to have OSA?
MVAP followed by home PM | 2 cross-sectional (702) | For severe OSAS (AHI ≥30 and ESS >10) using home-based AHI of 15 or 18: Sn (95% CI): 88.2% to 90.9% (NR) Sp (95% CI): 71.6% to 75.7% (NR) AUCs: 0.799 (0.777 to 0.822) and 0.833 (0.765 to 0.902) | Consistent Precise | Undetected | Fair | Concern for spectrum bias; risk of attrition bias in one | Populations with high prevalence of OSAS; studies included Medicare recipients and adults with hypertension
MVAP followed by home PM | 1 cross-sectional (250) | For any OSAS (AHI ≥5 and ESS >10) Sn (95% CI): 80.5% (NR) Sp (95% CI): 54.0% (NR) AUC (95% CI): 0.672 (NR) | Unknown Imprecise | Undetected | Fair | Concern for spectrum bias; risk of attrition bias | Populations with high prevalence of OSAS; studies included Medicare recipients and adults with hypertension
KQ 3. What is the accuracy of diagnostic tests for OSA?
Type II PMs | 3 (160) | Sn/Sp: Some wide ranges across multiple AHI cutpoints, with a majority being moderate to high AUC: High discriminatory accuracy (85% to 94%) across multiple AHI cutpoints LR: Majority were moderate to high across AHI cutpoints | Reasonably consistent Imprecise | Undetected | Fair | Small sample size; missing data (complete cases only); not all reported independent scoring | Those suspected of having OSA; referral populations
Type III PMs | 1 SR of 19 studies (1,507); 2 newer studies (184) | Sn/Sp: Some wide ranges across multiple AHI cutpoints; majority being moderate to high AUC: 85% to 99% across multiple AHI cutpoints LR: High for in-lab evaluations but lower and more varied for at-home evaluations | Reasonably consistent Imprecise | Undetected | Good | Heterogeneity of results across PM settings (in lab, at home) and for more severe OSA | Those suspected of having OSA; referral population
Type IV PMs | 1 SR of 70 studies (6,873^*^); 14 newer studies (1,900) | Sn/Sp: Wide range across multiple AHI cutpoints AUC: High discriminatory accuracy in diagnosing OSA (most >80%) across multiple AHI cutpoints, regardless of number of PM channels LR: Majority were moderate to high across AHI cutpoints | Inconsistent Imprecise | Undetected | Fair | Heterogeneity of scoring methods and criteria, PM AHI cutpoints; handling of missing data; not all reported independent scoring | Those suspected of having OSA; referral population
KQ 3. What is the reliability of diagnostic tests for OSA?
Type II PMs | 2 (78) | Good to very good kappas for dual scoring of PM and PSG data; high OSA staging concordance and low AHI variability between scorers | Reasonably consistent Imprecise | Undetected | Fair | Small sample size; not all scoring was blinded | Those suspected of having OSA; referral population
Type III PMs | No studies identified
Type IV PMs | 1 (15) | Very good interobserver agreement for manual scoring of PM results | Unknown Imprecise | Undetected | Fair | Single study; small sample size | Those suspected of having OSA; referral population
KQ 4. How much does treatment improve intermediate outcomes in persons with OSA?
CPAP^†^ | AHI: 19 RCTs (837) ESS: 34 RCTs (5,209) BP: 29 RCTs reported any measure | AHI CPAP vs. Sham: WMD, -33.8 (95% CI, -42.0 to -25.6; 13 trials; N=543) ESS CPAP vs. Sham: WMD, -2.0 (95% CI, -2.6 to -1.4; 22 trials; N=2,721) BP Diurnal SBP: WMD, -2.4 (95% CI, -3.9 to -0.9; 15 trials; 1,190 participants) Diurnal DBP: WMD, -1.3 (95% CI, -2.2 to 0.4); reduction in 24-hour mean arterial pressure about 2 points | Consistent for AHI and BP; inconsistent for ESS Precise | Undetected | Fair to good | Most trials were ≤12 weeks; for ESS, substantial heterogeneity in some meta-analyses, self-report, and validity | Referral population with known OSA
Mandibular advancement devices^†^ | AHI: 10 RCTs (616) ESS: 9 RCTs (562) BP: 5 RCTs reported any measure (349) | AHI MAD vs. Sham: WMD, -12.6, (95% CI, -15.5 to -9.7; 6 trials, N=307) ESS MAD vs. Sham: WMD -1.5 (95% CI, -2.8 to -0.2; 5 trials; N=267) BP No significant reduction in any BP measures | Consistent Precise for AHI, imprecise for ESS and BP | Undetected | Good for AHI and ESS, fair for BP | Heterogeneity of BP measures and analyses; low or NR rates of HTN at baseline for those analyses | Referral population with known OSA
Airway surgery | AHI: 5 RCTs (254) ESS: 4 RCTs (187) BP: 1 RCT (46) | AHI: trials of UPPP and LAUP found benefit ESS: no benefit BP: no significant change in either group | Unknown Imprecise | Undetected | Fair | Just 1 trial for each of 5 different surgeries (N= 32 to 67) | Potentially limited; OSA patients from ENT clinics, sleep clinics, or referrals; those deemed good candidates for surgery
Bariatric surgery | AHI: 1 RCT (60) ESS: 1 RCT (60) BP: 1 RCT (60) | No significant difference between groups | Unknown Imprecise | Undetected | Fair | | Potentially limited; morbidly obese candidates for bariatric surgery
Weight loss programs | AHI: 5 RCTs (477) ESS: 4 RCTs (213) BP: 3 RCTs (184) | AHI: WMD, -12.4 (95% CI, -19.4 to -5.5) ESS: WMD, -3.4 (95% CI, -5.9 to -1.0); 3/4 trials found reductions, ranging from -3 to -7 BP: no significant difference between groups | Some inconsistency Precise for AHI and ESS; imprecise for BP | Undetected | Fair to good | For BP: 3 different interventions studied; very wide qualitative CI | Obese men and women, generally with moderate to severe OSA
KQ 5. How much does treatment improve health outcomes in persons with OSA?
CPAP^ǂ^ | Mortality: 31 RCTs (2,673) SF-36 PCS: 7 RCTs (616) SF-36 MCS: 8 RCTs (978) EQ-5D: 2 RCTs (663) Sleep-related QOL (SAQLI or FOSQ): 13 RCTs (2,325) MVA: 3 RCTs (1,595) CBV events: 4 RCTs (1,604) CV events: 8 RCTs (1,529) HF: 1 RCT (723) | Mortality: No events (27 RCTs) or 1 event (2 RCTs) at ≤12 weeks; no proven benefit at 24 weeks (1 RCT: 2 vs. 2) or 4 years (1 RCT: 8 vs. 3) SF-36 PCS: CPAP vs. any comparator: WMD, 2.3 (95% CI, 0.2 to 4.4); 7 trials; N=648 SF-36 MCS: CPAP vs. any comparator: WMD, 1.2 (95% CI, -0.8 to 3.2); 8 trials; N=1,039 EQ-5D: No benefit (1 RCT); insufficient data provided to determine between group differences (1 RCT) SAQLI or FOSQ: CPAP vs. any comparator: SMD, 0.28 (95% CI, 0.14 to 0.42); 13 trials; N=2,325 MVA: No benefit across 3 RCTs CBV events: Overall, too few events were observed to draw conclusions^§^ CV events: Overall, too few events were observed to draw conclusions, but trend in direction favoring CPAP^‖^ | Mortality, CBV and CV events: Consistent for studies of relatively short duration (≤12 to 24 weeks); unknown for longer duration SF-36 PCS, MCS, and NHP: Inconsistent EQ-5D, heart failure: unknown Sleep-related QOL, MVA, TIA: Consistent Precise for sleep-related QOL (SAQLI and FOSQ); imprecise for all other outcomes | Detected for SF-36 outcomes (5 RCTs only reported on individual SF-36 domains but not overall, PCS, or MCS scores) Undetected for all other outcomes | Fair | Study duration may be insufficient to determine benefit for many health outcomes; small number of total events observed across studies (for mortality, MVA, CBV, and CV events) | Referral population with known OSA
Mandibular advancement devices | Mortality: 4 RCTs (245) SF-36 total: 1 RCT (97) SF-36 PCS: 2 RCTs (183) SF-36 MCS: 2 RCTs (183) Sleep-related QOL: 3 RCTs (256) MVA: 1 RCT (90) | One total death in no-treatment group in one 4-week RCT (N=93); mixed results for QOL measures; 5 total MVA events (3 in MAD groups and 2 in no treatment groups) | Inconsistent or unknown consistency Imprecise | Undetected for most; suspected for QOL measures | Fair to poor | Short study durations (1 to 12 weeks), small number of studies reporting the outcomes and too few events (for mortality and MVAs) | Referral population with known OSA
Airway surgery | Mortality: 3 RCTs (127) QOL (SF-36 PCS, MCS): 2 RCTs (92) Sleep-related QOL: 1 RCT (60) Cognitive impairment: 1 RCT (60) | Mortality: No deaths in any study (12 weeks to 15 months) QOL (SF-36): No benefit found over 8 to 24 weeks Sleep-related QOL: No benefit measured on SAQLI; possible benefit with TCRFTA compared with sham surgery on FOSQ but not SNORE25 Cognitive impairment: No benefit on multiple measures of reaction time | Unknown Imprecise | Undetected | Good to fair | 1 trial for each of 5 different surgeries (N=32 to 67); some study durations limited for assessing health outcomes; few total events | Potentially limited; OSA patients from ENT clinics, sleep clinics, or referrals; those deemed good candidates for surgery
Bariatric surgery | Mortality, QOL (SF-36), Headaches: 1 RCT with 2- year followup (60) | Mortality: No deaths QOL: SF-36 MCS score: -0.3 (95% CI, -5.3 to 4.8) SF-36 PCS score: 9.3 (95% CI, 0.5 to 18.0) Headache: 1 vs. 0 persons | Unknown consistency^¶^ Imprecise | Undetected | Fair | Small numbers of total events (for mortality) | Potentially limited; morbidly obese candidates for bariatric surgery
Weight loss programs | Mortality: 4 RCTs (451) General QOL (SF-36 or 15D): 3 RCTs (150) EQ-5D-VAS: 1 RCT (60) Sleep-related QOL (FOSQ): 1 RCT (45) Cognitive impairment: 1 RCT (45) | Mortality: 1 total death over 9 to 208 weeks General QOL: No benefit in 1 RCT measured by the 15D; 2 trials provide ≥1 scores on individual SF-36 domains EQ-5D-VAS: No difference after 13 weeks of treatment, but greater improvement for the treatment group after 13 additional weeks of followup (between-group difference, 9 [95% CI, 2 to 16]) FOSQ: 1 RCT found no benefit Cognitive impairment: 1 RCT found no benefit on multiple measures of cognitive function at 12 weeks | Unknown Imprecise | Undetected | Good to fair | Small numbers of total events (for mortality); heterogeneity of reporting for QOL; single small study for some outcomes | Obese men and women, generally with moderate to severe OSA
KQ 6. Is there an association between AHI and health outcomes?
All-cause mortality | 6 prospective cohorts (11,003)^#^ | For AHI ≥30 (severe OSA): HR, 2.07 (95% CI, 1.48 to 2.91) | Consistent Precise | Undetected | Good | Risk of residual confounding | General population
Cardiovascular mortality | 2 prospective cohorts (3,173) | For AHI ≥30 (severe), adjusted HR, 2.87 (95% CI, 1.1 to 7.3) to 5.9 (95% CI, 2.6 to 13.3) | Consistent Imprecise | Undetected | Fair to good | Risk of residual confounding | General population
Cancer-related mortality | 1 prospective cohort (1,522) | For AHI ≥30: adjusted HR, 4.8 (95% CI, 1.7 to 13.2) | Unknown Imprecise | Undetected | Fair | Single study; risk of residual confounding; lack of precise information for some risk factors (e.g., smoking) | General population
Cardiovascular events | 1 prospective cohort for each: nonfatal CV events (1,651) HF (4,422) CHD (4,422) | Nonfatal CV events for AHI ≥30: OR, 3.17 (95% CI, 1.12 to 7.52) Neither CHD nor incident HF were associated with OSA (of any severity) for men or for women in adjusted analyses^**^ | Unknown Imprecise | Undetected | Fair to good | Single study for each outcome; potential measurement bias, risk of residual confounding | General population
Stroke | 1 prospective cohort (5,422) | For men, AHI ≥19: adjusted HR, 2.86 (95% CI, 1.10 to 7.39) For women: HR, 1.21 (95% CI, 0.65 to 2.24) | Unknown Imprecise | Undetected | Fair to good | Single study; masking of outcomes assessors NR, risk of residual confounding | General population
Cognitive impairment or dementia | 1 prospective cohort (298) | For AHI ≥15: adjusted OR, 1.85 (95% CI, 1.11 to 3.08) | Unknown Imprecise | Undetected | Fair | Single study, risk of residual confounding | Older women
Cognitive decline | 1 prospective cohort (2,636) | For AHI ≥15: adjusted OR, 1.14 (95% CI, 0.84 to 1.54) on Trails B and OR, 0.99 (95% CI, 0.79 to 1.24) on 3MS | Unknown Imprecise | Undetected | Fair | Single study, risk of residual confounding | Older men
KQ 7. Are there harms associated with screening or diagnostic testing for OSA?
No studies identified
KQ 8. Are there harms associated with treatment of OSA?
CPAP | 9 RCTs (1,759) | Overall, 2% to 47% had specific adverse events while using CPAP. Commonly reported harms were oral or nasal dryness, eye or skin irritation, rash, epistaxis, and pain | Consistent Imprecise | Undetected | Fair | High heterogeneity in reporting and findings | Referral population with known OSA
Mandibular advancement devices | 8 RCTs (443) | 17% to 74% had any harms while using MADs. Common were oral or nasal dryness, excess salivation, oral mucosal/dental/jaw symptoms | Inconsistent Imprecise | Undetected | Fair | High amount of heterogeneity | Referral population with known OSA
Airway surgery | 4 RCTs (205) | 1% to 81% of participants had harms from surgery. Most common were pain, postoperative bleeding, difficulty speaking and swallowing, change in vocal quality, hematomas, ulcerations, infections, temporary nasal regurgitation, and pain | Unknown Imprecise | Undetected | Fair | Small sample sizes; just 1 trial for each of 4 different surgeries | General population of patients with OSA deemed suitable for surgery
Bariatric surgery | 1 RCT (60) | 1 rehospitalization for additional surgery in treatment arm | Unknown Imprecise | Undetected | Fair | Single study with small sample | Morbidly obese
Weight loss, diet and exercise | 1 RCT (63) of very low-calorie diet | Harms were reported by <10% of patients and included constipation, elevated alanine aminotransferase concentrations, dizziness, gout, and dry lips | Unknown Imprecise | Undetected | Fair | Single study with small sample | Obese men and women, generally with moderate to severe OSA

* This includes 24 studies (n=1,865) from the 2011 SR and 46 studies (n=5,008) from the 2007 Technology Assessment that were summarized by the 2011 SR.

† In this table, the total number of RCTs and participants reporting each outcome for CPAP or MADs are more than the number that contributed to the data in column 3 because we did not enter the CPAP or MAD “vs. control” data. Rather, we focused on the CPAP or MAD vs. sham data. We did, however, consider evidence from both comparator groupings in our assessments.

ǂ Selected results for the most commonly reported outcomes are included in this table. Details on additional measures (e.g., Nottingham Health Profile) with few studies and insufficient evidence to draw conclusions are provided in the text and Appendixes.

§ TIA: few events across 3 RCTs (CPAP vs. comparators: total of 4 vs. 7 combining all trials); stroke: few events across 4 RCTs (CPAP vs. comparators: 3 vs. 3 combining all trials). Trial durations were 12 weeks, 24 weeks, 1 year, and 4 years (median followup).

‖ MI: few events across 5 RCTs (5 vs. 8 combining all trials); incident or unstable angina: few events across 4 RCTs (4 vs. 9 combining all trials); incident atrial fibrillation: 3 RCTs (12 vs. 20 events combined).

¶ For SF-36 PCS, improvement is consistent with that expected from a large weight loss.

# Two of the publications used data from the same cohort (WSCS) and we did not double-count those participants here (we just used one of the publications in the meta-analysis).

** For the subgroup of men age ≤70 years, participants with AHI ≥30 were more likely to develop CHD than those with AHI <5 (adjusted HR, 1.68 [95% CI, 1.02 to 2.76]).

Abbreviations: 3MS=Modified Mini-Mental State Examination; AHI=apnea hypopnea index; AUC=area under the curve; BP=blood pressure; CBV=cerebrovascular; CHD=coronary heart disease; CI=confidence interval; CPAP=continuous positive airway pressure; CV=cardiovascular; DBP=diastolic blood pressure; ENT=ear, nose, and throat (otolaryngology); ESS=Epworth Sleepiness Scale; EQ-5D=European Quality of Life Scale; FOSQ=Functional Outcomes of Sleep Questionnaire; HF=heart failure; HR=hazard ratio; KQ=key question; LAUP=laser-assisted uvulopalatoplasty; LR=likelihood ratio; MAD=mandibular advancement device; MCS=mental component summary score; MVA=motor vehicle accident; MVAP=Multivariable Apnea Prediction; N=number; NHP=Nottingham Health Profile; NR=not reported; OR=odds ratio; OSA=obstructive sleep apnea; OSAS=obstructive sleep apnea syndrome; PCS=physical component summary score; PSG=polysomnography; PM=portable monitor; QOL=quality of life; RCT=randomized, controlled trial; SAQLI=Sleep Apnea Quality of Life Index; SBP=systolic blood pressure; SF-36=Medical Outcome Short-Form (36-Item) Health Survey; Sn=sensitivity; Sp=specificity; SR=systematic review; TIA=transient ischemic attack; UPPP=uvulopalatopharyngoplasty; WMD=weighted mean difference; WSCS=Wisconsin Sleep Cohort Study.

### Evidence for Benefit and Harms of Screening

We did not identify any eligible studies directly evaluating the effectiveness or adverse outcomes of screening for OSA compared with no screening. Potential harms include overdiagnosis and overtreatment for asymptomatic persons (with AHI ≥5) who would never have had symptoms of or problems from OSA and costs and additional testing (e.g., future PSG to follow patients over time). Furthermore, we found no studies evaluating the effect of OSA screening on psychological outcomes such as distress due to labeling or stigma.

### Screening Questionnaires and Clinical Prediction Tools

We found very few eligible studies evaluating the accuracy of questionnaires or prediction tools for distinguishing persons in the general population who are more or less likely to have OSA. The only screening approach with at least two included studies suggesting possible accuracy was the MVAP score followed by an in-home PM for detecting severe OSAS (AHI ≥30 and ESS >10). AUC was approximately 0.8, with sensitivity around 90 percent and specificity ranging from 72 to 76 percent.^103,104^ Although this approach may have promise for screening, the evidence was limited by potential spectrum bias,^233-237^ with oversampling of high-risk participants and those with OSA and OSAS, which may substantially overestimate the accuracy that would be achieved in the general population. Such overestimation was illustrated by a study evaluating the Berlin Questionnaire, which reported a reduction in sensitivity from 79 to 37 percent after adjusting for bias in the sampling procedure to report estimated screening properties for the general population.^102^ The included studies evaluating MVAP had a high prevalence of OSAS (≥25%),^103,104^ OSA (AHI ≥5 for 80% and mean AHI of 22.5),^104^ and sleepiness (74%).^103^ In addition, none prospectively measured calibration, often assessed by plotting the predicted risk versus an observed event rate,^107^ and none assessed clinical utility for improving health outcomes.

We included fewer studies evaluating questionnaires or clinical prediction tools than some previously published reviews and guidelines,^1,8,238^ primarily because of our requirement that studies enroll asymptomatic adults or persons with unrecognized symptoms of OSA; referral populations (e.g., to sleep clinics) were not eligible. The focus of previous reviews and guidelines was generally on diagnostic testing (of adults with symptoms suggestive of disordered sleep) rather than on screening (of asymptomatic persons or those with unrecognized symptoms). Nevertheless, those reviews and guidelines generally reported low overall quality/strength of evidence for questionnaires and prediction tools.

### Accuracy and Reliability of Diagnostic Tests

We found limited evidence evaluating Type II PMs (3 studies; total of 160 participants). For Type III and IV monitors, existing literature reveals some inconsistency, with wide ranges of sensitivity and specificity (Table 5), especially for single-channel Type IV monitors for detecting moderate to severe OSA. Nevertheless, many studies reported moderate to high LR+ (>5) and moderate to low LR- (<0.2), and previous reviews and guidelines concluded that moderate-quality evidence shows that Type III and IV monitors are “generally accurate to diagnose OSA, but have a wide and variable bias in estimating the actual AHI.”^1,238^ Studies published more recently for Type IV PMs have resulted in greater heterogeneity of methods and findings (than found by prior reviews) and wider ranges of sensitivity and specificity. Evidence for Type IV PMs is limited by inconsistency and imprecision. In addition, unlike other types of PMs, Type IV monitors are limited by their inability to differentiate obstructive and central events. We found scant data addressing reliability of PMs of any type.

Barriers to undergoing diagnostic testing for OSA include limited availability of PSG, ability to tolerate testing, inconvenience, and costs.^239^ It is unclear how often those barriers prevent completion of testing. Mean time from referral to sleep clinic evaluation in the United States has wide variation, ranging from a few weeks to more than a year, with longer wait times for university, state, and federal government sleep laboratory facilities.^239^ That time may not include the time from clinic evaluation to completion of diagnostic testing, which may occur at a subsequent visit. The majority of diagnostic evaluations are split-night PSG.^239^

### Benefits and Harms of Treatment for OSA

Our review found consistent evidence from good- and fair-quality RCTs that CPAP effectively reduces AHI to normal (<5) or near-normal (<10) levels, reduces excessive sleepiness, and reduces blood pressure. However, the clinical significance of mean reductions of 2 points on the ESS and 2 to 3 points for blood pressure measures is somewhat uncertain. For sleepiness, our data suggest a clinically significant reduction in most included trials because 85 percent of the trials in our meta-analysis for ESS that had mean baseline ESS scores of 10 or greater (indicating excessive daytime sleepiness) reported mean endpoint ESS scores in the normal range of less than 10^240,241^ for the CPAP groups (mean endpoint ESS <8). However, the threshold for a clinically significant change in ESS is somewhat uncertain. Although recent systematic reviews noted that experts consider a 1-point change in ESS clinically significant,^1^ other sources suggest that a greater change, of at least 3 or 4 points, should be the clinically significant threshold. For example, some trials that use ESS as an outcome have considered a 4-point or greater change in ESS as clinically significant for their sample size calculations or interpretation of findings.^242-244^ Also, the American College of Chest Physicians' outcome experts evaluating the ESS informally stated that a clinically significant change in the ESS is probably at least 3 points; a specific example cited was that a reduction of 1 point (e.g., from 3 [high] to 2 [moderate]) on two out of seven ESS domains was unlikely clinically relevant.^245^ Regardless of what constitutes a clinically significant change, potential bias from the subjective nature of the ESS remains (potential overreporting of improvements in sleepiness after receiving treatment), and some authors have raised concerns about its construct validity (i.e., uncertainty regarding whether it is an accurate measure of sleepiness).^246-248^ Multiple studies have reported associations between sleepiness and health outcomes, although many of them did not use the ESS to measure sleepiness. One study that used the nationwide population-based SHHS^249^ (5,816 participants; mean age, 63 years; 52.5% women) reported that excessive daytime sleepiness was strongly associated with reduced quality of life after adjusting for confounding variables (e.g., age, ethnicity) for both sexes. Sleepiness has also been linked to motor vehicle crashes in multiple observational studies.^37,39,250^ A cross-sectional study of 913 employed adults from the general U.S. population (enrolled in the WSCS) found that men and women with an AHI greater than 15 were significantly more likely to have multiple accidents over the past 5 years (OR, 7.3 [95% CI, 1.8 to >25], adjusted for age, miles driven, and sex) using state records for motor vehicle accident history (retrospectively).^37^ The study was limited by the retrospective design and potential confounding. Considering education and usual alcohol consumption did not alter the OR. However, none of their measures of perceived sleepiness (including those derived from ESS) were significantly related to accident occurrence. A cross-sectional study of 2,342 Australian commercial vehicle drivers found that the sleepiest 5 percent of drivers (based on ESS) had about twice the odds of a self-reported motor vehicle accident over the previous 3 years (OR, 1.91 [95% CI, 1.09 to 3.35]) and even greater odds of multiple accidents over the previous 3 years (OR, 2.67 [95% CI, 1.29 to 5.52]).^250^

For blood pressure reduction, some authors suggest that a difference of more than 9/10 mm Hg (systolic/diastolic) is clinically meaningful for individuals.^251-253^ However, across a population, guidelines have suggested that much smaller reductions of 2 to 3 mm Hg for systolic blood pressure could result in a clinically significant reduction in cardiovascular mortality (by 4% to 5% for coronary heart disease and 6% to 8% for stroke).^254^

We found that MADs and weight loss programs also reduce AHI and excessive sleepiness, although the magnitudes of effects were generally less than with CPAP, and blood pressure reduction was not established. Although we did not evaluate head-to-head studies (e.g., directly comparing MADs with CPAP), previous comparative effectiveness reviews examining head-to-head trials reported smaller effect sizes for MADs than for CPAP for reducing AHI.^1^ Evidence on surgical treatments was limited by unknown consistency and imprecision, because only a single RCT evaluated each surgical technique studied.

Evidence on most health outcomes was limited (i.e., too few RCTs reported or too few events occurred to make conclusions about the effectiveness for reducing mortality, cardiovascular events, or motor vehicle accidents). However, our meta-analysis for sleep-related quality of life found a significant benefit for CPAP, albeit with a small effect size (SMD, 0.28 [95% CI, 0.14 to 0.42]). The effect size was slightly greater among those with excessive daytime sleepiness at baseline but still small (0.33 [95% CI, 0.17 to 0.50]).

Reporting of harms from treatment in the included studies was sparse. Most did not report any information about harms. In general, the adverse events related to CPAP treatment were likely short-lived and could be alleviated with discontinuation of CPAP or additional interventions. Common adverse effects included oral or nasal dryness, eye or skin irritation, rash, epistaxis, and pain. Common adverse effects from MADs included oral or nasal dryness, excessive salivation, and jaw discomfort. No included studies reported on psychosocial harms of treatment, such as marital stress due to disruption of partner sleeping (e.g., because of the noise of CPAP).

Such adverse effects may limit adherence to treatment. A wide range of adherence to CPAP usage recommendations has been reported, from about 30 to 85 percent.^255^ A systematic review for AHRQ's Effective Healthcare Program reported that cohort studies with multivariable analyses for predictors of nonadherence show that 14 to 32 percent of patients discontinue CPAP over 4 years and patients use CPAP for an average of 5 hours per night; data were too limited to provide adherence rates for MADs.^1^ The review also found that AHI and ESS are independent predictors of CPAP adherence.^1^ A recent Cochrane systematic review of 33 studies (2,047 participants) found low- to moderate-quality evidence that three types of interventions can increase CPAP machine usage in CPAP-naive participants with moderate to severe OSAS.^255^ These included supportive interventions that encourage persons to continue to use their CPAP machines, short-term educational interventions, and behavioral therapy. However, they noted that trials did not assess persons who have struggled to adhere to treatment, and the impact of improved CPAP usage on daytime sleepiness, quality of life, and long-term cardiovascular risks remains unclear.

### Association Between AHI and Health Outcomes

Consistent, precise evidence from prospective cohort studies that focused on community-based participants supports the association between AHI and all-cause mortality. Although the cohort studies controlled for many potential confounders, residual confounding due to health-related factors that are associated with OSA (e.g., physical activity, diet) and that were generally not accounted for is possible. We found that persons with severe (AHI ≥30) or moderate to severe OSA (AHI ≥15) die at about twice the rate of controls when pooling data from multivariate analyses. We also found consistent evidence showing that persons with severe or moderate to severe OSA have increased cardiovascular mortality. The only studies reporting subgroup analyses suggested that the association may only be present for men age 70 years or younger (but not for women or for men older than age 70 years)^227^ and for those with excessive daytime sleepiness.^223^ These data do not prove causality, and residual confounding is a possibility, but the included studies were well designed and incorporated many potential confounders in their multivariate analyses.

## Limitations

This review is limited in the ability to describe the direct evidence on the effectiveness or harms of screening for OSA because we identified no studies comparing screened and unscreened populations. Therefore, we attempted to review literature that might establish an indirect chain of evidence from multiple questions that link screening to health outcomes (KQs 2 through 8). For the first question in that indirect pathway, we found limited evidence that one screening approach (MVAP followed by an in-home PM) might be useful to screen for severe OSAS, but the evidence was limited by potential spectrum bias, and no studies prospectively assessed calibration or clinical utility for improving health outcomes.

We required studies to use in-laboratory PSG as the reference standard for KQs 2 and 3. This is similar to the approach used in previous systematic reviews. For KQ 2, this resulted in exclusion of a large study from the SHHS that included 4,770 community participants and reported on the STOP, STOP-Bang, and ESS questionnaires. It reported sensitivity from 39 percent (ESS ≥11) to 87 percent (STOP-Bang) and specificity from 43 percent (STOP-Bang) to 71 percent (ESS) for predicting moderate to severe OSA (respiratory disturbance index ≥15).^256^ LR- ranged from 0.3 to 0.85, indicating minimal to small decreases in the likelihood of disease, and LR+ ranged from 1.4 to 1.5, indicating a minimal increase in the likelihood of disease.

We did not evaluate the accuracy of individual physical examination findings. We required questionnaires or clinical prediction tools to have multiple factors because previous systematic reviews have found limited utility of individual findings. A recent review of clinical examination accuracy, which was not limited to asymptomatic patients or those with unrecognized symptoms, found that (among individual symptoms or signs) the most useful observation for identifying patients with OSA was nocturnal choking or gasping, imparting a small increase in the likelihood of disease (summary likelihood ratio, 3.3 [95% CI, 2.1 to 4.6], when the diagnosis was established by AHI ≥10).^8^ The review found that many symptoms and signs provide limited information in determining the likelihood of OSA.^8^

We did not evaluate every possible outcome. We chose the outcomes that are most commonly reported and most potentially clinically meaningful. We did not include the Multiple Sleep Latency Test, for example, which was reported by a relatively small number of trials and did not show a clear benefit of CPAP, according to a prior systematic review.^1^ For KQ 6, we did not evaluate the association between AHI and incident diabetes. A 2011 systematic review concluded that there may be an association but the strength of evidence was low and the association may be confounded by obesity.^1^ A more recent (2014) systematic review concluded that the association between OSA and incident diabetes is uncertain.^92^

Our review was limited to the evaluation of the most common treatments for OSA. We did not evaluate some treatments that may have potential benefits, such as oropharyngeal exercises,^257,258^ playing the didgeridoo, or using nasal steroids for treating allergic rhinitis (or similar treatments that might secondarily improve OSA by treating another condition).^259-261^ Nevertheless, previous reviews and clinical practice guidelines suggest that the potential benefits of such treatments are limited or uncertain.^1,76^

We limited eligible study designs to RCTs for evaluating treatment benefits. It is possible that this approach excluded some studies that might provide useful evidence for certain treatments, although such evidence has a higher risk of bias because of potential selection bias and confounding. For example, the Swedish Obesity Study was a nonrandomized study that included almost 3,500 participants.^262^ Over 2-year followup after bariatric surgery, it found marked improvement in sleep apnea symptoms for patients treated with bariatric surgery than for a conservatively treated control group. Other examples include observational studies focused on motor vehicle accidents. A meta-analysis of such observational studies that evaluated the association between CPAP and motor vehicle accidents identified nine retrospective before-after studies, all without control groups (and all studies we consider to have a high risk of bias mainly because of the risk of selection bias and confounding), and reported a reduction in crash risk following treatment (risk ratio, 0.28 [95% CI, 0.22 to 0.35]).^263^ A recent observational study that used the Swedish Traffic Accident Registry reported that CPAP use for 4 or more hours per night was associated with a reduction of accident incidence (from 7.6 to 2.5 accidents/1,000 drivers/year).^264^

Some of our meta-analyses of RCTs evaluating benefits of CPAP (KQ 4) found substantial statistical heterogeneity. We did not find a clear explanation for the statistical heterogeneity, but possible explanations include variation in CPAP devices (e.g., machines, masks, humidifiers, filters, cushions), participant characteristics (e.g., studies with lower baseline mean AHI finding smaller effect sizes because of ceiling effects), apnea and hypopnea definitions, adherence, study duration, study methods, or chance. Definitions of apnea and hypopnea vary in published studies. For example, various cutpoints for oxygen desaturation are used to define hypopnea; some studies define hypopnea as requiring either oxygen desaturation or an electroencephalogram arousal, and some studies do not clearly define hypopnea. A publication from the SHHS demonstrated the potential impact of variation in hypopnea definitions on prevalence of OSA, reporting that varying the definition in an otherwise healthy older population resulted in the prevalence increasing from roughly 50 percent (using the Centers for Medicare & Medicaid Services definition of 4% oxygen desaturation) to greater than 80 percent (using the American Academy of Sleep Medicine 2012 definition of either a 3% oxygen desaturation or an electroencephalogram arousal).^265,266^ We did not abstract detailed information about apnea and hypopnea definitions from each study and did not conduct subgroup analyses or meta-regression to explore the specific contribution of every possible factor that may explain some of the statistical heterogeneity identified by our meta-analyses. Regardless of the cause of the statistical heterogeneity, all trials reported statistically significant improvement for AHI (with endpoint AHI values universally ≤10 for CPAP-treated groups), and the vast majority of trials that included participants with excessive daytime sleepiness at baseline (ESS ≥10) reported mean endpoint ESS scores well into the normal range (<8) for the CPAP-treated groups.

For the association between AHI and health outcomes, it is unclear whether some of the studies excluded central apnea from their analyses, and it is possible that central apnea may account for some small portion of the reported associations between AHI and health outcomes. Of note, one publication from the SHHS reported that the association between AHI and incidental myocardial infarction was due to increases in both obstructive and central apnea events.^267^ However, predominant central apnea is relatively rare, seen in less than 10 percent of patients presenting for PSG and in less than 1 percent of the general population.^16,17^ Among the studies in our meta-analysis analyzing the relationship between AHI and all-cause mortality, two studies reported no information about central events (and it is unclear whether central events were included in their analyses),^220,229^ one reported just that there were few central events,^226^ and two provided more detailed results.^223,227^ Among those that provided more detailed results, one reported data from the SHHS and found that the central apnea index was not associated with mortality in men or women,^227^ and the other reported that a sensitivity analysis excluding the 4 percent of patients with predominately central apnea resulted in no meaningful change in findings.^223^

For harms of treatment (KQ 8), we required studies to have a control group to be eligible. This resulted in the exclusion of large uncontrolled observational studies, which may be useful for determining rates of harms from surgical procedures. For example, a large study of patients who underwent UPPP reported a 0.2 percent (7/3,130) perioperative mortality rate and a serious complication rate of 1.6 percent (51/3,130), including reintubation, pneumonia, hemorrhage, cardiovascular complication, emergency tracheotomy, and mechanical ventilation for more than 48 hours.^268^ Such evidence has been summarized elsewhere.^1^

## Future Research Needs

To better understand the potential effectiveness of screening for OSA, randomized trials of asymptomatic persons (or those with unrecognized symptoms) that directly compare screening with no screening and assess health outcomes are needed (i.e., trials that address KQ 1, the overarching question). To better determine the accuracy of screening questionnaires and clinical prediction tools when used in the general population (related to our KQ 2), additional studies are needed; such studies should aim to include a representative community population, to avoid spectrum bias, and to further evaluate promising screening approaches (e.g., MVAP followed by in-home PM) as well as other approaches for which we found limited or no eligible studies, such as the STOP-Bang Questionnaire. A recently published systematic review and meta-analysis concluded that the STOP-Bang Questionnaire has good performance for screening for OSA in sleep clinic and surgical populations.^269^ However, it did not identify studies with representative community populations that compared STOP-Bang with PSG. Of the 17 included studies, 11 were from sleep clinic populations (not eligible for our review), three were from surgical populations, and three were from other populations. Of the three from surgical populations, we excluded one because of poor quality,^69^ one because of ineligible comparator^70^ as it compared STOP-Bang findings with a PM (rather than PSG), and one because of ineligible country^270^ (a small study of 40 patients undergoing coronary artery bypass graft or abdominal surgery in Brazil). Of the three studies from other populations, one was from the general population, one from bus drivers, and one from patients with renal failure. These were excluded from our review for the following reasons: ineligible comparator (it compared findings with a PM),^256^ ineligible country (study of 85 Turkish bus drivers),^271^ and ineligible comparison (it compared findings with a PM among 172 patients with renal failure).^272^

More studies are needed that assess the reliability of PMs for home use, particularly studies that enroll patients representative of the general population. Trials are needed that evaluate whether CPAP and other common treatments improve health outcomes (except for sleep-related quality of life), such as cardiovascular events. Studies are needed that determine whether findings (for diagnostic test accuracy and treatment benefits) differ for subgroups defined by age, sex, BMI, or OSA severity.

Two documents produced for AHRQ's Effective Healthcare Program specifically address future research needs related to diagnosis^273^ and treatment^274^ of OSA. To determine priorities, the authors engaged 21 to 22 panel members representing patients and the public, providers, purchasers of health care, payers, policymakers, and principal investigators. Some of the high-priority future research needs that are relevant to our review included determination of the prognostic accuracy of clinical prediction rules to predict clinical outcomes; assessment of the impact of treatment on major long-term clinical outcomes, including mortality, cardiovascular disease, and diabetes; and trials of different sleep apnea treatments based on patient characteristics (trials of CPAP and non-CPAP treatments stratified by disease severity).

## Conclusion

There is uncertainty about the clinical utility of all potential screening tools. Although screening with MVAP followed by an in-home PM may have promise for accurately distinguishing persons in the general population who are more or less likely to have OSA, current data are limited by potential spectrum bias, with oversampling of high-risk participants and those with OSA and OSAS. Further, we found no studies that prospectively evaluated screening questionnaires or clinical prediction tools to report calibration or clinical utility for improving health outcomes. Multiple treatments for OSA improve intermediate outcomes—CPAP effectively reduces AHI to normal or near-normal levels, reduces excessive sleepiness, and reduces blood pressure; MADs and weight loss programs also reduce AHI and excessive sleepiness, although the magnitudes of effects were generally less than with CPAP. Although good evidence has established that persons with severe or moderate to severe OSA die at twice the rate of controls, trials of CPAP and other treatments have not satisfactorily evaluated whether treatment reduces mortality or improves most other health outcomes, barring evidence of some possible benefit for sleep-related quality of life.