# Chapter 3 Results

## Literature Search

We identified 9,841 unique records and assessed 1,443 full texts for eligibility (Figure 2). We excluded 1,316 articles for various reasons detailed in Appendix C and included 110 studies (published in 127 articles) of good or fair quality. Of the included studies, three were studies of clinical prediction tools or screening questionnaires (KQ 2), 21 were studies of diagnostic test accuracy (KQ 3) (one of which was also included for KQ 2), 76 were RCTs focused on the benefits (KQs 4 and 5) and harms (KQ 8) of treatments for OSA, and 11 provided evidence on the association between AHI and health outcomes (KQ 6). We identified no eligible studies for KQ 1 (direct evidence of screening) or KQ 7 (harms of screening). Details of quality assessments of included studies and studies excluded because of poor quality are provided in Appendix D.

Figure 2 Summary of Evidence Search and Selection

* Insufficient information to assess risk of bias.

Abbreviations: KQ=Key Question; WHO ICTRP=World Health Organization International Clinical Trials Registry Platform.

This figure is a flow chart that summarizes the search and selection of articles. There were 10,033 references identified by searching PubMed, the Cochrane Library, and EMBASE. We identified 1,206 references from other sources, including the ClinicalTrials.gov and WHO ICTRP databases, hand searching and reference list review, peer reviewer suggestions, and from previous reports (for KQ 3). After removing duplicates, the titles and abstracts of 9,841 references were screened for potential inclusion. Of these, 1,443 were deemed appropriate for full-text review to determine eligibility. After full-text review, 1,316 were excluded: 14 for ineligible language/non-English; 31 for ineligible publication type/not original research; 172 for ineligible population; 161 for ineligible screening/intervention; 266 for ineligible comparator; 168 for no or ineligible outcome; 2 for ineligible setting; 244 for ineligible study design; 36 for ineligible country; 57 for no full-text availability; 33 for poor quality; and 131 that were superseded by other included articles. 127 articles representing 110 studies were included in this review.

## Results

### KQ 1 Direct Evidence That Screening for OSA Improves Health Outcomes

We found no eligible studies that addressed this question.

### KQ 2 Clinical Prediction Tools or Screening Questionnaires

We included three fair-quality studies assessing clinical prediction tools or screening questionnaires compared with facility-based PSG (Table 3).^102-104^ One evaluated the Berlin Questionnaire^102^ and two evaluated the Multivariable Apnea Prediction (MVAP) score, alone and when followed by an in-home PM.^103,104^ We found no eligible studies of good or fair quality evaluating other clinical prediction tools or screening questionnaires, such as the ESS, the STOP Questionnaire, or the STOP-Bang Questionnaire.

Table 3 Characteristics of Included Studies for KQ 2

First Author, Year Country Study Design | N | Participants | Questionnaire/Tool Name | Questionnaire/Tool Components | Mean Age (Range) | % F | % Non-white | Mean BMI | Mean AHI | % HTN % HF | % With OSA | Quality
Gurubhagavatula, 2013^104^ United States Cross-sectional | 250 | Those with HTN^*^ from internal medicine practices and a HTN clinic | Single-stage models used the MVAP score; two-stage models used MVAP plus AHI from home test | MVAP combined symptoms of snoring, choking, and witnessed apnea with BMI, age, and sex | 53 (NR) | 20 | 60 | 32.1 | 22.5 | 100 NR | Of the 79% who had in-lab PSG: Any: 80 Mild: 34 Moderate: 22 Severe: 25 % OSAS: Mild: 25 (AHI ≥5 and ESS >10) Severe: 7.6 (AHI ≥30 and ESS >10) | Fair
Morales, 2012^103^ United States Cross-sectional | 452 | Medicare recipients from the greater Philadelphia metro region, most with some daytime sleepiness^†^ | Single-stage models used the MVAP score; two-stage models used MVAP plus AHI from home test | MVAP combined symptoms of snoring, choking, and witnessed apnea with BMI, age, and sex | 71 (NR) | 70 | 64 | 30 | NR | NR 0 | Any OSAS (AHI ≥5 and ESS >10): 27 Mild (AHI 5–15 and ESS >10): 9 At least moderate (AHI ≥15 and ESS >10): 17 Moderate (AHI 15–30 and ESS >10): 8 Severe (AHI ≥30 and ESS >10): 8 | Fair
Hrubos-Strom, 2011^102^ Norway Cross-sectional | 16,302 completed the BQ; 518 had PSG | Randomly drawn from national population register | BQ (Norwegian translation) | 10 questions on snoring, witnessed apnea, fatigue or sleepiness, and blood pressure; and height, weight, age, and sex | Screening sample: 48 (NR) Clinical sample: 48 (NR) | 53 45 | NR NR | 26 28 | NA Median, 6.4 | 14 27 NR NR | NR | Fair

* Required to have blood pressure ≥140/90 mm Hg or to be on antihypertensive medications.

† From personal communication with Indira Gurubhagavatula (July 2015), 74% met their definition of daytime sleepiness (frequency of sleepiness, based on whether they had a problem staying awake, of every day or several [≥3] days per week); 32% had ESS >10.

Abbreviations: AHI=apnea-hypopnea index; BMI=body mass index; BQ=Berlin Questionnaire; ESS=Epworth Sleepiness Scale; F=female; HF=heart failure; HTN=hypertension; KQ=Key Question; MVAP=Multivariable Apnea Prediction; N=sample size; NR=not reported; OSA=obstructive sleep apnea; PSG=polysomnography.

Two studies that otherwise met our eligibility criteria were excluded because of high risk of bias and therefore rated as poor quality.^69,105^ Our main concerns were high risk of selection bias (mainly from attrition bias and spectrum bias, with oversampling of high-risk subjects) and inadequate handling of missing data (Appendix D). One of the studies evaluated the STOP and STOP-Bang Questionnaires in a preoperative sample (N=211).^69^ The other evaluated the MVAP score alone and when followed by an in-home PM among commercial driver's license holders (N=406).^105^

#### Berlin Questionnaire

The Berlin Questionnaire classifies risk of OSA as high or low by using three categories related to snoring, tiredness, and blood pressure (at least two positive categories constitutes high risk).^71^ Among the 10 questions, it also gathers information on age, sex, height, and weight. The one included study evaluating the Berlin Questionnaire randomly sampled Norwegians from the National Population Register to complete the Norwegian translation of the Berlin Questionnaire (55% response rate [16,302/29,258]).^102^ Of those completing the questionnaire, 24 percent were classified as high risk and 518 had in-hospital PSG. Of those 518, the mean age was 48 years, 45 percent were female, the mean BMI was 28 kg/m^2^, and the median AHI was 6.4. Although the group receiving PSG oversampled high-risk participants (70% were high risk), their analyses adjusted for bias in the sampling procedure to report estimated screening properties for the general population. They found suboptimal screening properties (for AHI ≥5: sensitivity of 37.2%, specificity of 84%; for AHI ≥15: 43% and 79.7%, respectively) (Table 4). Of note, because it has implications for the validity of studies that oversample high-risk groups (and illustrates the impact of spectrum bias), their unadjusted analyses (reported only in online appendixes) show much better sensitivity but worse specificity (for AHI ≥5: sensitivity of 79.4%, specificity of 40.5%; for AHI ≥15: 82.8% and 34.9%, respectively).

Table 4 Results of Included Studies: Accuracy of Screening Questionnaires and Clinical Prediction Tools (KQ 2)

First Author, Year | Questionnaire/Tool Name Cutoff Value | Sensitivity (95% CI) | Specificity (95% CI) | AUROC (95% CI) | Calibration | Others
Gurubhagavatula, 2013^104^ | MVAP to predict severe OSAS (AHI ≥30 and ESS >10) 0.483 | 91.5 (NR) | 43.9 (NR) | 0.684 (0.668 to 0.700) | NR | Neg LR, 0.190 NPTP=0.015
Gurubhagavatula, 2013^104^ | MVAP to predict any OSAS (AHI ≥5 and ESS >10) 0.559 | 69.4 (NR) | 56.5 (NR) | 0.614 (NR) | NR | Neg LR, 0.524 NPTP=0.148
Gurubhagavatula, 2013^104^ | MVAP + uAHI^*^ to predict severe OSAS (AHI ≥30 and ESS >10) uAHI 18 | 88.2 (NR) | 71.6 (NR) | 0.799 (0.777 to 0.822) | NR | Neg LR, 0.162 NPTP=0.015
Gurubhagavatula, 2013^104^ | MVAP + uAHI^*^ to predict any OSAS (AHI ≥5 and ESS >10) uAHI 13.5 | 80.5 (NR) | 54.0 (NR) | 0.672 (NR) | NR | Neg LR, 0.349 NPTP=0.104
Morales, 2012^103^ | MVAP to predict severe OSAS (AHI ≥30 and ESS >10) 0.49 | 90.0 (NR) | 64.4 (NR) | 0.776 (0.710 to 0.846) | NR | Neg LR, 0.141 NPTP=1.1%
Morales, 2012^103^ | MVAP + uAHI^*^ to predict severe OSAS (AHI ≥30 and ESS >10) uAHI 15 | 90.9 (NR) | 75.7 (NR) | 0.833 (0.765 to 0.902) | NR | Neg LR, 0.120 NPTP=1.0%
Hrubos-Strom, 2011^102^ | BQ to predict AHI ≥5^†^ BQ high risk vs. low risk | 37.2 (36.0 to 38.4) | 84.0 (83.2 to 84.7) | NR | NR | PPV (95% CI), 61.3 (59.7 to 62.9) NPV (95% CI), 66.2 (65.3 to 67.1) Pos LR (95% CI), 2.3 (2.2 to 2.5) Neg LR (95% CI), 0.8 (0.7 to 0.8)
Hrubos-Strom, 2011^102^ | BQ to predict AHI ≥15^†^ BQ high risk vs. low risk | 43.0 (41.2 to 44.8) | 79.7 (79.0 to 80.5) | NR | NR | PPV (95% CI), 33.5 (32.0 to 35.0) NPV (95% CI), 85.5 (84.8 to 86.1) Pos LR (95% CI), 2.1 (2.0 to 2.3) Neg LR (95% CI), 0.7 (0.7 to 0.7)

* 2-stage process using MVAP for everyone, and then home testing to determine AHI for those with an intermediate MVAP score.

† Estimates were based on a simulated model that adjusted for oversampling of BQ high-risk subjects (not just based on findings for the 518 in the clinical sample).

Abbreviations: AHI=apnea-hypopnea index; AUROC=area under the receiver operating characteristic curve; BMI=body mass index; BQ=Berlin Questionnaire; CI=confidence interval; ESS=Epworth Sleepiness Scale; KQ=key question; MVAP=Multivariable Apnea Prediction; N=sample size; Neg LR=negative likelihood ratio; NPTP=negative posttest probability; NPV=negative predictor value; NR=not reported; OSA=obstructive sleep apnea; OSAS=obstructive sleep apnea syndrome; Pos LR=positive likelihood ratio; PPV=positive predictive value; uAHI=unattended AHI from home sleep test.

#### MVAP Score

The MVAP score combines symptoms of snoring, choking, and witnessed apnea events with BMI, age, and sex.^106^ It rates apnea risk between zero and 1, with zero representing the lowest risk and 1 representing the highest risk. Both included studies assessing the MVAP were published by the same research group from Philadelphia.^103,104^ One study evaluated Medicare recipients (N=452) from the greater metropolitan area, most (74%) of whom had daytime sleepiness.^103^ The percentage with OSA was not reported, but 27 percent had OSA syndrome (OSAS) (defined as AHI ≥5 and ESS >10). The other study evaluated patients with hypertension from internal medicine practices at a Veterans Affairs (VA) Medical Center and a university-based hypertension clinic (N=250).^104^ Eighty percent of participants had OSA (AHI ≥5); of those, 22 percent had moderate and 25 percent had severe OSA, and 25 percent of all participants had OSAS. Mean ages of participants were 71^103^ and 53 years^104^, 60 to 64 percent were nonwhite, and mean BMIs were 30 to 32 kg/m^2^. The study of Medicare recipients included 70 percent women;^103^ the other study included 20 percent women.^104^ Key quality limitations included concern for attrition bias^104^ and moderate concern for selection bias/spectrum bias (with high prevalence of OSA, OSAS, and/or sleepiness among those receiving PSG)^103,104^ (Appendix D).

Both studies reported operating characteristics of MVAP to predict severe OSAS (AHI ≥30 and ESS >10) using MVAP cutoff scores of 0.48 to 0.49 (Table 4). Sensitivity was 90^103^ and 91.5 percent,^104^ with specificity of 64.4 and 43.9 percent, respectively (95% CIs not reported). The study of Medicare recipients reported reasonable discrimination (area under the curve [AUC], 0.78 [95% CI, 0.71 to 0.85]), whereas the other study found inadequate discrimination (AUC, 0.68 [95% CI, 0.67 to 0.70]). An AUC less than 0.70 is thought to indicate inadequate discrimination.^107,108^ Calibration, often assessed by plotting the predicted risk versus the observed rate,^107^ was not reported.

The study of patients with hypertension also reported operating characteristics of MVAP to predict any OSAS (AHI ≥5 and ESS >10) using an MVAP cutoff score of 0.559. It reported sensitivity of 69.4 percent, specificity of 56.5 percent, and AUC of 0.614.

#### MVAP Score Followed by an In-Home PM

The same two studies described in the previous section also reported measures of discrimination for the MVAP score followed by an in-home PM (Table 4).^103,104^ They reported characteristics to predict severe OSAS (AHI ≥30 and ESS >10) using different PM-based AHI cutoffs; one used 15^103^ and the other used 18.^104^ Both studies found better operating characteristics when using MVAP followed by an in-home PM than when using MVAP alone (sensitivity, 88.2% to 90.9%; specificity, 71.6% to 75.7%; AUC, 0.799 to 0.833).

The study of patients with hypertension also reported operating characteristics of MVAP to predict any OSAS (AHI ≥5 and ESS >10) using an in-home PM-based AHI cutoff of 13.5. It reported sensitivity of 80.5 percent, specificity of 54.0 percent, and AUC of 0.672.

### KQ 3 Accuracy and Reliability of Diagnostic Tests for OSA

We included three studies evaluating Type II PMs (Appendix E Table 1), one systematic review and two subsequent studies evaluating Type III PMs (Appendix E Table 2), and one systematic review and 14 subsequent studies evaluating Type IV PMs (Appendix E Tables 3–5). No studies evaluated the diagnostic accuracy of Type II, III, or IV PMs among subgroups defined by age, sex, or BMI. Table 5 summarizes the range of sensitivity, specificity, and AUC by type of PM for AHI thresholds of 5, 15, and 30. Additional information on study characteristics and results is available in Appendix E Tables 1–10.

Table 5 Summary of Accuracy of Diagnostic Tests for Obstructive Sleep Apnea

Portable Monitor | PSG AHI ≥5 | | | PSG AHI ≥15 | | | PSG AHI ≥30
Portable Monitor | Sn (%) | Sp (%) | AUC (%) | Sn (%) | Sp (%) | AUC (%) | Sn (%) | Sp (%) | AUC (%)
Type II | 88-96 | 50-84 | 86-90 | 85-94 | 77-95 | 89-94 | 64-86 | 98-100 | 85
Type III | 87-96 | 60-76 | 89-96 | 49-92 | 79-95 | 85-97 | 50-97 | 90-93 | 86-99
Type IV | 65-100 | 35-100 | NR^*^ | 7-100 | 15-100 | NR^†^ | NR^ǂ^ | NR^§^ | NR^‖^

* The 2011 systematic review did not report the range of AUC values for the 2007 technology assessment and articles newly included in the 2011 review. The AUC values among the 13 studies newly identified since the 2011 review ranged from 59 to 94.

† The 2011 systematic review did not report the range of AUC values for the 2007 technology assessment and articles newly included in the 2011 review. The AUC values among the 13 studies newly identified since the 2011 review ranged from 89 to 96.

ǂ The 2011 systematic review did not report the range of Sn values for the 2007 technology assessment and articles newly included in the 2011 review. The Sn values among the 13 studies newly identified since the 2011 review ranged from 59 to 100.

§ The 2011 systematic review did not report the range of Sp values for the 2007 technology assessment and articles newly included in the 2011 review. The Sp values among the 13 studies newly identified since the 2011 review ranged from 71 to 100.

‖ The 2011 systematic review did not report the range of AUC values for the 2007 technology assessment and articles newly included in the 2011 review. The AUC values among the 13 studies newly identified since the 2011 review ranged from 73 to 95.

Abbreviations: AHI=apnea-hypopnea index; AUC=area under the curve; NR=not reported; PSG=polysomnography; Sn=sensitivity; Sp=specificity.

Overall, many more studies have evaluated Type III and Type IV monitors than Type II. The best evidence comes from good-quality systematic reviews that reported sensitivity of 93 percent (pooled estimate from in-home studies) and 96 percent (pooled estimate from in-laboratory studies) for Type III PMs and at least 85 percent for Type IV PMs for detecting any OSA (AHI ≥5).^1^ Corresponding specificity was 60 percent (in-home) and 76 percent (in-laboratory) for Type III PMs, and ranged from 50 to 100 percent for Type IV PMs.^1^ Sensitivity decreased and specificity increased for detecting moderate or greater OSA (AHI ≥15) or severe OSA (AHI ≥30). The ranges of sensitivity and specificity reported across studies for Type IV monitors were wide.

Study participants were generally those referred to sleep units for suspected sleep apnea. We did not find studies that identified participants via screening to identify asymptomatic patients or those with unrecognized symptoms, although detailed reporting of why patients were referred was generally limited. Some studies were conducted in home settings and some tested PMs in laboratory settings; the latter generally reported better accuracy than the former. Reporting of PM AHI cutpoints that were compared with designated PSG AHI cutpoints was limited, with about half of the studies not reporting PM AHI cutpoints. Of those that reported PM AHI cutpoints, the cutpoints used varied across studies, and many studies reported accuracy only for the cutpoints that performed best in their studies.

#### Type II PMs

We included one study^109^ from Spain that evaluated a Type II PM in a sleep laboratory and two studies^110,111^ from Belgium and New Zealand that evaluated Type II PMs in home settings (Appendix E Table 1). All 160 participants from the three studies (68, 62, and 30 participants, respectively) had been referred to sleep units for suspected sleep apnea, and in two of the studies,^109,110^ more than 80 percent of participants had a PSG AHI of 5 or greater. In one study,^110^ patients had to report snoring, excessive daytime sleepiness, or “two other major symptoms of OSA.” The other studies did not report information about symptoms or reasons for referral. The mean PSG AHI ranged from 22 to 35 and the mean ESS ranged from 9 to 11. A majority of participants in each of the studies were male and overweight or obese (mean BMI, 29 to 31 kg/m^2^).

##### Diagnostic Accuracy

None of the studies reported the PM AHI cutpoints that were compared with the PSG AHI cutpoints of 5, 15, and 30. To diagnose OSA, defined as a PSG AHI of 5 or greater, Type II PMs had sensitivity of 88 to 96 percent and specificity of 50 to 84 percent. There was a trend of decreasing sensitivity and increasing specificity with increasing PSG AHI cutpoints. Sensitivity was 85 to 94 percent for an AHI of 15 or greater and 64 to 86 percent for an AHI of 30 or greater. Specificity was 77 to 95 percent and 98 to 100 percent for those PSG AHI cutpoints, respectively. In general, Type II PMs were accurate in diagnosing OSA, with AUC values of 85 to 94 across multiple AHI cutpoints. Two thirds of the LR+ and LR- values reported (across multiple cutpoints) indicated a moderate to high increase (LR+) or decrease (LR-) in the risk of OSA in two studies;^109,111^ LR+ ranged from 1.8 to 17.6 and LR- ranged from 0.08 to 0.37 across multiple AHI cutpoints.

##### Reliability

One study^109^ compared two expert scorers who manually scored both the PSG and Type II PM; scorers were blind to the patient;s identity and results from the other test (i.e., PSG or PM). The mean PM AHI scores were 19 (scorer 1) and 17 (scorer 2); the kappa (κ) coefficients for PSG AHI cutpoints of 5 or greater, 15 or greater, and 30 or greater were 0.66, 0.70, and 0.85, respectively. Similarly, the mean PSG AHI scores were 22 (scorer 1) and 20 (scorer 2); the κ coefficients for PSG AHI cutpoints of 5 or greater, 15 or greater, and 30 or greater were 0.84, 0.65, and 1.00, respectively. One study^111^ evaluated intrascorer reliability by rescoring a random selection of 10 sleep studies; it was not clear which of the 10 sleep studies were in-laboratory PSG or at-home PM. The intrascoring staging concordance was 94 percent and the mean variability in AHI was -0.8.

#### Type III PMs

We identified one systematic review from 2014^112^ and two studies^113,114^ that evaluated Type III PMs and were published after the systematic review search cutoff (Appendix E Table 2). Both Type III PMs were used at home and included channels for oxygen saturation, airflow, and thoracic and abdominal movements.

##### Findings of the 2014 Systematic Review

The review^112^ covered literature from 2004 through March 2013. Although the overall review included 59 studies (n=5,026 patients), the authors reported meta-analysis results from 19 studies (n=1,507 patients), stratified by setting of PM (i.e., sleep laboratory, home) and AHI cutpoint (i.e., ≥5, ≥10, ≥15, and ≥30).

Patients (n=5,026) with suspected OSA had a mean age of 51 years, a mean ESS score of 12, a mean BMI of 30 kg/m^2^, and were predominantly male (ratio of male to female was 2.9 to 1); patient characteristics were not synthesized for the 19 studies in the meta-analysis. The PM performed better in the sleep laboratory setting than at home for all AHI cutpoints. The pooled sensitivity for the home and laboratory settings for an AHI of 15 or greater were 79 and 92 percent, respectively, and generally decreased with increasing OSA severity. The pooled specificity for the home and laboratory settings for an AHI of 15 or greater were 79 and 91 percent, respectively, and generally increased with increasing OSA severity. Discriminatory accuracy of the PMs was high, with AUC for all AHI cutpoints ranging from 85 percent for an AHI of 15 or greater in the home setting to 99 percent for an AHI of 30 or greater in the laboratory setting. Pooled likelihood ratios for the home setting indicated a small to moderate increase (LR+) or decrease (LR-) in the risk of OSA; LR+ ranged from 2.3 to 8.2 and LR- ranged from 0.11 to 0.26 across multiple AHI cutpoints. Seventy-five percent of the pooled likelihood ratios for the laboratory setting indicated a high increase (LR+) or decrease (LR-) in the risk of OSA; LR+ ranged from 3.9 to 14.9 and LR- ranged from 0.03 to 0.09. There was moderate to substantial statistical heterogeneity of results for two AHI cutpoints in the sleep laboratory setting (I^2^=85 for AHI ≥5; I^2^=66 for AHI ≥15) and for two AHI cutpoints in the home setting (I^2^=53 for AHI ≥10; I^2^=82 for AHI ≥15); sensitivity analyses, whereby studies with only patients with comorbidities were excluded, did not explain the heterogeneity or substantially change the results.

##### Description of Type III PM Studies Published After the 2014 Systematic Review Searches

The two included studies (from Spain and Canada) had a total of 184 participants referred to sleep clinics who underwent evaluation for OSA by Type III PMs at home; one study^113^ required that participants 1) snored or had some observed apnea events during sleep, 2) had ESS of less than 15, or 3) had a significant comorbidity with daily symptoms (e.g., chronic obstructive pulmonary disease). More than 90 percent of the patients in both studies had a PSG AHI of 5 or greater. The mean PSG AHI in one study^113^ was 30 and in the other study^114^ ranged from 15 to 25 among patients with low scores and from 35 to 39 among patients with high scores on the Berlin, Sleep Apnea Clinical Score, and STOP-Bang Questionnaires. Patients were more commonly male (55% to 66%) and obese (mean BMI, 30 to 31 kg/m^2^); the mean age of patients was 50 to 54 years.

One study did not report the PM AHI cutpoints that were compared with PSG AHI;^114^ the other study reported the PM AHI cutpoints that were compared with PSG AHI cutpoints of 5 and 15.^113^ To diagnose OSA, defined as a PSG AHI of 5 or greater, Type III PMs had sensitivity of 87 to 96 percent and specificity of 60 to 76 percent. As in the review, sensitivity decreased and specificity generally increased with increasing AHI. AUC values ranged from 82 to 95 percent across all AHI cutpoints. At a PSG AHI of 15 or greater, one study^113^ reported that a PM AHI of less than 7 would exclude OSA and a PM AHI of 22 or greater would confirm OSA. A majority of likelihood ratios indicated a moderate or high increase (LR+) or decrease (LR-) in the risk of OSA (LR+ ranged from 2.6 to 15.50 and LR- ranged from 0.06 to 0.50).

#### Type IV PMs

We identified one good-quality systematic review from 2011^1^ as well as 14 studies^104,115-127^ that evaluated the diagnostic accuracy of Type IV PMs and were published after the systematic review search cutoff (Appendix E Tables 3–5). Four studies evaluated PMs with 1 channel,^116, 118,121,122^ five studies evaluated PMs with 2 channels,^117,120,123,124,126^ and five studies evaluated PMs with 3 or more channels.^104,115,119,125,127^

##### Findings of the 2011 Systematic Review

The good-quality 2011 systematic review^1^ covered literature from inception of the databases through September 2010 and summarized findings from the investigators' earlier 2007 technology assessment of PMs^75^ that covered literature from inception of the databases through February 2007. The systematic review authors evaluated 24 new studies (seven graded quality A, 11 graded quality B, and six graded quality C) that included 1,865 participants. Seven PMs had more than 3 channels, nine had 2 channels, and nine had a single channel. Patients in 20 of the studies had been referred for suspected sleep apnea or UPPP; the remaining studies included particular populations (e.g., commercial motor vehicle drivers, persons with diabetes, persons with heart failure). The mean ages of patients ranged from 37 to 61 years, and the percentage of male patients ranged from 32 to 100 percent. The mean ESS score ranged from 5.8 to 13.3, and the mean PSG AHI ranged from 14 to 44.

The ranges of sensitivity and specificity for Type IV PMs for the diagnosis of OSA were wide across multiple AHI cutpoints, regardless of the number of channels. Sensitivity ranges were 85 to 100 percent, 43 to 100 percent, and 18 to 100 percent for AHI cutpoints of 5, 15, and 30, respectively. Specificity ranges were 50 to 100 percent, 42 to 100 percent, and 50 to 100 percent for AHI cutpoints of 5, 15, and 30, respectively. The range of sensitivity and specificity increased further when 46 studies (5,008 participants) of Type IV PMs from the 2007 technology assessment were included. Most studies, across both the 2011 systematic review and the 2007 technology assessment, had LR- close to 0.1 for an AHI cutpoint of 5; as AHI cutpoint increased, more studies were at the intersection of an LR+ of 10 or greater or LR- of 0.1 or less, suggesting a better ability to predict elevated AHI.

##### Description of Studies Published After the 2011 Systematic Review Searches

We included 14 studies of Type IV PMs from Australia or North America (n=4),^104,122,123,127^ South America (n=2),^117,124^ Europe (n=7),^115,116,118-121,126^ and Asia (n=1).^125^ Sample sizes ranged from 25^125^ to 348^119^ participants (total of 1,900 participants) who were primarily referred for suspected sleep apnea. One study referred patients after cardiorespiratory polygraphy,^121^ one study referred patients after screening with the Berlin Questionnaire,^127^ and one study referred a population of patients with hypertension.^104^ Multiple studies required clinical symptoms such as snoring, excessive daytime sleepiness, or observed apneas during sleep;^117,119,126^ one study stated that patients had been referred both with and without symptoms (but did not provide further details).^124^ In all but one study,^127^ fewer than half of the patients were female. The mean age ranged from 41 to 61 years, and the mean BMI ranged from overweight (26 kg/m^2^) to obese (33 kg/m^2^). Among the studies reporting ESS scores, the mean ranged from 10 to 12. The mean PSG AHI ranged from 16 to 38, and the percentage of participants with an AHI of 5 or greater was more than 70 percent (among 10 studies reporting).

Eleven studies administered the PMs in the laboratory or hospital setting,^115-118,120,121,123-127^ and four studies administered the PMs in the home setting.^104,119,122,127^ The single-channel Type IV PMs were pulse oximeters; one study^122^ also evaluated a single-channel PM that measured snoring. The 2-channel Type IV PMs were primarily pulse oximeters that also measured snoring,^117,123,124^ heart rate,^120,126^ and airflow.^124^ All of the Type IV PMs with three or more channels included pulse oximeters. Some studies of 2-channel PMs evaluated manual versus automatic scoring,^117^ different hypopnea criteria,^117^ the use of respiratory disturbance index versus AHI,^124^ and different PM AHI cutpoints.^123^ Less than half (43%) of studies reported the PM AHI cutpoints that were compared with designated PSG AHI cutpoints.

There was a wide range of sensitivity and specificity for all Type IV PMs across multiple AHI cutpoints (58 to 100 and 35 to 100, respectively); most AUC values were greater than 80. One study of a 4-channel PM reported lower AUC values for a PSG AHI of 5 or greater (AUC, 0.59) when the PM AHI was 8.9, and a PSG AHI of 30 or greater (AUC, 0.73) when the PM AHI was 16.^104^ A majority of likelihood ratios indicated a moderate to high increase (LR+) or decrease (LR-) in the risk of OSA; the LR+ ranged from 1.6 (PSG AHI ≥10)^119^ to 13.7 (PSG respiratory disturbance index ≥10),^124^ and the LR- ranged from 0.01 (PSG AHI ≥5)^104^ to 0.57 (PSG AHI ≥5).^127^

One study^117^ evaluated reliability of a 2-channel PM using a manual scoring method; interrater agreement for the classification of patients with or without OSA was very good (κ=0.81).

### KQ 4 Benefits of Treatment for Improving AHI, Sleepiness, and Blood Pressure

We included 76 good- or fair-quality RCTs: 56 trials (described in 60 articles) evaluated CPAP (Appendix E Tables 11 and 12),^128-187^ 10 trials (12 articles) evaluated MADs (Appendix E Table 13),^173,180,188-197^ six trials evaluated surgical interventions (Appendix E Table 14),^198-203^ and six trials (10 articles) evaluated weight loss programs (Appendix E Table 15).^204-213^

#### CPAP

Of the 56 included RCTs, 36 trials (39 articles) compared CPAP with sham CPAP (Appendix E Table 11)^128-151,153-157,159-164,166-169^ and 20 (21 articles) compared CPAP with other controls (Appendix E Table 12).^152,158,165,170-187^ Most studies identified participants from sleep clinics or referrals. None of the trials focused on subjects who were screen-detected in primary care settings, but two trials identified participants by screening patients in cardiology or heart failure clinics using the Berlin Questionnaire^178^ or the ESS.^184^ Most trials were conducted in the United States (18 trials), United Kingdom (14 trials), or Spain (11 trials); four or fewer were conducted in each of the following: Hong Kong, Australia, Canada, and New Zealand. Duration of treatment ranged from 1 week to 4 years; it was 12 weeks or less in most trials, but five treated participants for 24 weeks or longer,^145,171,172,174,182^ including two that followed participants for 52 weeks^171,182^ and one that did so for a median of 4 years.^172^ Mean age was in the 40s to 50s in most studies and ranged from 42 to 71 years. The vast majority of participants in most trials were men, with 44 trials reporting that less than one third of participants were women. More than half of participants were women in just one trial.^167^ More than three fourths of included studies did not report the percentage of minority participants. Of those that did, it ranged from 5 to 56 percent. Mean BMI was 30 to 35 kg/m^2^ in most trials (range, 27 to 39 kg/m^2^). Mean or median baseline AHI (or similar measure) was in the severe OSA range (AHI ≥30) for more than 75 percent of trials; eight trials reported it in the moderate OSA range,^150,151,155,162,173,178,180,182^ and four reported it in the mild OSA range.^166,174,176,183^ The range of OSA severity of the enrolled participants in trials most frequently spanned the moderate to severe ranges (29 trials) or the mild to severe ranges (19 trials). Seven trials limited participants to more narrow ranges: mild only,^176^ mild to moderate,^151,166,173,183^ or severe only.^130,165^ One trial did not report sufficient data to determine the range of OSA severity of participants.^174^ Mean baseline ESS was 10 or greater in 33 trials, indicating excessive daytime sleepiness. Ten trials reported a mean baseline ESS of less than 10,^130,134,138,147,162,171,172,174,178,181^ and 13 trials did not report baseline ESS.

##### AHI

The trials reporting sufficient data for meta-analysis were all 12 weeks or less. Our meta-analyses found that CPAP reduced AHI more than sham CPAP (WMD, -33.8 [95% CI, -42.0 to -25.6]; 13 trials; 543 participants) and more than other controls (WMD, -25.8 [95% CI, -34.2 to -17.5]; 6 trials; 294 participants) (Appendix F Figures 1 and 2). Our meta-analyses found substantial statistical heterogeneity that may be due to variation in CPAP devices (e.g., machines, masks, humidifiers, filters, cushions), participant characteristics (e.g., studies with lower baseline mean AHI finding smaller effect sizes due to ceiling effects), apnea and hypopnea definitions, adherence, study duration, or chance. Nevertheless, all individual studies reported statistically significant improvement, and endpoint AHI values were universally 10 or less for CPAP-treated groups, and most were 5 or less.

##### ESS

Thirty-four trials reported sufficient ESS data to include in meta-analyses. Most were 12 weeks or less in duration; five followed participants for 24 weeks,^145,174^ 48 to 52 weeks,^171,182^ or longer.^172^ Our meta-analyses found that CPAP reduced ESS more than sham CPAP (WMD, -2.0 [95% CI, -2.6 to -1.4]; 22 trials; 2,721 participants) and more than other controls (WMD, -2.2 [95% CI, -2.8 to -1.6]; 12 trials; 2,488 participants) (Appendix F Figures 9 and 10). Our analyses found substantial statistical heterogeneity that may be due to variation in CPAP devices, participant characteristics (e.g., baseline ESS), adherence, study duration, or chance. We were unable to find a clear explanation for the heterogeneity. Among the 27 trials with mean or median baseline ESS of 10 or greater (mean baseline ESS, 12.7) or those that provided subgroup analyses for the participants with excessive sleepiness, our subgroup meta-analyses found a similar result (WMD, -2.4 [95% CI, -2.9 to -1.9]) (Appendix F Figure 11). Twenty-three of those 27 trials reported mean endpoint ESS scores of less than 10 for the CPAP group (mean endpoint ESS <8). Our subgroup meta-analyses by OSA severity (3 categories: mild to moderate OSA, mild to severe OSA, and moderate to severe OSA) did not find a clear difference by OSA severity. Effect sizes were -1.7, -2.1, and -2.4, respectively, and CIs overlapped considerably; the analysis still found considerable statistical heterogeneity within the mild to severe and moderate to severe groups (Appendix F Figure 12).

##### Blood Pressure

Twenty-nine trials reported sufficient blood pressure data to include in meta-analyses. Blood pressure outcomes were reported in a variety of ways (e.g., 24-hour mean arterial blood pressure, 24-hour systolic or diastolic, diurnal mean arterial blood pressures, diurnal systolic). The most common were diurnal systolic and diurnal diastolic blood pressure. Most trials were 12 weeks or less in duration; three followed participants for 24 to 52 weeks.^171,174,182^ Our meta-analyses found that CPAP reduced diurnal systolic blood pressure by 2 to 3 points (WMD, -2.4 [95% CI, -3.9 to -0.9]; 15 trials; 1,190 participants; I^2^=0%) and reduced diurnal diastolic blood pressure by more than 1 point (WMD, -1.3 [95% CI, -2.2 to -0.4]; 15 trials; 1,190 participants; I^2^=16%) compared with sham CPAP. Reduction in 24-hour mean arterial pressure was about 2 points with CPAP compared with sham CPAP (WMD, -2.1 [95% CI, -3.2 to -1.0]; 5 trials; 621 participants; I^2^=3%). Appendix F provides more detailed results of meta-analyses for all blood pressure measures reported.

Among the six studies that focused on participants with uncontrolled hypertension or that provided subgroup analyses for the participants with uncontrolled hypertension,^135,137,141,162,171,181^ our subgroup meta-analyses found similar but slightly larger magnitudes of effect (Appendix F Figures 34 and 35). For example, for the three outcomes described in the previous paragraph, we found reductions of -2.5, -2.1, and -2.7, respectively.

##### Subgroups

None of the included trials reported data by subgroups defined by age, sex, or BMI. We conducted subgroup analyses by OSA severity as described above.

#### MADs

We included 10 RCTs (described in 12 publications) assessing the effect of MADs on AHI, ESS, or blood pressure (Appendix E Table 13).^173,180,188-195,197,214^ Six compared MADs with sham devices that did not advance the mandible,^188-192,195^ one compared an MAD with a placebo tablet,^173^ two compared MADs with no treatment,^197,214^ and one compared an MAD with conservative management of OSA with weight loss.^180^ All studies recruited participants with known or suspected OSA from specialty clinics, such as sleep medicine or ear, nose, and throat (ENT) clinics. Most studies were conducted in Europe, two were conducted in Australia,^173,192^ and one in Hong Kong.^180^ Treatment durations ranged from 4 to 12 weeks for most studies, but one study lasted only 1 week^214^ and one lasted 24 weeks.^189^ Mean age of participants ranged from 45 to 59 years. The vast majority of participants in all trials were men, with women comprising 17 to 25 percent of participants in the nine trials reporting sex. No studies documented the percentage of minority participants. All studies included participants with mild to moderate OSA, and six studies also included participants with severe OSA.^180,188,191,192,195,214^ Mean baseline ESS scores ranged from 11 to 14, indicating excessive daytime sleepiness. One study included only participants with known hypertension.^188^

##### AHI

Ten trials reported sufficient data for meta-analysis.^173,180,188-192,195,197,214^ Our meta-analyses found that MADs improved AHI more than sham (-12.6 [95% CI, -15.5 to -9.7]; 6 trials; 307 participants; I^2^=0%) and more than other controls (-8.2 [95% CI, -13.9 to -2.5]; 5 trials; 358 participants; I^2^=57%) (Appendix F Figures 4 and 5).

##### ESS

Nine trials reported sufficient data for meta-analysis.^173,180,188,190-192,195,197,214^ Our meta-analyses found that MADs improved ESS more than both sham (-1.5 [95% CI, -2.8 to -0.2]; 5 trials; 267 participants; I^2^=34%) and other controls (-1.7 [95% CI, -2.2 to -1.2]; 5 trials; 358 participants; I^2^=52%) (Appendix F Figures 13 and 14).

##### Blood Pressure

Five trials reported sufficient data for meta-analysis.^180,188,190,191,194^ Blood pressure outcomes were reported in a variety of ways (i.e., 24-hour, diurnal or nocturnal, systolic or diastolic). Only one of the trials reported any statistically significant differences between an MAD and sham for some of its blood pressure measures (diurnal systolic blood pressure, -3.0 [95% CI, -5.6 to -0.4]).^194^ Our meta-analyses found no statistically significant differences between MADs and comparators for any of the measures (Appendix F Figures 36–41).

##### Subgroups

We found no studies that assessed whether the effect of MADs on intermediate outcomes differs for subgroups defined by age, sex, BMI, or severity of OSA.

#### Airway Surgery

Five included trials evaluated ENT surgeries (Appendix E Table 14). Each trial evaluated a different surgical technique, including radiofrequency surgery of the soft palate,^198^ temperature-controlled radiofrequency tissue ablation (TCRFTA),^203^ UPPP,^199^ laser-assisted uvulopalatoplasty (LAUP),^201^ and septoplasty.^202^ Three of the trials had sham surgery comparison groups;^198,202,203^ two compared surgery with no treatment.^199,201^ Sample sizes ranged from 32^198^ to 67.^199^ Participants were generally identified from ENT clinics, sleep clinics, or referrals. None of the trials focused on subjects who were screen-detected in primary care settings. Trials were conducted in Finland,^198^ United States,^203^ Sweden,^199^ Canada,^201^ and Greece.^202^ Duration of followup after surgery ranged from 8 weeks^203^ to around 15 months.^201^ Mean age ranged from 38 to 49 years. The majority of participants were men; four trials included 0 to 24 percent women and the trial of septoplasty included around 40 percent women.^202^ None of the trials reported the percentage of nonwhite participants. Mean BMI ranged from 27 to 32 kg/m^2^. Mean AHI was in the severe OSA range (AHI ≥30) for trials of UPPP^199^ and septoplasty,^202^ in the moderate OSA range for trials of radiofrequency surgery^203^ and LAUP,^201^ and in the mild range for one trial of soft palate radiofrequency surgery.^198^ The full range of OSA severity of participants was moderate to severe in the trial of UPPP,^199^ mild to severe in the trial of septoplasty,^202^ mild to moderate in trials of radiofrequency surgery^203^ and LAUP,^201^ and mild only for one trial of soft palate radiofrequency surgery.^198^ Mean baseline ESS was 10 or greater in four of the trials, indicating excessive daytime sleepiness; the trial of soft palate radiofrequency surgery reported mean baseline ESS of 8 for one group and 10 for the other.^198^

##### AHI

All five trials reported AHI. The trials of UPPP^199^ and LAUP^201^ found greater reductions in AHI for surgery than for no treatment of -26.4 (95% CI, -36.2 to -16.6) and -10.5 (95% CI, -16.9 to -4.1), respectively (Appendix F Figure 8). The other three trials (radiofrequency surgery of the soft palate, TCRFTA, or septoplasty) all had sham comparators and found no clinically or statistically significant differences between various airway surgeries and sham.^198,202,203^

##### ESS

Four of the five trials reported ESS. None of them found a statistically significant difference between participants in surgical and comparator groups (Appendix F Figure 17).

##### Blood Pressure

Only the trial of LAUP (N=46) reported blood pressure outcomes.^201^ It reported no significant changes in systolic or diastolic blood pressure in either the LAUP or control group.

#### Bariatric Surgery

The one included trial randomized 60 morbidly obese (mean BMI, 45 kg/m^2^) Australians with moderate to severe OSA (mean AHI around 60) to bariatric surgery or a conventional weight loss program.^200^ It followed participants for 2 years. Mean age was close to 50 years. More than 40 percent were female. The trial reported a significant reduction in AHI for both groups; the between-group difference was not statistically significant (-11.5 [95% CI, -28.3 to 5.3]). Similarly, both groups had a significant reduction in ESS, but the between-group difference was not statistically significant (-3.2 [95% CI, -7.2 to 0.8]). The trial found no significant difference between groups for systolic or diastolic blood pressure (mean between-group differences, -1.4 [95% CI, -11.7 to 9] and 2.4 [95% CI, -4.6 to 9.4], respectively).

#### Weight Loss, Diet, and Exercise Interventions

Six included trials (described in 10 articles) evaluated weight loss programs (Appendix E Table 15).^204-213^ Each trial evaluated a different intervention and control—two interventions focused primarily on exercise,^204,208^ two focused primarily on diet,^207,211^ and two used multicomponent lifestyle interventions (exercise, diet, and psychoeducation).^205,210^ One compared an inpatient individualized exercise training with standard health education,^204^ one compared exercise training with a stretching control,^208^ one compared an intensive lifestyle intervention (consisted of portion-controlled diet, physical activity, and group behavioral weight loss intervention) with a diabetes support and education control,^205^ one compared a very low energy diet with usual diet,^207^ one compared a very low calorie diet (for 12 weeks) plus supervised lifestyle (for 52 weeks) with usual care (routine lifestyle guidance),^211^ and one compared a program of supervised individualized exercise sessions, cognitive-behavioral psychoeducation, and dietary education with advice alone. Sample sizes ranged from 26^204^ to 264.^205^ Participants were generally identified from sleep clinics, referrals, and advertisements. None of the trials focused on subjects who were screen-detected in primary care settings. Trials were conducted in the United States,^205, 208^ Sweden,^207^ Finland,^211^ United Kingdom,^210^ and France.^204^ Duration of followup was 4 to 26 weeks for four of the trials; the other two trials followed participants to 4 or 5 years.^205,211^ Mean age ranged from 47 to 61 years. Mean BMI ranged from 30 to 40 kg/m^2^. Mean AHI was in the moderate to severe OSA range for four of the trials, in the mild range for the trial that evaluated very low calorie diet plus supervised lifestyle,^211^ and in the moderate to severe range but controlled with CPAP use in one trial.^210^ Mean baseline ESS was 10 or greater in two trials,^204,211^ less than 10 in three,^207,208,210^ and not reported in one.^205^ The weight loss achieved by intervention groups was very limited in one trial (-0.3 kg)^208^ and modest in another (-2.3 kg)^210^ but reached more clinically significant levels in the rest (5- to 20-kg reduction).^205,207,213^

##### AHI

Five trials reported AHI.^204,205,207,208,213^ Four of the five found statistically significant reductions in AHI, ranging from -5.8 (95% CI, -9.7 to -1.9) to -23 (95% CI, -30.1 to -15.9) (Appendix F Figure 6). The trial reporting the largest reduction in AHI (a reduction nearing that achieved by CPAP) also reported a much larger weight reduction than other trials (-20 kg over 9 weeks from a very low energy diet).^207^ Our meta-analysis found a WMD of -12.4 (95% CI, -19.4 to -5.5). We found substantial statistical heterogeneity (I^2^=79%), which was no longer present after removing the one study with much larger weight reduction (and the largest reduction in AHI) (Appendix F Figure 7).

##### ESS

Four trials reported ESS.^204,207,208,213^ Three of the four found statistically significant reductions in ESS, ranging from -3 to -7. Our meta-analysis found that weight loss interventions improved ESS more than controls (-3.4 [95% CI, -5.9 to -1.0]; 4 trials; 213 participants; I^2^=78%) (Appendix F Figure 15). The substantial statistical heterogeneity was reduced when removing the one trial that enrolled participants with mild OSA (Appendix F Figure 16).

##### Blood Pressure

Three trials reported blood pressure outcomes.^209-211^ One found similar blood pressure reductions for exercise training (N=27) and a stretching control (N=16) after 12 weeks, although it reported a slightly greater magnitude of reduction for the stretching control group (systolic blood pressure, -6.7 vs. -7.3; diastolic blood pressure, 0 vs. -2.7; between-group difference, 95% CI, or p-value not reported).^209^ Another trial (N=60) found no significant difference between a multicomponent lifestyle intervention and advice only at 13 weeks (mean difference, 0 [95% CI, -5 to 4]) or after another 13 weeks off treatment (mean difference, -2 [95% CI, -7 to 4]).^210^ The other trial (N=81) reported no significant difference between a very low calorie diet with supervised lifestyle counseling and a routine lifestyle counseling control group at 12 months (-1.7 vs. -1.1; p=0.88; and -1.9 vs. -0.4; p=0.62) or at 2-year postintervention followup.^211,212^

##### Subgroups

We found no studies that assessed whether the effect of weight loss interventions on intermediate outcomes differs for subgroups defined by age, sex, BMI, or severity of OSA.

### KQ 5 Benefits of Treatment for Improving Health Outcomes

We included 50 good- or fair-quality RCTs that reported at least one eligible health outcome (47 of these were included in KQ 4). Most of those were short-term RCTs (≤12 weeks) that reported zero or few deaths over the course of the study. The characteristics of these studies are summarized in Appendix E Tables 13–16, and the results are summarized in Appendix E Tables 17–19.

#### CPAP

Thirty-five RCTs comparing CPAP with sham CPAP^128,130,137-139,142,145,147,150,151,154,155,157,161-164,166, 168,172,215^ or another control^170,172-178,180,182-184,216,217^ reported at least one eligible health outcome. Most trials identified participants from sleep clinics or referrals, and none focused on persons who were screen-detected in primary care settings. Ten trials were conducted in the United States;^139,145,147,150,155,157,166,178,183,215^ others were set in Canada,^184^ Australia,^140,161,173^ New Zealand,^151^ Hong Kong,^180^ United Kingdom,^142,162-164,168,174-177,182,216,217^ and Spain.^128,130,137,138,154, 170,172^ Most trials followed participants for 12 weeks or less; four trials measured outcomes over 24 weeks or longer,^145,172,174,182^ including one that followed participants for a median of 4 years.^172^ Most trials enrolled populations with a mean age in the 40s to 50s (range, 42 to 71 years). The vast majority of participants in most trials were men; women made up a third or less of the enrolled population in 26 trials. All eight trials that described race enrolled a majority of white participants. Mean BMI was 30 to 35 kg/m^2^ in most trials (range, 27 to 37 kg/m^2^). Mean or median baseline AHI (or similar measure) was in the severe OSA range (AHI ≥30) for more than half of trials; nine trials reported it in the moderate OSA range,^150,151,155,162,173,178,180,182,216^ and five reported it in the mild OSA range.^166,174,176,183,217^ The range of OSA severity of enrolled participants in trials most frequently spanned the moderate to severe range (27 trials) or the mild to severe range (15 trials). Six trials limited participants to more narrow ranges: mild only,^176^ mild to moderate,^151,166,173,183^ or severe only.^130^ One trial did not report sufficient data to determine the range of OSA severity of participants.^174^ Mean or median baseline ESS was 10 or greater in most trials (23), indicating excessive daytime sleepiness. Five trials reported a mean baseline ESS of less than 10,^130,138,162,172,174^ and seven trials did not report baseline ESS.

##### Mortality

Thirty-one RCTs reported on mortality (Appendix E Table 17). The vast majority (29 RCTs) reported mortality rates at 12 weeks or less, and the vast majority (27 RCTs; 2,211 total participants) reported no deaths in any study group;^128,130,137,139,140,142,147,150,151,154,155,157,162-164,166, 170,173,175-178,180,183,184,216,217^ two trials (462 total participants) reported one death, either in the CPAP^174^ or sham CPAP group at 12 weeks.^138^ Two RCTs assessed mortality over a longer duration.^145,172^ One (N=1,105) reported two deaths in each study arm over 24 weeks.^145^ The other (N=723) reported eight deaths in the CPAP group and three in the control group over about 4 years (incidence density ratio, 2.6 [95% CI, 0.70 to 11.8]; p=0.16).^172^

##### Quality of Life

Twenty-two RCTs reported quality-of-life measures (Appendix E Table 17). Fourteen measured quality of life using the Medical Outcome Short-Form (36-Item) Health Survey (SF-36).^130,138,142, 151,154,163,164,166,173,174,176,180,182,183^ Only one RCT (N=179) reported changes in total SF-36 scores; at 12 weeks, participants randomized to CPAP showed greater improvement than controls in the total SF-36 score (mean change from baseline, 4.7 vs. 2.0; p<0.05).^173^ Most studies using the SF-36 reported changes separately for the physical component score (PCS) and the mental component score (MCS). Some studies only reported data for all or some of the eight subscales of the SF-36. Eight trials reported sufficient data for meta-analysis of SF-36 MCS.^130,138,142,154,163, 164,166,174^ Seven of these compared CPAP with sham CPAP and reported outcomes at 12 weeks or less; one trial compared CPAP with another control and reported outcomes at 24 weeks.^174^ Our meta-analysis found no difference between CPAP and comparators in the change from baseline SF-36 MCS (WMD, 1.2 [95% CI, -0.8 to 3.2]; 8 trials; 1,039 participants) (Appendix F Figure 42). Seven trials reported sufficient data for meta-analysis of SF-36 PCS;^130,138,142,154,163, 164,166^ all compared CPAP with sham and reported outcomes at 12 weeks or less. Our meta-analysis found that CPAP improved scores significantly more than sham (WMD, 2.3 [95% CI, 0.2 to 4.4]; 7 trials; 648 participants) (Appendix F Figure 43). Both meta-analyses found moderate statistical heterogeneity.

Seven RCTs measured general quality of life using another measure (Appendix E Table 17). Two RCTs measured changes in quality of life using the EuroQol.^137,174^ In one trial (N=323), there was no difference between CPAP and control groups in the change from baseline total score at 24 weeks.^174^ The other trial (N=340) only reported within-group changes; the CPAP group improved at 12 weeks (p<0.001 compared with baseline; effect size [standard deviation units] 0.38), but no improvement was seen in the control group.^137^ Five RCTs assessed quality of life using the Nottingham Health Profile. Three of them found no difference between groups in the change from baseline overall scores,^175,176,217^ one reported greater improvement in the CPAP group compared with controls (4.9 vs. 7.9 [lower scores indicate greater improvement]; p=0.002),^216^ and one reported only outcomes for six subscore domains (greater improvement for CPAP than control on two of six scores) (Appendix E Table 17).^170^

Thirteen RCTs assessed sleep-related quality of life—six using the Sleep Apnea Quality of Life Index (SAQLI)^164,168,174,180,182,218^ and seven using the Functional Outcomes of Sleep Questionnaire (FOSQ).^130,151,154,161,166,173,177^ Most trials reported outcomes at 12 weeks or less; two reported outcomes at 24 weeks (or 6 months)^174,218^ and one at 52 weeks.^182^ Eight trials compared CPAP with sham,^130,151,154,161,164,166,168,218^ and the others compared CPAP with another control.^173,174,177,180,182^ Our meta-analysis (combining SAQLI and FOSQ scores) found that CPAP was associated with improved sleep-related quality-of-life scores compared with controls (SMD, 0.28 [95% CI, 0.14 to 0.42]; 13 trials; 2,325 participants) (Appendix F Figure 44). Our sensitivity analysis including only studies with mean baseline ESS of 10 or greater found a slightly greater but similar effect size (0.33 [95% CI, 0.17 to 0.50]; 9 trials; 1,709 participants) (Appendix F Figure 46).

##### Cognitive Impairment

Twelve RCTs reported one or more measures of cognitive function.^130,145,147,151,170,173,175,176,182,215-217^ In general, studies assessed cognitive function using heterogeneous outcome measures and reported inconsistent results (Appendix E Table 17).

##### Motor Vehicle Accidents

Three RCTs reported on the incidence of motor vehicle accidents. In one trial (N=212), there were no accidents in either group at 12 weeks.^178^ The other two reported similar rates between CPAP and comparator groups over 24 weeks (10 vs. 11 accidents out of 1,105 participants)^145^ or over 1 year (2 vs. 1 accidents out of 278 participants).^182^

##### Cardiovascular Events

Eight RCTs reported on the incidence of one or more cardiovascular events.^138,145,151,168,172,174,178, 182^ Five (1,529 total participants) reported on the incidence of myocardial infarction; a total of one myocardial infarction occurred (combined) in either group (the control group) across four of the trials over 3 weeks to 1 year.^151,174,178,182^ The trial with the longest duration (723 participants) reported two myocardial infarctions in the CPAP group and eight in the control group over 4 years.^172^

Four RCTs reported on the incidence of angina^138,174,182^ or unstable angina;^178^ trial durations were 52 weeks,^182^ 24 weeks,^174^ and 12 weeks.^138,178^ Overall, too few events occurred to draw conclusions (CPAP vs. comparators: total of 4 vs. 9 angina events among a total of 570 participants).^138,174,178,182^

Three RCTs reported on the incidence of atrial fibrillation; trial durations were 12 weeks,^178^ 24 weeks,^174^ and 1 year.^182^ In the trial measuring outcomes at 12 weeks, one participant developed atrial fibrillation (randomized to the control group);^178^ in the trials assessing outcomes at 6 months and 1 year (669 total participants), there was no difference in the incidence of atrial fibrillation between groups (12 vs. 19 events).^182^

One RCT reported one event in either group for each of the following (details are provided in Appendix E Table 17): unspecified tachyarrhythmia requiring hospitalization,^178^ percutaneous coronary intervention for worsening angina,^178^ and emergent cardiac surgery.^168^ One trial reported only an overall number of cardiovascular events (as adverse events) without describing how outcomes were measured or defined (31 vs. 29 events in CPAP and control arms, respectively).^145^ One trial reported hospitalizations for unstable angina or arrhythmia (17 vs. 11 in CPAP and control arms, respectively, out of 723 participants).^172^

##### Cerebrovascular Events

Four included RCTs (1,604 total participants) reported on the incidence of transient ischemic attacks^172,174,182^ and/or strokes.^172,174,178,182^ Trial durations were 12 weeks,^178^ 24 weeks,^174^ 1 year,^182^ and 4 years (median followup).^172^ Overall, too few events were observed to draw conclusions (CPAP vs. comparators: total of 4 vs. 7 transient ischemic attacks and 3 vs. 3 strokes, combining all trials). The trial with the longest followup (723 participants with median followup of 4 years) reported the most observed events, reporting fewer transient ischemic attacks in the CPAP group than in the control group (2 vs. 5) but more nonfatal strokes (3 vs. 2).^172^

##### Heart Failure

In one RCT (N=723), three participants in the CPAP group developed new heart failure compared with five in the control group over a median followup of 4 years.^172^

##### Headaches

In one RCT (N=37), three participants in the control group developed headaches at 4 weeks compared with none in the CPAP group.^176^

##### Subgroups

The APPLES (Apnea Positive Pressure Long-term Efficacy Study) trial found no significant overall difference between CPAP and sham CPAP for improvement in quality of life after 6 months.^218^ However, subgroup analyses stratified by OSA severity found that greater improvement in quality of life may occur for persons with severe OSA treated with CPAP who used it more than 4 hours per night (compared with those treated with sham CPAP; between-group difference on SAQLI, 0.2; p<0.05).^218^ We found no other studies that reported difference for the effect of CPAP on health outcomes for subgroups defined by age, sex, BMI, or severity of OSA.

#### MADs

We included six RCTs assessing the effect of MADs on health outcomes, including mortality, quality of life, cognitive impairment, and cardiovascular events (Appendix E Table 13).^173,180, 189,191,197,214^ None of the included studies reported the incidence of cerebrovascular events, heart failure, or headaches. Two studies compared MADs with sham devices that did not advance the mandible,^189,191^ one compared an MAD with a placebo tablet,^173^ two compared MADs with no treatment,^197,214^ and one compared an MAD with conservative management of OSA with weight loss.^180^ All studies recruited participants with known or suspected OSA from specialty clinics, such as sleep medicine or otolaryngology. Four studies were conducted in Europe, one in Australia,^173^ and one in Hong Kong.^180^ Treatment durations ranged from 4 to 12 weeks for most studies, while one lasted for only 1 week^214^ and one for 24 weeks.^189^ Mean age of participants ranged from 45 to 51 years in all studies. The vast majority of participants were men, with women comprising 18 to 27 percent in the five trials reporting sex. No studies reported percentage of minority participants. All studies included participants with mild to moderate OSA, and three also included participants with severe OSA.^180,191,214^

##### Mortality

Among the four trials that reported on mortality over 1 to 12 weeks,^173,191,197,214^ three of the trials reported no deaths in any participants. The other trial reported one death in the group that received no treatment.^191^

##### Quality of Life

Five included trials reported at least one quality-of-life measure.^173,180,189,191,197^ All five used the SF-36, two also used the SAQLI,^180,197^ and two also used the FOSQ.^173,197^ Because of heterogeneity in the reporting of SF-36 outcomes, the results were not amenable to meta-analysis. Overall, results were mixed, with some studies finding no significant benefits of MADs for improving quality of life,^180,189^ some reporting possible benefits for some measures or subscales but not others,^173,191^ and some reporting benefits for some overall quality-of-life scores.^197^ Further details and specific data are provided in Appendix E. Because of inconsistency, imprecision, and heterogeneity of reporting, findings are insufficient to make conclusions about the potential benefits of MADs for improving quality of life.

##### SF-36

The trial (N=39) that compared an MAD with a sham device for 24 weeks found no significant differences in multiple SF-36 subscores.^189^ A four-arm crossover trial (N=90) of three different types of MADs compared with no treatment found significant improvement in the SF-36 PCS for a SleepPro2 (MEDiTAS, Milton Keynes, UK) MAD only, and the SF-36 MCS for a custom MAD only.^197^ A trial (N=67) that compared an MAD with conservative management found no significant difference in SF-36 Physical Function, Mental Health, and General Health subscores.^180^ Another trial (N=93) that compared an MAD with a sham device or no treatment found no significant benefit for SF-36 PCS but reported some improvement for SF-36 MCS scores (although it was unclear if the improvement was significantly greater than that with controls because of how the findings were reported).^191^ A trial (N=197) that compared 12 weeks of an MAD with placebo tablet found a significant improvement in overall SF-36 score from baseline but not compared with placebo tablet.^173^

##### Disease-Specific Quality-of-Life Measures

The trial that compared an MAD with conservative management for 10 weeks found significant improvements in Emotional and Symptoms subscores but not in total SAQLI score.^180^ The four-arm crossover trial that compared three types of MADs (each for 6 weeks) found significant improvement in total SAQLI score for all devices and nearly all subscores for all devices.^197^ The trial that compared an MAD with a placebo tablet reported significant improvement in mean FOSQ score at 12 weeks but not in subscores other than Social Outcomes.^173^

##### Other Health Outcomes

We included one trial assessing each of the following outcomes for participants using MADs over 6 to 12 weeks: cognitive impairment,^173^ motor vehicle accidents,^197^ and cardiovascular events.^197^ Specific data are provided in Appendix E. Because of unknown consistency, imprecision, and very limited numbers of events, findings are insufficient to make conclusions about the potential benefits of MADs for these outcomes.

##### Subgroups

We found no studies that assessed whether the effect of MADs on health outcomes differs for subgroups defined by age, sex, BMI, or severity of OSA.

#### Airway Surgery

Four of the five included RCTs evaluating ENT surgeries described in KQ 4 reported at least one included health outcome (Appendix E Table 18).^198,201-203^ Each trial evaluated a different surgical technique, including radiofrequency surgery of the soft palate,^198^ TCRFTA,^203^ LAUP,^201^ and septoplasty.^202^ These studies are described in detail in KQ 4.

##### Mortality

Three RCTs reported no deaths in any study arms over 12 weeks to around 15 months.^198,201,202^

##### Quality of Life

Three RCTs reported quality-of-life measures (Appendix E Table 18). Two trials (92 participants combining both trials) measured general quality of life using the SF-36; there were no differences between groups in change from baseline for PCS or MCS over 8 to 24 weeks.^198, 203^ Two trials measured sleep-related quality of life.^201,203^ The trial (N=46) comparing LAUP with no treatment found no significant difference between groups for overall SAQLI scores but reported a difference for the SAQLI Symptoms subscore.^201^ The trial (N=60) comparing TCRFTA with sham surgery reported greater improvement in overall FOSQ scores for the TCRFTA group (between-group difference, 0.9 [95% CI, -0.1 to 1.9]; one-sided p=0.04) but no difference on the Symptoms of Nocturnal Obstruction and Related Events score.^203^

##### Cognitive Impairment

One RCT (N=60) comparing TCRFTA with sham surgery found no difference between groups in three measures of reaction times measured using the Psychomotor Vigilance Task (slowest reaction time, median reaction time, and fastest reaction time).^203^

##### Subgroups

We found no studies that assessed whether the effect of airway surgery on health outcomes differs for subgroups defined by age, sex, BMI, or severity of OSA.

#### Bariatric Surgery

One RCT (N=60) compared bariatric surgery with a conventional weight loss program in persons with severe OSA (mean AHI ranged from 57 to 65 across study arms);^200^ characteristics are described in KQ 4 and Appendix E Table 18. There were no deaths in either group at 2 years. At 2 years, participants randomized to bariatric surgery had greater improvement in quality of life measured by the SF-36 PCS (between-group difference, 9.3 [95% CI, 0.5 to 18.0]; p=0.04); however, there was no difference between groups in the change from baseline SF-36 MCS (between-group difference, -0.3 [95% CI, -5.3 to 4.8]; p=0.92).^200^ One person in the bariatric surgery arm developed headaches during the study compared with no participants in the conventional weight loss group.^200^

#### Weight Loss Programs

Six RCTs (described in nine articles) evaluated weight loss programs; the characteristics are described in detail in KQ 4 and Appendix E Table 18.^204-213^

##### Mortality

Four RCTs (45 participants combining all studies) assessed mortality; three reported no deaths in any group over 9 to 208 weeks,^205,207,208^ and one reported one death at 52 weeks (it was not reported which study arm the person was in).^211^

##### Quality of Life

Four RCTs assessed quality of life.^204,208,210,211^ Two measured general quality of life using the SF-36;^204,208^ both reported on scores across the eight domains but did not report a PCS, MCS, or overall score (detailed results are in Appendix E Table 18). In one trial comparing an inpatient weight loss program with a control, the authors only provide within-group changes from baseline; the control group did not improve in any of the eight SF-36 domain scores, while the weight loss program group improved significantly on most domain scores (except for vitality and emotional role limitation).^204^ The trial of very low calorie diet plus supervised lifestyle compared with usual care found no difference between groups in the mean change from baseline 15-dimensional measure of health-related quality-of-life scores at 52 weeks (mean change from baseline score, 0.041 vs. 0.022; p=0.167).^211^ One RCT measured changes in sleep-related quality of life using the FOSQ; there was no difference between groups in change from baseline scores (p-value was not significant, per authors).^208^ Finally, the RCT that compared a multicomponent lifestyle intervention with advice only for obese long-term CPAP users found no difference on the EuroQol EQ-5D-3L Visual Analogue Scale between groups at the end of the 13-week treatment phase (between-group mean difference, 3 [95% CI, -4 to 10]), but it reported greater improvement for the intervention group 13 weeks after the treatment phase ended (between-group mean difference, 9 [95% CI, 2 to 16]).^210^

##### Cognitive Impairment

One trial comparing exercise training with a stretching control assessed for changes in cognitive function over 12 weeks with the Psychomotor Vigilance Test, Stroop Color-Word Test, and Trail-Making Test; there were no difference between groups on any of these measures.^208^

### KQ 6 Association Between OSA and Health Outcomes

We included 11 fair- or good-quality prospective cohort studies (described in 12 articles) that assessed the association between AHI and health outcomes (Appendix E Table 20).^50,219-229^ All focused on community-based participants; one also enrolled some participants from a sleep clinic.^50^ Three good-quality studies analyzed participants from the Sleep Heart Health Study (SHHS),^224,225,227^ a cohort of men and women age 40 years or older recruited from other prospective cohort studies (e.g., Framingham Offspring and Omni Study, Atherosclerosis Risk in Communities Study) between 1995 and 1998. Two included studies evaluated the WSCS,^221,226^ a community-based, random sample of state-employed adults ages 30 to 60 years. Two articles reported data from the same study (Busselton Health Study) for different durations of followup.^228,229^

Six studies (described in seven articles) reported the association with all-cause mortality;^220,221, 223,226-229^ three with cardiovascular mortality;^50,226,227^ two with cardiovascular events;^50,224^ and one each with cancer-related mortality,^221^ stroke,^225^ cognitive decline,^219^ and cognitive impairment or dementia.^222^ We found no eligible studies reporting on the association between AHI and quality of life, motor vehicle accidents, or headaches. Two studies that evaluated the association between AHI and stroke^230,231^ and one that evaluated the association between AHI and cognitive function were excluded because of poor quality (Appendix D Table 11).^232^

Nine of 11 studies were conducted in the United States, one was conducted in Spain,^50^ and one was conducted in Australia.^228^ Most studies followed patients for 8 to 14 years; followup ranged from a mean of 3.4^220^ to 22 years.^221^ Three studies included only men; half of the studies included between 45 and 56 percent women. Two studies did not report the proportion of nonwhite participants;^50,228^ other studies reported a range from 5 to 26 percent. Mean BMI ranged from 26 to 30 kg/m^2^ in most studies. Most studies did not report mean AHI or mean ESS at baseline. The percentage of participants with diabetes ranged from 3 to 13 percent among studies reporting it.

Participants were generally untreated for OSA or analyses excluded those who were treated. Eight of the 11 studies reported either excluding persons who received treatment from the study or running additional analyses that excluded those who were treated; the percentage of participants who were treated was low, ranging from 0 to 9.9 percent. Two of the smallest included studies (total sample sizes of 393^229^ and 289^223^) did not report the percentage who were treated for OSA but reasoned that any potential treatment would only have resulted in their data underestimating the true HR. One study reporting the association between AHI and stroke included 1.9 percent (102/5,422) who were treated with CPAP during the study and did not report sensitivity analyses that excluded those participants.^225^

#### All-Cause Mortality

Six studies (described in seven articles) evaluated AHI as a predictor of all-cause mortality.^220,221, 223,226-229^ These included two studies reporting on WSCS participants^221,226^ and two articles (one study) reporting on different lengths of followup for the Busselton Health Study.^228,229^ Sample sizes ranged from 289^223^ to 6,294.^227^ Mean duration of followup ranged from 3.4^220^ to 20 years.^229^ Mean age ranged from 48^226^ to 78 years.^223^

In multivariate analyses, all included studies reported that persons with severe or moderate to severe OSA at baseline had a higher risk of death. HRs ranged from 1.46^227^ to 6.24.^228^ Variables included in the models are detailed in Appendix E Table 21. Briefly, all included age and some medical conditions in the final model; all considered BMI (although it did not remain in the final model in one study); most included smoking, sex, race, hypertension or blood pressure, and diabetes. Our meta-analysis of five studies (using one of the two publications from the WSCS to avoid double-counting and using the article reporting longer followup for the Busselton Health Study) found that persons with severe or moderate to severe OSA died at about twice the rate of controls (Figure 3) (HR, 2.07 [95% CI, 1.48 to 2.91]). The analysis found moderate statistical heterogeneity (I^2^=58%), likely due to variation in AHI thresholds for the study groups (e.g., using 15, 20, or 30 to define the highest risk group), duration of followup, and approach to analyses (i.e., variables included in multivariate models).

Figure 3 Association Between AHI and All-Cause Mortality, by OSA Severity

Abbreviations: AHI=apnea-hypopnea index; OSA=obstructive sleep apnea.

Figure 3 displays a forest plot of studies reporting the association between AHI and all-cause mortality, stratified by OSA severity. Our meta-analysis of 5 studies (using 1 of the 2 publications from the WSCS to avoid double-counting and the article reporting longer followup for the Busselton Health Study) found that people with severe or moderate to severe OSA died at about twice the rate of controls (hazard ratio, 2.07 [95% CI, 1.48 to 2.91]). Two studies using data from the SHHS or WSCS assessed whether moderate (AHI of 15 to <30) or mild (AHI 5 to <15) OSA levels are associated with mortality. Neither of the 2 studies nor our pooled analyses found a statistically significant association between moderate or mild OSA and all-cause mortality.

Two studies using data from the SHHS^227^ or the WSCS^226^ assessed whether moderate (AHI, 15 to <30) or mild (AHI, 5 to <15) OSA is associated with mortality. Neither of the individual studies nor our pooled analyses found a statistically significant association between moderate or mild OSA and all-cause mortality (Figure 3).

Two of the included studies reported evidence for subgroups—either by sex and age^227^ or by presence of sleepiness.^223^ The former used the SHHS data (N=6,294) and reported that the association between an AHI of 30 or greater and mortality was only statistically significant for men age 70 years or younger (adjusted HR, 2.09 [95% CI, 1.31 to 3.33]) but not for men older than age 70 years (HR, 1.27 [95% CI, 0.86 to 1.86]) or for women of any age (HR, 1.40 [95% CI, 0.89 to 2.22]).^227^ The latter found that the association between an AHI of 20 or greater and death was limited to those with excessive daytime sleepiness (determined by self-report of having a problem with feeling sleepy or struggling to stay awake during the daytime ≥3 or ≥4 times a week) but was not significant for those without excessive daytime sleepiness (HR, 2.28 [95% CI, 1.46 to 3.57] vs. 0.74 [95% CI, 0.39 to 1.38]) compared with a reference group with an AHI of less than 20 and no excessive daytime sleepiness.

#### Cardiovascular Mortality

Three studies evaluated the association between AHI and cardiovascular mortality.^50,226,227^ Sample sizes ranged from 1,522^226^ to 6,294.^227^ Mean duration of followup ranged from 8.2^227^ to 13.8 years.^226^ Mean age ranged from 48^226^ to 63 years.^227^

In multivariate analyses, all three studies reported that persons with severe or moderate to severe OSA at baseline had a higher risk of death (Figure 4). We did not pool data from these three studies because of substantial heterogeneity; the SHHS only reported data for men and used different AHI thresholds than the other two studies (combining moderate and severe OSA vs. reporting data for severe OSA separately). It reported the smallest association (men only: HR, 1.69 [95% CI, 1.13 to 2.52]) and noted that an association between moderate to severe OSA and cardiovascular mortality was not identified for women.^227^ For the other two studies, HRs ranged from 2.9 to 5.9. The strongest association was reported by the WSCS (HR, 5.9 [95% CI, 2.6 to 13.3]; when excluding those treated with CPAP: HR, 5.2 [95% CI, 1.4 to 19.2]).^226^ Variables included in the models are detailed in Appendix E Table 21. Briefly, all included age, BMI, smoking, and multiple medical conditions or used matching for age and BMI. Two of three included alcohol use, blood pressure, and cholesterol.

Figure 4 Association Between AHI and Cardiovascular Mortality, by OSA Severity

Abbreviations: AHI=apnea-hypopnea index; OSA=obstructive sleep apnea.

Figure 4 displays a forest plot of studies reporting change in AHI and cardiovascular mortality, stratified by OSA severity. In multivariate analyses, all 3 studies reported that persons with severe or moderate to severe OSA at baseline had a higher risk of death. We did not pool data from these 3 studies because of substantial heterogeneity; the SHHS only reported data for men and used different AHI thresholds than the other 2 studies. It reported the smallest association (men only: HR, 1.69 [95% CI, 1.13 to 2.52]) and noted that an association between moderate to severe OSA and cardiovascular mortality was not identified for women. For the other 2 studies, hazard ratios ranged from 2.9 to 5.9. The strongest association was reported by the WSCS (HR, 5.9 [95% CI, 2.6 to 13.3]).

#### Cancer-Related Mortality

One publication used a 22-year followup of the WSCS cohort (N=1,522) to evaluate the association between AHI and cancer-related mortality.^221^ Participants had a mean age of 48 years, 45 percent were female, and mean BMI was 30 kg/m^2^. Fifty participants had cancer-related deaths (eight from lung cancer; four each from colorectal, ovarian, and endometrial cancer; three each from brain, breast, and bladder cancer; and multiple other cancers causing one or two deaths each). The study reported a significant association between an AHI of 30 or greater and cancer-related mortality (HR, 4.8 [95% CI, 1.7 to 13.2]), and results suggested a dose-response association between AHI and cancer-related mortality (Appendix E Table 21) (HR for mild OSA, 1.1 [95% CI, 0.5 to 2.7]; HR for moderate OSA, 2.0 [95% CI, 0.7 to 5.5]). The model included adjustment for age, sex, BMI, and smoking; additional adjustment for alcohol use, physical activity, educational status, diabetes, waist circumference, and sleep duration did not materially change results (data not reported). Similarly, analyses stratified for sleepiness and obesity found no clinically important differences. Analyses removing those treated with CPAP resulted in slightly increased HRs (data not reported).

#### Cardiovascular Events

Two studies following patients for approximately 8 to 10 years evaluated the association between AHI and cardiovascular events (Appendix E Table 20).^50,224^ Sample sizes were 1,651^50^ and 4,422.^224^ One was conducted in Spain; one was conducted in the United States and reported on participants from the SHHS.^224^ Mean ages of participants were 50^50^ and 63 years.^224^ One evaluated men only;^50^ slightly more than half were women in the other.^224^

The two studies reported different outcomes. The Spanish study reported 144 total nonfatal cardiovascular events (including nonfatal myocardial infarction, nonfatal stroke, coronary bypass surgery, and percutaneous transluminal coronary angiography).^50^ In multivariate analyses, those with untreated severe OSA at baseline had a higher risk of events (OR, 3.17 [95% CI, 1.12 to 7.52]), adjusted for age; hypertension; presence of cardiovascular disease (ischemic heart disease, congestive heart disease, or cerebrovascular disease); diabetes; lipid disorders; smoking status; alcohol use; systolic and diastolic blood pressure; blood glucose; total cholesterol; triglycerides; and current use of antihypertensive, lipid-lowering, and antidiabetic drugs; they also matched for age and BMI.

The SHHS study reported 473 total incident coronary heart disease events (composite of first occurrence of myocardial infarction, coronary heart disease deaths, and revascularization procedures) and 308 total incident heart failure events.^224^ Neither incident coronary heart disease nor incident heart failure were associated with OSA (of any severity) for men or women when adjusting for age, race, BMI, smoking, total and high-density lipoprotein cholesterol, lipid-lowering medications, diabetes mellitus, systolic and diastolic blood pressure, and use of antihypertensive medications (Appendix F Figure 47 and Appendix E Table 22). However, in the subgroup of men age 70 years or younger, participants with an AHI of 30 or greater were more likely to develop coronary heart disease than those with an AHI less than 5 (adjusted HR, 1.68 [95% CI, 1.02 to 2.76]).

#### Stroke

One good-quality publication from the SHHS (N=5,422) evaluated the association between AHI and ischemic stroke over a median followup of 8.7 years.^225^ Participants in the various AHI categories had median ages of 62 to 75 years, 55 percent were female, and mean BMI was 28 kg/m^2^. All participants were untreated for OSA. Incident ischemic strokes occurred in 193 participants. The study separated results by sex (Appendix E Table 22). For men, moderate to severe OSA (using AHI ≥19, the highest quartile for the study participants, vs. AHI <4) was associated with ischemic stroke (HR, 2.86 [95% CI, 1.10 to 7.39]). For women, the study did not find a statistically significant association (HR, 1.21 [95% CI, 0.65 to 2.24]). HRs for severe OSA (AHI ≥30) were not reported. The models adjusted for age, BMI, smoking status, systolic blood pressure, use of antihypertensive medications, diabetes status, and race (secondary analyses also addressed atrial fibrillation; including it did not materially change the findings).

#### Cognitive Impairment or Dementia

One study evaluated the association between AHI and cognitive impairment or dementia among 298 older women (mean age, 82 years).^222^ Mean BMI was 28 kg/m^2^. Incident mild cognitive impairment or dementia occurred in 107 participants over a mean followup of 4.7 years. Participants with an AHI of 15 or greater had an increased risk of developing cognitive impairment or dementia compared with participants with an AHI less than 15 (OR, 1.85 [95% CI, 1.11 to 3.08]) when adjusted for age, race, BMI, education level, smoking status, presence of diabetes, presence of hypertension, antidepressant use, benzodiazepine use, and use of nonbenzodiazepine anxiolytics. Additional adjustment for baseline cognitive test scores strengthened the association (OR, 2.36 [95% CI, 1.34 to 4.13]).

Although we found no studies evaluating cognitive impairment or dementia per se among men, one study evaluated the association between AHI and cognitive decline among 2,636 community-dwelling men age 67 years or older in the Outcomes of Sleep Disorders in Men study.^219^ Cognitive decline was assessed using the Trails B and the Modified Mini-Mental State Examination. After 3.4 (median) years of followup, participants with an AHI of 15 or greater did not have an increased risk of cognitive decline compared with participants with an AHI less than 15 using either outcome measure (OR, 1.14 [95% CI, 0.84 to 1.54] and 0.99 [95% CI, 0.79 to 1.24], respectively) when adjusted for age, site, race, BMI, education, number of depressive symptoms, history of diabetes, history of stroke or transient ischemic attack, history of hypertension, history of coronary heart disease, history of Parkinson's disease, impairment in instrumental activities of daily living, benzodiazepine use, antidepressant use, self-reported health status, physical activity, alcohol use, and smoking status.

### KQ 7 Harms of Screening or Diagnostic Testing

We found no eligible studies that addressed this question.

### KQ 8 Harms Associated With Treatment

Reporting of harms in the included studies was sparse. Most did not report any information about harms. Twenty-two of the RCTs included in KQ 4 reported on harms associated with treatments for OSA. These included nine trials of CPAP,^141,145,150,163,166,167,176,180,183^ eight of MADs,^180,189-191, 193,195,197,214^ one of a very low energy diet,^207^ four of airway surgeries,^198,199,201,203^ and one of bariatric surgery.^200^ Characteristics of all 22 studies have been described in previous sections of this report. Detailed results of studies reporting harms are provided in Appendix E Tables 23–26.

#### CPAP

Of the nine included RCTs, six compared CPAP with a sham device, two compared CPAP with usual care,^180,183^ and one compared CPAP with an oral placebo capsule.^176^ Most studies enrolled fewer than 100 persons; one study^166^ enrolled 281 participants, and the APPLES trial^145^ enrolled 1,098 participants. The majority of enrollees were male, mean age ranged from 42 to 61 years, and most participants were overweight or obese (mean BMI, 27 to 39 kg/m^2^). Most of the studies followed patients for 8 to 12 weeks. In general, the adverse events related to CPAP treatment were likely short-lived and could be alleviated with discontinuation of CPAP or additional interventions. Overall, 2 to 47 percent of participants in trials reporting any harms had specific adverse events while using CPAP. These included oral or nasal dryness, eye or skin irritation, rash, epistaxis, and pain.

Across four studies,^150,167,180,183^ 11 percent of patients receiving therapeutic CPAP reported irritation compared with 1 percent of control patients. In one study,^145^ rash was reported by significantly more patients receiving therapeutic CPAP than participants receiving sham (18% vs. 11%; p=0.001). One study reported three nosebleeds: one in the CPAP group (2%) and two in the control group (4%).^183^ In two studies, 12 and 47 percent of patients reported oral or nasal dryness in the therapeutic CPAP group compared with no reports in the usual care arm.^176,180^ Pain was reported in two trials.^167,176^ In one, there was one report each (2%) of ear pain and noncardiac chest pain in the therapeutic CPAP arm; no control patients reported pain.^167^ In the other, no active CPAP patients reported pain compared with one control patient (3%) who reported chest and arm pain.^176^ None of the studies reported the need for additional sleep medication, excess salivation, or tooth damage or loosening.

#### MADs

Eight RCTs reported harms of MAD use.^180,189-191,193,195,197,214^ Most studies lasted 4 to 6 weeks, one lasted a single week,^214^ one lasted 10 weeks,^180^ one lasted 12 weeks,^190^ and one lasted 24 weeks.^189^ Across three studies that reported any discontinuation because of adverse events, 7 percent of active MAD patients discontinued use due to harms compared with 1 percent of control patients.^180,191,197^ No studies reported rashes, claustrophobia, nosebleeds, or the need for additional sleep medications.

In four studies, rates of oral dryness ranged from 5 to 33 percent with active MADs compared with 0 to 3 percent with control.^180,189,190,197^ Five studies reported rates of excess salivation.^180,189, 190,192,197^ Three of these reported excessive salivation rates ranging from 23 to 68 percent in the active treatment arms compared with 0 to 3 percent in the sham or no treatment groups.^180,189,197^ One reported a higher rate of excessive salivation in the sham MAD arm than in the active treatment arm (58% and 36%, respectively).^190^ The remaining study reported no significant difference in excess salivation between MAD and sham groups but did not report numbers of patients.^192^

All eight RCTs reporting harms included some report of oral mucosal, dental, or jaw symptoms, including mucosal or dental pain, discomfort or tenderness, mucosal erosions, jaw or temporomandibular joint pain or discomfort that occurred either upon waking or persistent, jaw occlusal changes, and jaw muscle discomfort. In seven studies, adverse oral mucosal, dental, or jaw symptoms ranged from 17 to 74 percent in MAD groups compared with 0 to 17 percent in sham, no treatment, or conservative management groups. One study reported only that there was a statistically significant difference in jaw discomfort and tooth tenderness in the MAD group compared with sham.^192^

#### Airway Surgery

Four included studies assessed harms of surgical treatment: one each of single-session soft palate radiofrequency surgery,^198^ TCRFTA,^203^ UPPP,^199^ and LAUP.^201^ Two of the trials had sham surgery comparison groups;^198,203^ the rest compared surgery with no treatment or usual care. Sample size was fewer than 70 in all trials, and the majority of patients were male, overweight, and middle aged. No studies reported perioperative death, nerve palsy, need for additional emergency surgery, cardiovascular events, respiratory failure, or airway stenosis.

Overall, less than 1 to 81 percent of participants in trials reporting any harms had harms from surgery. These included postoperative bleeding; rehospitalization; difficulty speaking, breathing, drinking, opening the mouth, and swallowing; change in vocal quality; hematomas; ulcerations; infections; temporary nasal regurgitation; and pain. In the trial that compared LAUP with no treatment,^201^ 17 participants (81%) reported moderate to severe pain, nine (33%) reported mild to severe hemorrhaging, one (5%) reported a change in vocal quality, five (24%) reported temporary nasal regurgitation, and four (19%) reported mild infections. In the Sleep Apnoea Karolinska UPPP (SKUP^3^) trial,^199^ four UPPP patients (13%) reported pain and two (6%) reported postoperative bleeding. In the trial that compared TCRFTA with sham surgery, patients in both arms reported similar increases in pain 1 week after the procedure (up to 1.6 to 1.8 out of 10; difference was not statistically significant). Pain ratings returned to baseline by 3 weeks postprocedure. Rates of other harms did not differ between groups either. There were six reported hematomas: three in the treatment group (12%) and three in the control group (11%), and one ulceration reported in the treatment group. The trial of single-session soft palate radiofrequency surgery^198^ reported that participants in the treatment group gave significantly higher ratings of pain, speaking problems, and swelling sensations (within 1 to 6 days after surgery) than sham surgery patients (data not reported, shown in figure only).

#### Bariatric Surgery

In the trial of bariatric surgery compared with a conventional weight loss program,^200^ one surgical patient was rehospitalized because of an acute proximal gastric pouch dilation causing obstructive symptoms and requiring elective laparoscopic replacement of the adjustable gastric banding.

#### Weight Loss, Diet, and Exercise Interventions

The single weight loss study that reported harms compared a very low energy diet with usual diet over 9 weeks.^207^ In the very low energy diet group, less than 10 percent of patients reported each of the following: constipation, elevated alanine aminotransferase concentrations, dizziness, gout, and dry lips.