# Chapter 2 Methods

## Key Questions and Analytic Framework

The Evidence-based Practice Center investigators, USPSTF members, and AHRQ Medical Officers developed the scope and Key Questions (KQs). Figure 1 shows the analytic framework and KQs that guided the review.

Figure 1 Analytic Framework

Abbreviations: AHI =apnea-hypopnea index; KQ =Key Question; OSA =obstructive sleep apnea.

Key Questions to Be Systematically Reviewed

1a Does screening for obstructive sleep apnea (OSA) in adults improve health outcomes?
1b Does the evidence on screening for OSA in adults differ for subgroups defined by age, sex, body mass index (BMI), or OSA severity?
2a What is the accuracy of currently existing clinical prediction tools or screening questionnaires in identifying persons in the general population who are more or less likely to have OSA?
2b What is the accuracy of multistep screening approaches, such as using a questionnaire or prediction tool followed by overnight home-based testing, in identifying persons in the general population who are more or less likely to have OSA?
3a What is the accuracy and reliability of diagnostic tests for OSA?
3b Do the accuracy and reliability of diagnostic tests for OSA differ for subgroups defined by age, sex, or BMI?
4a How much does treatment with continuous positive airway pressure (CPAP), mandibular advancement devices, surgery, or weight loss programs improve intermediate outcomes (i.e., the apnea-hypopnea index [AHI], blood pressure, or sleepiness) in persons with OSA?
4b Do the benefits of treatment (for intermediate outcomes) differ for subgroups defined by age, sex, BMI, or OSA severity?
5a Does treatment with CPAP, mandibular advancement devices, surgery, or weight loss programs improve health outcomes in persons with OSA?
5b Do the benefits of treatment (for health outcomes) differ for subgroups defined by age, sex, BMI, or OSA severity?
6 Is there an association between AHI and health outcomes?
7a Are there harms associated with screening or diagnostic testing for OSA?
7b Do the harms of screening or diagnostic testing differ for subgroups defined by age, sex, or BMI?
8a Are there harms associated with treatment of OSA?
8b Do the harms of treatment differ for subgroups defined by age, sex, BMI, or OSA severity?

This figure is the proposed analytic framework depicting the eight key questions and the research approach that will guide the evidence review. In general, the figure illustrates the overarching question (key question 1): whether screening adults for obstructive sleep apnea (OSA) leads to improved health outcomes. The framework starts on the left with the patient population of interest: asymptomatic adults. Moving from left to right, the figure depicts the availability of clinical prediction tools or screening questionnaires that distinguish people who are more or less likely to have OSA (key question 2) and the accuracy and reliability of diagnostic tests for OSA (key question 3). There are potential harms of screening and diagnostic tools (key question 7). For adults with OSA, treatment may improve intermediate outcomes, such as the apnea-hypopnea index, blood pressure, and daytime sleepiness (key question 4), and also health outcomes, such as mortality, quality of life, motor vehicle crashes, cardiovascular and cerebrovascular events, heart failure, headaches, and cognitive impairment (key question 5). Treatment may also result in harms (key question 8). The framework also includes assessment of the evidence supporting an association between the apnea-hypopnea index and the aforementioned health outcomes (key question 6).

## Data Sources and Searches

We searched PubMed/MEDLINE, the Cochrane Library, and EMBASE for English-language articles published through October 25, 2015, with surveillance of the literature through October 5, 2016. We used Medical Subject Headings as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, tests, interventions, outcomes, and study designs. Complete search terms and limits are listed in Appendix B1. We conducted targeted searches for unpublished literature by searching ClinicalTrials.gov and the World Health Organization International Clinical Trials Registry Platform. To supplement electronic searches, we reviewed the reference lists of pertinent review articles and studies that met our inclusion criteria, and added all previously unidentified relevant articles. We reviewed all literature suggested by peer reviewers or public comment respondents and incorporated eligible studies into the final review.

## Study Selection

We developed inclusion and exclusion criteria for populations, interventions, comparators, outcomes, timing, settings, and study designs with input from the USPSTF (Appendix B2). We included English-language studies of adults age 18 years or older conducted in countries categorized as “very high” on the Human Development Index. We excluded studies of children, adolescents, pregnant women, and adults with acute stroke or other acute conditions that can trigger onset of OSA and studies focused on screening, diagnosis, or treatment of OSA among persons with rare conditions (e.g., acromegaly) for whom testing for OSA would be considered part of management for their disease (rather than screening and primary prevention).

For KQs 1 (direct evidence that screening improves health outcomes) and 2 (accuracy of clinical prediction tools or screening questionnaires), we required studies to enroll asymptomatic adults or persons with unrecognized symptoms of OSA; referral populations were not eligible. For KQ 1, randomized, controlled trials (RCTs) comparing screened with nonscreened groups were eligible. For KQ 2, prospective cohort studies and cross-sectional studies that evaluated screening questionnaires or clinical prediction tools (alone or followed by a home-based PM) compared with overnight PSG conducted in a sleep laboratory were eligible. Studies assessing single patient characteristics or risk factors were not eligible; clinical prediction tools were required to include multiple factors. We excluded studies of persons referred to sleep laboratories because of concern for OSA and excluded studies where only a subgroup (usually the highest risk group) had PSG because of concern for verification bias.

For KQs 3 (accuracy and reliability of diagnostic tests) and 7 (harms associated with screening and diagnostic tests), referral populations were also eligible (in addition to the populations that were eligible for KQs 1 and 2). For KQ 3, good-quality, recent (within 5 years) systematic reviews comparing PMs (including Type II, III, and IV monitors) with formal, attended PSG conducted in a sleep laboratory (Type I) were eligible for inclusion (Table 2). Given that we identified multiple good-quality, recent, and directly relevant systematic reviews for KQ 3, our results for KQ 3 mainly describe previously published systematic reviews. We also included primary studies published after the search cutoff of the most recent systematic reviews (to look for any new studies that might change the findings of previously published systematic reviews). For KQ 7, studies eligible for KQ 1, 2, or 3 that reported false-positive results leading to unnecessary treatment, anxiety, condition-specific distress, or stigma were eligible.

For KQs on benefits (4 and 5) and harms (8) of treatment, RCTs of persons with a confirmed diagnosis of OSA were eligible; studies could include asymptomatic and/or symptomatic adults. We included studies evaluating CPAP, MADs, surgery, and weight loss programs; other treatments were not eligible (e.g., oropharyngeal exercises). For KQ 8, prospective cohort studies with at least 100 participants that reported harms of surgical interventions were also eligible.

For KQ 6 (association between OSA and health outcomes), we included prospective cohort studies that followed participants for at least 1 year and evaluated the association between AHI and health outcomes (by comparing persons with higher vs. lower AHI and following them for incident events). We excluded studies without an attempt to handle potential confounding (e.g., through multivariable analysis and/or restriction), those focused primarily on central sleep apnea, those enrolling patients hospitalized for acute events (e.g., myocardial infarction), and those enrolling patients in a periprocedural period (e.g., ablation for atrial fibrillation). Good-quality, recent (within 5 years), and directly relevant systematic reviews were eligible. However, of the three recent systematic reviews identified,^1,91,92^ none met our criteria for direct relevance and good quality; all were rated as fair quality for the information related to KQ 6, and all of them differed from our eligibility criteria (e.g., by combining community-based and referral populations). Therefore, we did not include any previously published systematic reviews for KQ 6.

Two investigators independently reviewed titles and abstracts; those marked for potential inclusion by either reviewer were retrieved for evaluation of the full text. Two investigators independently reviewed the full text to determine final inclusion or exclusion. Disagreements were resolved by discussion and consensus.

## Quality Assessment and Data Abstraction

For each included study, one investigator extracted pertinent information about the methods, populations, interventions, comparators, outcomes, timing, settings, and study designs. A second team member reviewed all data extractions for completeness and accuracy.

We assessed the quality of studies as good, fair, or poor, using predefined criteria developed by the USPSTF and adapted for this topic (Appendix B3).^93^ Two independent reviewers assigned quality ratings for each study. Disagreements were resolved by discussion with an experienced team member. We included only studies rated as having good or fair quality.

## Data Synthesis and Analysis

We qualitatively synthesized findings for each KQ by summarizing the characteristics and results of included studies in tabular and narrative format. To determine whether meta-analyses were appropriate, we assessed the clinical and methodological heterogeneity of the studies following established guidance.^94^ We qualitatively assessed the populations, tests, treatments, comparators, outcomes, and study designs, looking for similarities and differences. Eligible outcomes for this review covered a wide range of measures; key measures and questionnaires are summarized in Appendix B4.

For KQ 3, when qualitatively evaluating likelihood ratios, we considered positive likelihood ratios (LR+) to indicate a minimal (1–2), small (2–5), moderate (5–10), or large/high (>10) increase in the risk of OSA. We considered negative likelihood ratios (LR-) to indicate a minimal (0.5–1), small (0.2–0.5), moderate (0.1–0.2), or large (<0.1) decrease in the risk of OSA. Likelihood ratios below 0.1 or above 10 are typically thought to provide strong evidence for ruling out (LR- <0.1) or ruling in (LR+ >10) diagnoses.^95,96^

For KQs 4 and 5, when multiple similar studies were available, we used random-effects models using the inverse-variance weighted method (DerSimonian and Laird) to estimate pooled effects.^97^ For continuous outcomes (e.g., AHI, blood pressure), we calculated the weighted mean difference (WMD) between intervention and control; when multiple scales were combined in one meta-analysis (for sleep-related quality of life), we used the standardized mean difference (SMD), Cohen's d. For Cohen's d, a small effect size is 0.20, medium effect size is 0.50, and large effect size is 0.80.^98^ Whenever possible, we used the number of all randomized patients as the denominator to reflect a true intention-to-treat analysis. For our meta-analyses of CPAP and MAD treatments, we stratified analyses by comparison groups, providing pooled estimates for studies using sham controls (e.g., a sham CPAP device) separately from those not using sham controls. We combined parallel trials and crossover trials but conducted subgroup analyses to explore whether findings differed by this study design feature.

For KQ 6, we conducted meta-analyses of adjusted hazard ratios (HRs) and 95 percent CIs for all-cause mortality (the only outcome for KQ 6 with a sufficient number of similar studies). We used random-effects models to estimate pooled effects. We converted HRs to a log scale and calculated standard errors of log HRs to normalize distributions and stabilize variances. We then used the metan command with the eform command in Stata (StataCorp, College Station, TX) to estimate pooled HRs. We stratified analyses by AHI thresholds corresponding to OSA severity categories. For outcomes other than all-cause mortality, we produced forest plots showing results of individual studies but did not estimate pooled effects because we found too few studies.

For all quantitative syntheses, the chi-squared statistic and the I^2^ statistic were calculated to assess statistical heterogeneity in effects between studies.^99,100^ An I^2^ from 0 to 40 percent might not be important, 30 to 60 percent may represent moderate heterogeneity, 50 to 90 percent may represent substantial heterogeneity, and 75 percent or greater represents considerable heterogeneity.^101^

We conducted several types of subgroup analyses and sensitivity analyses to explore heterogeneity or robustness of findings. We performed subgroup analyses by OSA severity, baseline sleepiness, and baseline blood pressure.

Quantitative analyses were conducted using Comprehensive Meta-Analysis version 3.3 (Biostat, Inc., Englewood, NJ) and Stata version 14.

## Expert Review and Public Comment

A draft report was reviewed by content experts, representatives of federal partners, USPSTF members, and AHRQ Medical Officers and was revised based on comments, as appropriate. It was also posted for public comment.

## USPSTF Involvement

This review was funded by AHRQ. AHRQ staff and USPSTF members participated in developing the scope of the work and reviewed draft manuscripts, but the authors are solely responsible for the content.