# Chapter 1 Introduction

## Scope and Purpose

This report will be used by the U.S. Preventive Services Task Force (USPSTF) to inform a recommendation on the topic of screening for obstructive sleep apnea (OSA) in adults. The USPSTF has not previously made a recommendation on sleep apnea. The purpose of this report is to systematically evaluate the current evidence on screening for and treatment of OSA for populations and settings relevant to primary care in the United States. In this report, we summarize the evidence on the benefits and harms of screening for and treatment of OSA and the characteristics of diagnostic tests.

## Condition Definition

OSA occurs when airflow is absent or substantially reduced because of upper airway obstruction, but breathing effort persists. It can be categorized as mild, moderate, or severe based on the number of apnea and hypopnea events per hour (Table 1). It is different from central apnea, in which both airflow and breathing effort are absent.

Table 1 Definitions

Term | Definition
Apnea | Cessation of airflow for at least 10 seconds^8,275^
Hypopnea | Reduction in airflow by at least 30% for at least 10 seconds with decrease in oxygen saturation
Apnea-hypopnea index (AHI)^*^ | Number of apnea and hypopnea events per hour of sleep
Obstructive sleep apnea (OSA)
Mild^8,73^ | AHI ≥5 to <15
Moderate^8,73^ | AHI ≥15 to <30
Severe^8,73^ | AHI ≥30
Obstructive sleep apnea syndrome | AHI ≥5 with evidence of daytime sleepiness^3,8,276^

* The respiratory disturbance index (RDI) is a similar measure to AHI, but it also includes the number of respiratory effort–related arousals per hour of sleep (in addition to apnea and hypopnea events).

Abbreviations: AHI=apnea-hypopnea index; OSA=obstructive sleep apnea; RDI=respiratory disturbance index.

OSA severity is usually categorized using the apnea-hypopnea index (AHI) as assessed by a sleep study (polysomnography [PSG]). The AHI incorporates both obstructive and central apnea and hypopnea events, and significantly elevated AHI itself is not synonymous with OSA (because it can indicate OSA, central sleep apnea, or mixed sleep apnea—both OSA and central sleep apnea). The existing literature has used a range of AHI diagnostic thresholds, from 5 to 20^1^ episodes per hour for OSA. Both the Centers for Medicare & Medicaid Services and the American Academy of Sleep Medicine define OSA as an AHI or respiratory disturbance index of at least 15 events per hour, or at least 5 events per hour with documented symptoms (e.g., excessive daytime sleepiness, impaired cognition, mood disorders, or insomnia; waking up breath-holding, gasping, or choking; or documented hypertension, ischemic heart disease, or history of stroke).^2,3^

## Etiology and Natural History

Persons with OSA have frequent cessation or reduction of airflow during sleep that results in oxygen desaturation and arousals from sleep. Upper airway obstruction during sleep is often associated with anatomical abnormalities or obesity-related peripharyngeal fat that cause narrowing of respiratory passages, decreased pharyngeal muscle tone, and insufficient neuromuscular responses to airway obstruction.^4-6^ One longitudinal population-based study of nearly 700 adults (Wisconsin Sleep Cohort Study [WSCS]) found that about 6 percent of 45-year-olds with mild OSA progressed to moderate or severe OSA over 4 years; participants whose body weight increased by at least 10 percent had a 6-fold increased risk of developing moderate or severe OSA.^7^ Much variation in development of moderate to severe OSA, however, was not accounted for by weight change. Many adverse clinical outcomes have been associated with sleep apnea (see Prevalence and Burden below); in particular, untreated, severe OSA (AHI >30) is associated with increased all-cause mortality.^1^

### Risk Factors

Risk factors for OSA include male sex (odds ratio [OR], 3.1 [95% (confidence interval) CI, 2.5 to 3.8]),^8^ increasing age (40 to 70 years), higher body mass index (BMI), craniofacial and upper airway abnormalities (e.g., children with retrognathia or micrognathia), and postmenopausal status (OR, 3.5 to 4.3 for AHI ≥15).^4,7-22^ Persons with OSA (especially moderate to severe OSA) have an increased incidence of hypertension, although the presence of hypertension is not useful in detecting persons at increased risk of OSA.^8^ Smoking, alcohol use, sedative use, and nasal congestion have been suspected but have sparse or mixed evidence.^8,23-30^

## Prevalence and Burden

Reported estimates of prevalence vary, likely because of the variation in the definitions of OSA used (i.e., different AHI cutoffs), sampling biases, year of publication, or combinations of these factors.^31^ A 2013 systematic review estimated a prevalence range of 2 to 14 percent among four community-based studies after correcting for oversampling.^8^ The two U.S.-based studies that were included found about 10 percent^15^ with mild OSA and 3.8^32^ to 6.5^15^ percent with moderate or severe OSA when using data from the 1990s. However, prevalence is increasing due to rising rates of obesity.^33,34^ Extrapolation of long-term followup data (from 1988–1994 to 2007–2010) from one of the U.S. cohorts estimated a 16 percent prevalence for mild OSA and 10 percent for moderate or severe OSA (AHI ≥15).^33^ Evidence about the prevalence of severe OSA (AHI ≥30) is scant, although clearly this prevalence would be lower than the prevalence of combined moderate and severe OSA. The prevalence of severe OSA that would be detected by screening is unknown, including asymptomatic individuals (or individuals with unrecognized symptoms) who are unaware of their diagnosis.

Prevalence appears to increase with age through the sixth to seventh decade and then plateaus.^14, 16,17^ OSA is approximately 2 to 3 times more common in men than in women, although the gap narrows at the age of menopause in women.^15-17,35^ Data published in 2009 (N=1,500) and 2013 (N=1,520) estimated the prevalence around 15 percent in men and 5 percent in women when using either an AHI threshold of 15 or using a combination of AHI of at least 5 with at least one symptom of disturbed sleep.^33,34^

Many adverse clinical outcomes have been associated with sleep apnea. The various adverse outcomes are thought to be primarily due to chronic disturbances in gas exchange (e.g., hypercapnia and hypoxemia), sympathetic nervous system arousal (i.e., oxidative stress caused by intermittent hypoxemia leading to sympathetic activation), and fragmented sleep. Untreated, severe OSA (AHI ≥30) is associated with increased all-cause mortality.^1^ However, there is controversy in the literature regarding the extent to which OSA independently contributes to various adverse outcomes beyond the contributions of age, BMI, and other potential confounders. OSA is associated with several cardiovascular risk factors, making it more difficult to establish an independent association between OSA and cardiovascular disease. The adverse clinical outcomes of untreated OSA that have been reported in various studies include increased risk of motor vehicle and other accidents;^36-42^ cognitive impairment;^13,43^ lost work days,^44^ work disability,^45^ and impaired work performance;^46^ decreased quality of life;^47^ and mortality.^34,39,48,49^ In addition, bidirectional associations between OSA and the following have been reported: cardiovascular events,^48,50^ coronary heart disease and heart failure,^49,51-55^ angina,^56,57^ atrial fibrillation,^58^ stroke,^49,59^ hypertension,^7,12,34,60-63^ and diabetes and metabolic syndrome.^64-67^ Appendix A provides additional details related to prevalence and burden of OSA.

## Rationale for Screening

In theory, screening to identify unrecognized OSA followed by appropriate treatment could improve sleep quality and normalize AHI and oxygen saturation levels to prevent adverse health outcomes. Potential screening strategies include formal screening questionnaires and clinical prediction tools that include various combinations of subjective and objective findings. For persons who screen positive, a diagnostic test would be used to determine whether they have OSA—either a formal PSG in a sleep facility or home-based testing with a portable monitor (PM).

### Screening Strategies

The available screening questionnaires and clinical prediction tools attempt to identify persons at higher risk of sleep apnea. Many of them combine questions about symptoms with objective findings (e.g., BMI). Screening questionnaires that could be considered for use in primary care include the Epworth Sleepiness Scale (ESS),^68^ the STOP Questionnaire (Snoring, Tiredness, Observed Apnea, High Blood Pressure),^69^ STOP-Bang Questionnaire (STOP Questionnaire plus BMI, Age, Neck Circumference, and Gender),^70^ the Berlin questionnaire,^71^ and the Wisconsin Sleep Questionnaire.^15^ Previous reviews found that most tools were validated in referral settings (using populations with a higher prevalence of OSA) and not in the general population.^8^ Thus, the accuracy and reliability of these tools in general primary care settings were unclear.

The current diagnostic standard for OSA is technologist-attended PSG conducted in a sleep laboratory facility.^72^ The use of PSG for diagnosis requires measurement of the following physiologic signals: electroencephalogram, electrooculogram, chin electromyelogram, airflow, oxygen saturation, respiratory effort, and electrocardiogram or heart rate.^73^ Additional recommended measurements include body position and leg movements.^73^ The frequency of events is typically reported as an AHI.^73^ In-laboratory PSG is costly and potentially inconvenient for patients. PMs have been proposed as an alternative.^74^ Sleep study monitors are generally classified by the signals recorded^75^: Type I is facility-based PSG; Type II monitors are portable but record the same information as facility-based monitors (perhaps with fewer channels); Type III monitors are portable and have at least two respiratory channels but do not record the channels that differentiate between sleep and wake; and Type IV includes all PMs that fail to meet Type III criteria (Table 2).

Table 2 Classification of Monitors Used for Diagnosis of Obstructive Sleep Apnea^*^

Type | Portability | Number of Channels | Typical Parameters | ≥2 Airflow or Effort Channels | Measures AHI
I | Facility-based | ≥7 (Usually 12–16) | EEG, EOG, EMG, ECG/HR, airflow (nasal and/or oral), respiratory effort (thoracic or abdominal movement), SaO_2_, body position, leg movement, snoring | Yes | Yes
II | Portable | ≥7 | EEG, EOG, EMG, ECG or HR^†^, airflow, respiratory effort (thoracic or abdominal movement), SaO_2_ | Yes | Yes
III | Portable | ≥4 (Usually 4–7) | Ventilation and/or airflow, respiratory effort (thoracic or abdominal movement), ECG or HR, SaO_2_ | Yes | No
IV | Portable | ≥1 (Usually 1–3) | Usually SaO_2_^ǂ^; may include additional channels provided the monitor doesn't qualify as Type III^§^ | No | No

* Modified with permission from a previous systematic review^1^; personal communication with Dr. Ethan Balk, October 5, 2015.

† Heart rate is allowed in place of electrocardiogram in Type II portable monitors. Type II monitors usually measure the same channels as Type I monitors but are portable.

ǂ Unlike other monitor types that measure SaO_2_ by oximetry, Type IV monitors may measure SaO_2_ by oximetry and/or airflow.

§ Parameters that are more commonly measured by Type IV portable monitors include but are not limited to snoring, body position, leg movement, peripheral arterial tone, and plethysmograph.

Abbreviations: AHI=apnea-hypopnea index; ECG=electrocardiogram; EEG=electroencephalogram; EMG=electromyogram; EOG=electrooculogram; HR=heart rate; SaO_2_=arterial O_2_ saturation.

## Treatment Approaches

Continuous positive airway pressure (CPAP) is the standard first-line treatment for OSA.^76^ CPAP devices deliver compressed air into the airway, aiming to keep the airway open. The 2013 clinical practice guideline from the American College of Physicians (ACP) recommends 1) that all overweight and obese patients with OSA be encouraged to lose weight (strong recommendation, low-quality evidence), 2) CPAP as initial therapy for patients diagnosed with OSA (strong recommendation, moderate-quality evidence), and 3) mandibular advancement devices (MADs) as an alternative therapy to CPAP for patients with OSA who prefer them or for those with adverse effects associated with CPAP (weak recommendation, low-quality evidence). The ACP concluded that evidence to ascertain the efficacy or comparative efficacy of other therapies that have been studied for OSA was insufficient.^76^ These included positional therapy, oropharyngeal exercise, palatal implants, surgical interventions, pharmacologic therapy, and atrial overdrive pacing.

Types of surgical procedures that have been studied or used for OSA include nasal and nasopharyngeal procedures, oral and oropharyngeal procedures, hypopharyngeal and laryngeal procedures, global airway procedures, and upper airway bypass. Specific procedures include uvulopalatopharyngoplasty (UPPP), in which tissue is removed from the throat and the rear of the mouth; maxillomandibular advancement, in which the jaw is surgically moved forward; soft palate implants; nasal polyp removal; tonsillectomy; and tracheostomy. Bariatric surgery for obese patients with OSA has been reported to have positive effects on AHI or sleep-related symptoms.^77-79^ Both a 2011 comparative effectiveness review for the Agency for Healthcare Research and Quality (AHRQ)^1^ and the related ACP clinical practice guideline^76^ concluded that evidence on surgical interventions was insufficient (mainly because each of the seven included studies assessed a different treatment and outcomes were inconsistent).

Published data on the frequency of use of different treatments are limited. The available data suggest that CPAP is by far the most commonly used treatment and that surgical treatments are rarely used.^80,81^

## Current Clinical Practice in the United States

Most primary care clinicians do not routinely screen for OSA, and most patients do not discuss their sleep-related symptoms with their primary care clinician; a practice-based research network study of 44 randomly selected practices found that only 20 percent of patients (who regularly visit primary care clinicians) with sleep-related symptoms spontaneously reported their symptoms to their primary care clinician.^82-86^ Providers may be unsure about how to identify and diagnose OSA.^83,87-90^ There is uncertainty regarding which type of sleep-monitoring devices are best for diagnosing OSA^75^ and how to follow patients who have been diagnosed with OSA.

Several guidelines have been issued related to screening, evaluation, and treatment of patients suspected of having OSA (Appendix A).