# Appendix G Summary of Contextual Questions and Where They Are Addressed in the Report

1a What is the rate of adherence to CPAP, mandibular advancement devices, and weight loss interventions among persons with OSA?
1b How effective are interventions designed to enhance adherence to CPAP?
  CQ1 is addressed in the Discussion, last paragraph under “Benefits and Harms of Treatment for OSA” (pg 37). That entire paragraph is related to CQ 1a and 1b. Briefly, a wide range of adherence to CPAP usage recommendations has been reported, ranging from about 30 to 85 percent. A systematic review reported that 14 to 32 percent of patients discontinue CPAP over 4 years and patients use CPAP for an average of 5 hours per night; data were too limited to provide adherence rates for MADs. A recent Cochrane systematic review of 33 studies (2,047 participants) found low- to moderate-quality evidence that three types of interventions can increase CPAP machine usage in CPAP-naive participants with moderate to severe OSA syndrome. However, they noted that trials did not assess people who have struggled to adhere to treatment and the impact of improved CPAP usage on daytime sleepiness, quality of life, and long-term cardiovascular risks remains unclear.
  For weight loss interventions, a wide range of adherence has been reported. A systematic review of interventions for improving nutrition and physical activity behaviors reported that adherence to attending intervention programs ranged from 33.0 percent to 95.0 percent and that retention rates ranged from 43 percent to 96 percent (mean 80%).^296^ The review for the USPSTF on behavioral counseling to promote physical activity and a healthful diet to prevent cardiovascular disease in adults noted that most trials did not report adherence to interventions.^297^ The review for the USPSTF on counseling to promote a healthy lifestyle in persons with cardiovascular risk factors^298^ noted that many intensive combined lifestyle and diet-only interventions would require resources that are not currently available or paid for and that “…fidelity of and adherence to counseling interventions should be routinely reported to better understand the applicability of behavioral counseling trial findings”. A systematic review that reported adherence to self-monitoring activities in weight loss interventions^299^ noted that “detailed measurement of adherence to self-monitoring has been reported infrequently; thus, little is known about the extent to which people adhere over time.” It concluded that the variability in measurement methods (for adherence) made it impossible to compare adherence across studies. Data from years 1 and 5 of the Women's Health Initiative Dietary Modification Trial (N∼50,000), in which participants were randomly assigned to a low-fat dietary intervention arm or usual diet control arm, suggest that long-term dietary change can be achieved (although it was in a clinical trial setting). The authors reported adherence to a low-fat dietary pattern (less than 20% energy from fat, five or more fruit/vegetable and six or more grain servings daily) assessed as the difference between groups in percent total energy from fat. The difference was 10.9 percentage points of energy from fat at Year 1 and 9.0 at Year 5.
2 What are the barriers to undergoing diagnostic testing for OSA (e.g., availability of polysomnography, ability to tolerate testing)? How often do those barriers prevent completion of testing?
  CQ2 is addressed in the Discussion, second paragraph under “Accuracy and Reliability of Diagnostic Tests” (pg 35). That entire paragraph is related to CQ 2. Briefly, barriers include limited availability of PSG, ability to tolerate testing, inconvenience, and costs. It is unclear how often those barriers prevent completion of testing. Mean time from referral to sleep clinic evaluation ranges from a few weeks to more than a year, with longer wait times for university, state, and federal government sleep lab facilities.
3 Is there an association between reduction in sleepiness and quality of life, work productivity, motor vehicle crashes, or other health outcomes?
  Some information related to this CQ was within 1 study in the results for KQ 6 (because one study assessing the relationship between AHI and all-cause mortality evaluated subgroups based on sleepiness). That study (last paragraph under the All-cause Mortality header in KQ 6, pg 28) found that the association between AHI ≥20 and death was limited to those with excessive daytime sleepiness (determined by self-report of having a problem with feeling sleepy or struggling to stay awake during the daytime ≥3 or 4 times a week) but was not significant for those without excessive daytime sleepiness (HR, 2.28; 95% CI, 1.46 to 3.57 vs. HR, 0.74; 95% CI, 0.39 to 1.38) compared with a reference group with AHI <20 and no excessive daytime sleepiness.
  CQ 3 is addressed also in the Discussion in under “Benefits and Harms of Treatment for OSA” (pg 35-36). One publication that used the nation-wide population-based Sleep Heart Health Study (SHHS) (n=5,816; mean age=63 years; 52.5% women) reported that EDS was strongly associated with reduced QoL even after adjusting for confounding variables (age, ethnicity) for both sexes. Sleepiness has been linked to motor vehicle crashes in multiple observational studies. A cross-sectional study of 913 employed adults from the general U.S. population (enrolled in the Wisconsin Sleep Cohort Study) found that men and women with AHI >15 were significantly more likely to have multiple accidents over the past 5 years (OR, 7.3; 95% CI, 1.8 to >25; adjusted for age, miles driven, and sex) using state records for motor vehicle accident history (retrospectively). The study was limited by the retrospective design and potential confounding. Considering education and usual alcohol consumption reportedly did not alter the odds ratio. None of their measures of perceived sleepiness (including those derived from ESS) were significantly related to accident occurrence. A cross-sectional study of 2,342 Australian commercial vehicle drivers found that the sleepiest five percent of drivers (based on ESS) had about twice the odds of a self-reported motor vehicle accident over the previous three years (OR, 1.91; 95% CI, 1.09 to 3.35) and even greater odds of multiple accidents over the previous three years (OR, 2.67; 95% CI, 1.29 to 5.52).
  Note that the various studies reporting associations between sleepiness and health outcomes do not establish the degree to which a reduction in sleepiness would result in improved health outcomes (and they are not all limited to people with OSA).
4 Is there an association between reduction in blood pressure and health outcomes?
  CQ 4 is addressed in the first paragraph under “Benefits and Harms of Treatment for OSA” (pg 35-36). Briefly, yes, data suggest that mean reductions of 2 to 3 mm Hg for systolic blood pressure (across a population) could result in a clinically significant reduction in cardiovascular mortality (by 4% to 5% for coronary heart disease and 6% to 8% for stroke).
5 What are clinically meaningful changes in the AHI, sleepiness (as measured by the Epworth Sleepiness Scale), and blood pressure?
  There is no clear numerical change in AHI that constitutes a clinically meaningful change for AHI. Reducing it from severe OSA levels to normal (<5) or near normal levels could possibly be clinically meaningful. Our KQ 6 findings suggest that it may be clinically meaningful, but empiric data to confirm that is lacking.
  CQ 5 is addressed also in the first paragraph under “Benefits and Harms of Treatment for OSA” (pg 35-36). Briefly, for sleepiness, the threshold for a clinically significant change in ESS is somewhat uncertain. Although a reduction from ESS ≥10 (indicating excessive daytime sleepiness) to one of <10 (considered the normal range) is likely clinically meaningful, recent systematic reviews found that some experts consider a 1 point change in ESS clinically significant. However, other sources suggest that a greater change, of at least 3 or 4 points, should be the clinically significant threshold. For example, some trials that use ESS as an outcome have considered a ≥ 4-point change in ESS as clinically significant for their sample size calculations or in their interpretation of findings.^242-244^ Also, the American College of Chest Physicians' outcome experts evaluating the ESS informally stated that a clinically significant change in the ESS is probably at least ≥3; a specific example cited was that a reduction by 1 point (e.g., from 3 [high] to 2 [moderate]) on two out of seven ESS domains was unlikely clinically relevant.
  For blood pressure reduction, some authors suggest that a difference of more than 9/10 mm Hg is clinically meaningful for individuals. However, across a population, guidelines have suggested that much smaller reductions of 2 to 3 mm Hg for systolic blood pressure could result in a clinically significant reduction in cardiovascular mortality (by 4% to 5% for coronary heart disease and 6% to 8% for stroke).
6 Is there an association between OSA and incident diabetes?
  CQ 6 is addressed in the Limitations section of the report when mentioning that we did not evaluate the association between AHI and incident diabetes (pg 38). A 2011 systematic review concluded that there may be an association but the strength of evidence was low and the association may be confounded by obesity. A more recent (2014) systematic review concluded that the association between OSA and incident diabetes is uncertain.