# Appendix F Results of Meta-Analyses

Appendix F Figure 1 AHI, CPAP vs. Control

This figure displays a forest plot showing a meta-analysis of 6 studies reporting change in AHI with CPAP or control. A negative difference in means favors CPAP. Meta-analysis of the 6 trials found a difference in means of -25.81 (95% CI, -34.17 to -17.45; I2=87%). The pooled estimates for crossover studies only and parallel studies only are -20.54 (95% CI, -32.40 to -8.68) and -31.02 (95% CI, -42.81 to -19.24), respectively.

Appendix F Figure 2 AHI, CPAP vs. Sham CPAP

This figure displays a forest plot showing a meta-analysis of 13 studies reporting change in AHI with CPAP or sham CPAP. A negative difference in means favors CPAP. Meta-analysis of the 13 trials found a difference in means of -33.82 (95% CI, -42.02 to -25.62; I2=85%). The pooled estimates for crossover studies only and parallel studies only are -30.33 (95% CI, -43.49 to -17.16) and -36.03 (95% CI, -46.51 to -25.55), respectively.

Appendix F Figure 3 AHI, CPAP vs. Any Inactive, Grouped by OSA Severity

This figure displays a forest plot showing a meta-analysis of 19 studies reporting change in AHI with CPAP or any inactive control, grouped by OSA severity. A negative difference in means favors CPAP. Meta-analysis of the 19 trials found a difference in means of -28.10 (95% CI, -39.95 to -16.24; I2=85%). The estimate from the 1 study of mild to moderate OSA was -15.50 (95% CI, -34.84 to 3.84). The estimate from the 7 studies of patients with the full range of OSA was -24.41 (95% CI, -32.70 to -16.13). The estimate from the 11 studies of patients with moderate to severe OSA was -39.01 (95% CI, -46.34 to -31.67). The estimate from the 1 study of patients with severe OSA only was -27.80 (95% CI, -49.68 to -5.92)

Appendix F Figure 4 AHI, MADs vs. Control

This figure displays a forest plot showing a meta-analysis of 5 studies (8 arms total) reporting change in AHI with MADs or control. A negative difference in means favors MADs. Meta-analysis of the 5 trials found a difference in means of -8.20 (95% CI, -13.89 to -2.50; I2=57%). The pooled estimates for crossover studies only and parallel studies only are -5.85 (95% CI, -7.80 to -3.90) and -11.20 (95% CI, -17.52 to -6.09), respectively.

Appendix F Figure 5 AHI, MADs vs. Sham MAD

This figure displays a forest plot showing a meta-analysis of 6 studies reporting change in AHI with MADs or sham MADs. A negative difference in means favors MADs. Meta-analysis of the 6 trials found a difference in means of -12.61 (95% CI, -15.54 to -9.69; I2=0%). The pooled estimates for crossover studies only and parallel studies only are -13.54 (95% CI, -17.55 to -9.53) and -11.56 (95% CI, -15.84 to -7.29), respectively.

Appendix F Figure 6 AHI, Lifestyle Intervention vs. Control

This figure displays a forest plot showing a meta-analysis of 5 studies reporting change in AHI with lifestyle intervention or control. A negative difference in means favors lifestyle intervention. Meta-analysis of the 5 trials found a difference in means of -12.42 (95% CI, -19.38 to -5.47; I2=79%).

Appendix F Figure 7 AHI, Lifestyle Intervention vs. Control, Sensitivity Analysis^a^

* We found substantial statistical heterogeneity (I^2^=79%) in the main analysis, which was no longer present after removing the one study with much larger weight reduction (and with the largest reduction in AHI).

This figure displays a forest plot showing a meta-analysis of 4 studies reporting change in AHI with lifestyle intervention or control, minus the study by Johansson et al. A negative difference in means favors lifestyle intervention. Meta-analysis of the 4 trials found a difference in means of -7.19 (95% CI, -10.03 to -4.36; I2=0%).

Appendix F Figure 8 AHI, Surgery vs. Control

This figure displays a forest plot showing results of 6 studies reporting change in AHI with surgery or control. A negative difference in means favors surgery. We did not pool the studies. The trials of UPPP and LAUP found greater reductions in AHI for surgery than for no treatment of -26.4 (95% CI, -36.2 to -16.6) and -10.5 (95% CI, -16.9 to –4.1), respectively. The other 3 trials (of radiofrequency surgery of the soft palate, TCRFTA, or septoplasty) all had sham comparators and found no clinically or statistically significant differences between various airway surgeries and sham.

Appendix F Figure 9 ESS, CPAP vs. Control

This figure displays a forest plot showing a meta-analysis of 12 studies reporting change in ESS with CPAP or control. A negative difference in means favors CPAP. Meta-analysis of the 12 trials found a difference in means of -2.19 (95% CI, -2.78 to -1.61; I2=84%). The pooled estimates for crossover studies only and parallel studies only are -2.47 (95% CI, -3.60 to -1.35) and -2.09 (95% CI, -2.77 to -1.41), respectively.

Appendix F Figure 10 ESS, CPAP vs. Sham CPAP

This figure displays a forest plot showing a meta-analysis of 22 studies reporting change in ESS score with CPAP or sham CPAP. A negative difference in means favors CPAP. Meta-analysis of the 22 trials found a difference in means of -2.00 (95% CI, -2.59 to -1.40; I2=76%). The pooled estimates for crossover studies only and parallel studies only are -1.86 (95% CI, -2.62 to -1.10) and -2.22 (95% CI, -3.19 to -1.25), respectively.

Appendix F Figure 11 ESS, CPAP vs. Any Inactive, Sensitivity Analysis With Only Studies With Baseline Mean ESS ≥10

This figure displays a forest plot showing a sensitivity meta-analysis of 27 studies with a mean ESS score at baseline greater than or equal to 10 reporting change in ESS with CPAP or any inactive control. A negative difference in means favors CPAP. Meta-analysis of the 27 trials found a difference in means of -2.37 (95% CI, -2.89 to -1.85; I2=78%).

Appendix F Figure 12 ESS, CPAP vs. Any Inactive, Grouped by OSA Severity

This figure displays a forest plot showing a meta-analysis of 33 studies reporting change in ESS score with CPAP or any inactive control, grouped by OSA severity. A negative difference in means favors CPAP. The estimate from the 5 studies of mild to moderate OSA was -1.69 (95% CI, -2.38 to -1.01). The estimate from the 10 studies of patients with the full range of OSA was -2.14 (95% CI, -2.96 to -1.33). The estimate from the 18 studies of patients with moderate to severe OSA was -2.35 (95% CI, -3.11 to -1.60).

Appendix F Figure 13 ESS, MADs vs. Control

This figure displays a forest plot showing a meta-analysis of 5 studies (8 arms total) reporting change in ESS score with MADs or control. A negative difference in means favors MADs. Meta-analysis of the 5 trials found a difference in means of -1.68 (95% CI, -2.19 to -1.17; I2=52%). The pooled estimates for crossover studies only and parallel studies only are -1.83 (95% CI, -2.45 to -1.21) and -1.39 (95% CI, -2.27 to -0.50), respectively.

Appendix F Figure 14 ESS, MADs vs. Sham MAD

This figure displays a forest plot showing a meta-analysis of 5 studies reporting change in ESS score with MADs or sham MADs. A negative difference in means favors MADs. Meta-analysis of the 5 trials found a difference in means of -1.48 (95% CI, -2.75 to -0.21; I2=34%). The pooled estimates and 95% CIs for crossover studies only and parallel studies only are -0.86 (-2.26 to 0.53) and -2.16 (-3.66 to -0.66), respectively.

Appendix F Figure 15 ESS, Lifestyle Intervention vs. Control

This figure displays a forest plot showing a meta-analysis of 4 studies reporting change in ESS score with lifestyle intervention or control. A negative difference in means favors lifestyle intervention. Meta-analysis of the 4 trials found a difference in means of -3.43 (95% CI, -5.92 to -0.95; I2=78%).

Appendix F Figure 16 ESS, Lifestyle Intervention vs. Control, Sensitivity Analysis^a^

^a^ The substantial statistical heterogeneity found in the main analysis was reduced when removing the one trial that enrolled participants with mild OSA.

This figure displays a forest plot showing a meta-analysis of 3 studies reporting change in AHI with lifestyle intervention or control, minus the study by Tuomilehto et al. A negative difference in means favors lifestyle intervention. Meta-analysis of the 3 trials found a difference in means of -4.42 (95% CI, -6.44 to -2.41; I2=47%).

Appendix F Figure 17 ESS, Surgery vs. Control

This figure displays a forest plot showing results of 6 studies reporting change in AHI with surgery or control. A negative difference in means favors surgery. We did not pool the studies. None of them found a statistically significant difference between participants in surgical and comparator groups.

Appendix F Figure 18 24-Hour Mean Arterial Pressure, CPAP vs. Control

This figure displays a forest plot showing a meta-analysis of 3 studies reporting change in 24-hour mean arterial pressure with CPAP or control. A negative difference in means favors CPAP. Meta-analysis of the 3 trials found a difference in means of -1.99 (95% CI, -3.99 to 0.02; I2=30%). The pooled estimates and 95% CIs for crossover studies only and parallel studies only are -1.00 (-2.59 to 0.59) and -3.05 (-4.83 to -1.28), respectively.

Appendix F Figure 19 24-Hour Mean Arterial Pressure, CPAP vs. Sham

This figure displays a forest plot showing a meta-analysis of 5 studies reporting change in 24-hour mean arterial pressure with CPAP or sham CPAP. A negative difference in means favors CPAP. Meta-analysis of the 5 trials found a difference in means of -2.07 (95% CI, -3.19 to -0.95; I2=3%). The pooled estimates and 95% CIs for crossover studies only and parallel studies only are -0.74 (-4.48 to 3.00) and -2.20 (-3.37 to -1.03), respectively.

Appendix F Figure 20 24-Hour Systolic Blood Pressure, CPAP vs. Control

This figure displays a forest plot showing a meta-analysis of 6 studies reporting change in 24-hour systolic blood pressure with CPAP or control. A negative difference in means favors CPAP. Meta-analysis of the 6 trials found a difference in means of -1.29 (95% CI, -2.85 to 0.26; I2=65%). The pooled estimates and 95% CIs for crossover studies only and parallel studies only are -1.18 (-2.84 to 0.48) and -2.08 (-6.46 to 2.29), respectively.

Appendix F Figure 21 24-Hour Systolic Blood Pressure, CPAP vs. Sham

This figure displays a forest plot showing a meta-analysis of 6 studies reporting change in 24-hour systolic blood pressure with CPAP or sham CPAP. A negative difference in means favors CPAP. Meta-analysis of the 6 trials found a difference in means of -2.13 (95% CI, -3.43 to -0.83; I2=0%). The pooled estimates and 95% CIs for crossover studies only and parallel studies only are -0.10 (-5.21 to 5.01) and -2.27 (-3.62 to -0.93), respectively.

Appendix F Figure 22 24-Hour Diastolic Blood Pressure, CPAP vs. Control

This figure displays a forest plot showing a meta-analysis of 6 studies reporting change in 24-hour diastolic blood pressure with CPAP or control. A negative difference in means favors CPAP. Meta-analysis of the 6 trials found a difference in means of -2.16 (95% CI, -3.80 to -0.51; I2=68%). The pooled estimates and 95% CIs for crossover studies only and parallel studies only are -1.09 (-3.79 to 1.62) and -2.79 (-4.86 to -0.71), respectively.

Appendix F Figure 23 24-Hour Diastolic Blood Pressure, CPAP vs. Sham

This figure displays a forest plot showing a meta-analysis of 6 studies reporting change in 24-hour diastolic blood pressure with CPAP or sham CPAP. A negative difference in means favors CPAP. Meta-analysis of the 6 trials found a difference in means of -1.91 (95% CI, -3.05 to -0.77; I2 =3%). The pooled estimates and 95% CIs for crossover studies only and parallel studies only are -1.47 (-6.78 to 3.84) and -1.93 (-3.10 to -0.76), respectively.

Appendix F Figure 24 Diurnal Mean Arterial Pressure, CPAP vs. Sham

This figure displays a forest plot showing a meta-analysis of 10 studies reporting change in diurnal mean arterial pressure with CPAP or sham CPAP. A negative difference in means favors CPAP. Meta-analysis of the 10 trials found a difference in means of -1.57 (95% CI, -3.12 to -0.01; I2 =57%). The pooled estimates and 95% CIs for crossover studies only and parallel studies only are -1.21 (-3.74 to 1.31) and -1.78 (-3.76 to 0.19), respectively.

Appendix F Figure 25 Diurnal Systolic Blood Pressure, CPAP vs. Control

This figure displays a forest plot showing a meta-analysis of 10 studies reporting change in diurnal systolic blood pressure with CPAP or control. A negative difference in means favors CPAP. Meta-analysis of the 10 trials found a difference in means of -1.58 (95% CI, -4.94 to 1.78; I2=75%). The pooled estimates and 95% CIs for crossover studies only and parallel studies only are 1.80 (-5.34 to 8.94) and -2.45 (-5.61 to 0.71), respectively.

Appendix F Figure 26 Diurnal Systolic Blood Pressure, CPAP vs. Sham

This figure displays a forest plot showing a meta-analysis of 15 studies reporting change in diurnal systolic blood pressure with CPAP or sham CPAP. A negative difference in means favors CPAP. Meta-analysis of the 15 trials found a difference in means of -2.39 (95% CI, -3.89 to -0.88; I2=0%). The pooled estimates and 95% CIs for crossover studies only and parallel studies only are -3.45 (-5.61 to -1.28) and -1.83 (-3.09 to -0.57), respectively.

Appendix F Figure 27 Diurnal Diastolic Blood Pressure, CPAP vs. Control

This figure displays a forest plot showing a meta-analysis of 10 studies reporting change in diurnal diastolic blood pressure with CPAP or control. A negative difference in means favors CPAP. Meta-analysis of the 10 trials found a difference in means of -2.09 (95% CI, -4.00 to -0.19; I2=57%). The pooled estimates and 95% CIs for crossover studies only and parallel studies only are -0.40 (-4.01 to 3.21) and -2.65 (-4.44 to -0.87), respectively.

Appendix F Figure 28 Diurnal Diastolic Blood Pressure, CPAP vs. Sham

This figure displays a forest plot showing a meta-analysis of 15 studies reporting change in diurnal diastolic blood pressure with CPAP or sham CPAP. A negative difference in means favors CPAP. Meta-analysis of the 15 trials found a difference in means of -1.28 (95% CI, -2.18 to -0.37; I2=16%). The pooled estimates and 95% CIs for crossover studies only and parallel studies only are -0.85 (-2.46 to 0.75) and -1.47 (-2.57 to -0.38), respectively.

Appendix F Figure 29 Nocturnal Mean Arterial Pressure, CPAP vs. Sham

This figure displays a forest plot showing a meta-analysis of 7 studies reporting change in nocturnal mean arterial pressure with CPAP or sham CPAP. A negative difference in means favors CPAP. Meta-analysis of the 7 trials found a difference in means of -2.26 (95% CI, -3.49 to -1.04; I2=0%). The pooled estimates and 95% CIs for crossover studies only and parallel studies only are -1.39 (-4.84 to 2.06) and -2.39 (-3.69 to -1.08), respectively.

Appendix F Figure 30 Nocturnal Systolic Blood Pressure, CPAP vs. Control

This figure displays a forest plot showing a meta-analysis of 4 studies reporting change in nocturnal systolic blood pressure with CPAP or control. A negative difference in means favors CPAP. Meta-analysis of the 4 trials found a difference in means of -4.40 (95% CI, -7.13 to -1.67; I2=0%).

Appendix F Figure 31 Nocturnal Systolic Blood Pressure, CPAP vs. Sham

This figure displays a forest plot showing a meta-analysis of 7 studies reporting change in nocturnal systolic blood pressure with CPAP or sham CPAP. A negative difference in means favors CPAP. Meta-analysis of the 7 trials found a difference in means of -2.58 (95% CI, -5.68 to 0.52; I2=0%). The pooled estimates and 95% CIs for crossover studies only and parallel studies only are 0.00 (-4.94 to 4.94) and -3.55 (-5.11 to -2.00), respectively.

Appendix F Figure 32 Nocturnal Diastolic Blood Pressure, CPAP vs. Control

This figure displays a forest plot showing a meta-analysis of 5 studies reporting change in nocturnal diastolic blood pressure with CPAP or control. A negative difference in means favors CPAP. Meta-analysis of the 5 trials found a difference in means of -2.10 (95% CI, -3.39 to -0.81; I2=64%). The pooled estimates and 95% CIs for crossover studies only and parallel studies only are 1.00 (-1.39 to 3.39) and -3.37 (-4.89 to -1.84), respectively.

Appendix F Figure 33 Nocturnal Diastolic Blood Pressure, CPAP vs. Sham

This figure displays a forest plot showing a meta-analysis of 7 studies reporting change in nocturnal diastolic blood pressure with CPAP or sham CPAP. A negative difference in means favors CPAP. Meta-analysis of the 7 trials found a difference in means of -1.25 (95% CI, -2.23 to -0.26; I2=0%). The pooled estimates and 95% CIs for crossover studies only and parallel studies only are -1.00 (-3.81 to 1.81) and -1.28 (-2.33 to -0.23), respectively.

Appendix F Figure 34 24-Hour Blood Pressure Measures, CPAP vs. Any Inactive in Patients With Hypertension

This figure displays a forest plot showing a meta-analysis of 4 studies that reported change in a 24-hour blood pressure measure with CPAP or any inactive control in patients with hypertension. A negative difference in means favors CPAP. The estimate from the 4 studies that reported 24-hour diastolic blood pressure was -1.99 (95% CI, -3.24 to -0.75). The estimate from the 3 studies of patients that reported 24-hour mean arterial pressure was -2.70 (95% CI, -4.77 to -0.63). The estimate from the 4 studies that reported 24-hour systolic blood pressure was -2.33 (95% CI, -3.97 to -0.69).

Appendix F Figure 35 Diurnal and Nocturnal Blood Pressure Measures, CPAP vs. Any Inactive in Patients With Hypertension

This figure displays a forest plot showing a meta-analysis of 6 studies that reported change in a diurnal or nocturnal blood pressure measure with CPAP or any inactive control in patients with hypertension. A negative difference in means favors CPAP. The estimate from the 5 studies that reported diurnal diastolic blood pressure was -2.06 (95% CI, -3.63 to -0.50). The estimate from the 4 studies of patients that reported diurnal mean arterial pressure was -1.80 (95% CI, -3.81 to 0.21). The estimate from the 5 studies that reported diurnal systolic blood pressure was -2.53 (95% CI, -4.37 to -0.68). The estimate from the 3 studies that reported nocturnal diastolic blood pressure was -1.77 (95% CI, -3.90 to 0.35). The estimate from the 3 studies that reported nocturnal mean arterial pressure was -2.29 (95% CI, -4.92 to 0.33). The estimate from the 3 studies that reported nocturnal systolic blood pressure was -4.09 (95% CI, -6.66 to -1.51).

Appendix F Figure 36 24-Hour Systolic Blood Pressure, MADs vs. Any Inactive

This figure displays a forest plot showing a meta-analysis of 3 studies reporting change in 24-hour systolic blood pressure with MADs or any inactive control. A negative difference in means favors MADs. Meta-analysis of the 3 trials found a difference in means of -0.68 (95% CI, -3.24 to 1.88; I2=17%). The pooled estimates and 95% CIs for studies comparing MADs with controls only and with sham MADs only are -1.50 (-5.97 to 2.97) and -0.28 (-3.40 to 2.84), respectively.

Appendix F Figure 37 24-Hour Diastolic Blood Pressure, MADs vs. Any Inactive

This figure displays a forest plot showing a meta-analysis of 3 studies reporting change in 24-hour diastolic blood pressure with MADs or any inactive control. A negative difference in means favors MADs. Meta-analysis of the 3 trials found a difference in means of -0.75 (95% CI, -2.77 to 1.27; I2=25%). The pooled estimates and 95% CIs for studies comparing MAD with controls only and with sham MADs only are -1.00 (-4.51 to 2.51) and -0.62 (-3.09 to 1.84), respectively.

Appendix F Figure 38 Diurnal Systolic Blood Pressure, MADs vs. Any Inactive

This figure displays a forest plot showing a meta-analysis of 4 studies reporting change in diurnal systolic blood pressure with MADs or any inactive control. A negative difference in means favors MADs. Meta-analysis of the 4 trials found a difference in means of -1.33 (95% CI, -4.47 to 1.81; I2=27%). The pooled estimates and 95% CIs for studies comparing MADs with controls only and with sham MADs only are -2.40 (-12.45 to 7.65) and -1.21 (-4.52 to 2.09), respectively.

Appendix F Figure 39 Diurnal Diastolic Blood Pressure, MADs vs. Any Inactive

This figure displays a forest plot showing a meta-analysis of 4 studies reporting change in diurnal diastolic blood pressure with MADs or any inactive control. A negative difference in means favors MADs. Meta-analysis of the 4 trials found a difference in means of -0.95 (95% CI, -3.60 to 1.71; I2=55%). The pooled estimates and 95% CIs for studies comparing MADs with controls only and with sham MADs only are 0.40 (-6.76 to 7.56) and -1.16 (-4.02 to 1.70), respectively.

Appendix F Figure 40 Nocturnal Systolic Blood Pressure, MADs vs. Any Inactive

This figure displays a forest plot showing a meta-analysis of 3 studies reporting change in nocturnal systolic blood pressure with MADs or any inactive control. A negative difference in means favors MADs. Meta-analysis of the 3 trials found a difference in means of 0.42 (95% CI, -2.03 to 2.87; I2=0%). The pooled estimates and 95% CIs for studies comparing MADs with controls only and with sham MADs only are -3.30 (-13.06 to 6.46) and 0.67 (-1.86 to 3.20), respectively.

Appendix F Figure 41 Nocturnal Diastolic Blood Pressure, MADs vs. Any Inactive

This figure displays a forest plot showing a meta-analysis of 4 studies reporting change in nocturnal diastolic blood pressure with MADs or any inactive control. A negative difference in means favors MADs. Meta-analysis of the 4 trials found a difference in means of -0.57 (95% CI, -2.52 to 1.37; I2=0%). The pooled estimates and 95% CIs for studies comparing MAD with controls only and with sham MADs only are -1.67 (-3.84 to 0.51) and 0.33 (-1.47 to 2.13), respectively.

Appendix F Figure 42 Short-Form (36-Item) Health Survey Mental Component Summary, CPAP vs. Inactive Control

This figure displays a forest plot showing a meta-analysis of 8 studies reporting change in the SF-36 MCS with CPAP or any inactive control. A positive difference in means favors CPAP. Meta-analysis of the 8 trials found a difference in means of 1.19 (95% CI, -0.84 to 3.23; I2=69%).

Appendix F Figure 43 Short-Form (36-Item) Health Survey Physical Component Summary, CPAP vs. Inactive Control

This figure displays a forest plot showing a meta-analysis of 7 studies reporting change in the SF-36 PCS with CPAP or any inactive control. A positive difference in means favors CPAP. Meta-analysis of the 7 trials found a difference in means of 2.29 (95% CI, 0.21 to 4.37; I2=57%).

Appendix F Figure 44 Sleep-Related Quality of Life, CPAP vs. Inactive Control^a^

* Batool-Anwar, 2016a data are from participants with CPAP (or sham) compliance < 4 hours; Batool-Anwar, 2016b data are from participants with compliance >4 hours.

This figure displays a forest plot showing a meta-analysis of 12 studies reporting change in sleep-related quality of life with CPAP or any inactive control. A positive standardized difference in means favors CPAP. Meta-analysis of the 12 trials found a difference in means of 0.32 (95% CI, 0.17 to 0.47; I2=50%). The pooled estimates and 95% CIs for studies comparing CPAP with controls only and with sham CPAP only are 0.29 (0.07 to 0.50) and 0.35 (0.13 to 0.58), respectively.

Appendix F Figure F45 Sleep-Related Quality of Life, CPAP vs. Inactive Control; Sensitivity Analysis Without Phillips^a^

* Batool-Anwar, 2016a data are from participants with CPAP (or sham) compliance < 4 hours; Batool-Anwar, 2016b data are from participants with compliance >4 hours.

This figure displays a forest plot showing a meta-analysis of 11 studies reporting change in sleep-related quality of life with CPAP or any inactive control, minus the study by Phillips et al. A positive standardized difference in means favors CPAP. Meta-analysis of the 11 trials found a difference in means of 0.36 (95% CI, 0.19 to 0.52; I2=39%). The pooled estimates and 95% CIs for studies comparing CPAP with controls only and with sham CPAP only are 0.28 (0.11 to 0.46) and 0.45 (0.24 to 0.66), respectively.

Appendix F Figure 46 Sleep-Related Quality of Life, CPAP vs. Inactive Control; Sensitivity Analysis Including Only Studies With Mean Baseline ESS ≥10

* Batool-Anwar, 2016a data are from participants with CPAP (or sham) compliance < 4 hours; Batool-Anwar, 2016b data are from participants with compliance >4 hours.

This figure displays a forest plot showing a meta-analysis of 8 studies reporting change in sleep-related quality of life with CPAP or any inactive control, only using studies with patients with a baseline ESS score greater than or equal to 10. A positive standardized difference in means favors CPAP. Meta-analysis of the 8 trials found a difference in means of 0.40 (95% CI, 0.23 to 0.56; I2=25%). The pooled estimates and 95% CIs for studies comparing CPAP with controls only and with sham CPAP only are 0.31 (0.09 to 0.52) and 0.48 (0.27 to 0.68), respectively.

Appendix F Figure 47 Association Between AHI and Cancer-Related Mortality, Cardiovascular Events, Stroke, and Cognitive Impairment or Dementia

This figure displays a forest plot showing a meta-analysis of 5 studies that reported associations between AHI and one of the following: cancer-related mortality, cardiovascular events, stroke, and cognitive impairment or dementia, stratified by OSA severity. The effect size from the 1 study that reported cancer-related mortality was 3.40 (95% CI, 1.71 to 6.75) for severe OSA, 1.10 (95% CI, 0.49 to 2.46) for moderate OSA, and 1.80 (95% CI, 1.13 to 2.87) for mild OSA, all compared with people with an AHI less than 5. The effect size from the 1 study that reported nonfatal cardiovascular events was 3.17 (95% CI, 1.22 to 8.21) for severe OSA and 1.10 (95% CI, 0.49 to 2.46) and 1.57 (95% CI, 0.70 to 3.54) for mild to moderate OSA, both compared with people with an AHI less than 5. The effect size from the 1 study that reported coronary heart disease was 1.58 (95% CI, 0.93 to 2.67) for men with severe OSA, 1.19 (95% CI, 0.56 to 2.52) for women with severe OSA, 1.13 (95% CI, 0.68 to 1.88) for men with moderate OSA, 1.01 (95% CI, 0.60 to 1.70) for women with moderate OSA, 0.88 (95% CI, 0.57 to 1.35) for men with mild OSA, and 1.13 (95% CI, 0.80 to 1.60) for women with mild OSA, all compared with people with an AHI less than 5. The effect size for ischemic stroke was 2.86 (95% CI, 1.10 to 7.41) for men with moderate to severe OSA, 1.21 (95% CI, 0.65 to 2.25) for women with moderate to severe OSA, 1.86 (95% CI, 0.70 to 4.95) for men with roughly moderate OSA, 1.20 (95% CI, 0.67 to 2.15) for women with roughly moderate OSA, 1.86 (95% CI, 0.67 to 5.14) for men with mild OSA, and 1.34 (95% CI, 0.76 to 2.36) for women with mild OSA, all compared with people with an AHI less than 4. The effect size from the 1 study that reported cognitive impairment or dementia was 2.36 (95% CI, 1.34 to 4.14) for people with moderate to severe OSA compared with people with an AHI less than 15.