# Appendix E Additional Tables of Study Results

Appendix E Table 1 Characteristics of Included Studies of Type II Portable Monitors for KQ 3

Appendix E Table 2 Characteristics of Included Studies of Type III Portable Monitors for KQ3

Appendix E Table 3 Characteristics of Included Studies of Type IV (3+ Channels) Portable Monitors for KQ3

Appendix E Table 4 Characteristics of Included Studies of Type IV (2 Channels) Portable Monitors for KQ3

Appendix E Table 5 Characteristics of Included Studies of Type IV (1 Channel) Portable Monitors for KQ3

Appendix E Table 6 Results of Newly Identified, Included Studies for KQ 3: Accuracy of Diagnostic Tests (Type II Portable Monitors)

Appendix E Table 7 Results of Newly Identified, Included Studies for KQ 3: Accuracy of Diagnostic Tests (Type III Portable Monitors)

Appendix E Table 8 Results of Newly Identified, Included Studies for KQ 3: Accuracy of Diagnostic Tests (Type IV Portable Monitors With 3+ Channels)

Appendix E Table 9 Results of Newly Identified, Included Studies for KQ 3: Accuracy of Diagnostic Tests (Type IV Portable Monitors With 2 Channels)

Appendix E Table 10 Results of Newly Identified, Included Studies for KQ 3: Accuracy of Diagnostic Tests (Type IV Portable Monitors With 1 Channel)

Appendix E Table 11 Characteristics of Included Randomized, Controlled Trials Comparing CPAP and Sham CPAP (KQ 4)

Appendix E Table 12 Characteristics of Included Randomized, Controlled Trials Comparing CPAP and Control (KQ 4)

Appendix E Table 13 Characteristics of Included Randomized, Controlled Trials That Evaluated Mandibular Advancement Devices (KQs 4 and 5)

Appendix E Table 14 Characteristics of Included Randomized, Controlled Trials That Evaluated Surgical Interventions (KQ 4)

Appendix E Table 15 Characteristics of Included Randomized, Controlled Trials That Evaluated Weight Loss, Diet, and Exercise Programs (KQ 4)

Appendix E Table 16 Characteristics of Included Randomized, Controlled Trials Comparing CPAP and Any Comparator Reporting a Health Outcome (KQ 5)

Appendix E Table 17 Results of Included Randomized, Controlled Trials Assessing CPAP: Health Outcomes (KQ 5)

Appendix E Table 18 Results of Included Randomized, Controlled Trials That Evaluated a Health Outcome: Bariatric Surgery, Weight Loss Programs, and Oral Surgery (KQ 5)

Appendix E Table 19 Results of Included Randomized, Controlled Trials That Evaluated Mandibular Advancement Devices: Health Outcomes (KQ 5)

Appendix E Table 20 Characteristics of Included Prospective Cohort Studies for KQ 6

Appendix E Table 21 Results of Included Prospective Cohort Studies Reporting Mortality by AHI (KQ 6)

Appendix E Table 22 Results of Included Prospective Cohort Studies Reporting Cardiovascular Events, Cerebrovascular Events, or Cognitive Impairment by AHI (KQ 6)

Appendix E Table 23 Results of Included Randomized, Controlled Trials: Harms of CPAP Compared With Sham or Control (KQ 8)

Appendix E Table 24 Results of Included Randomized, Controlled Trials: Harms of MADs Compared With Sham or Control (KQ 8)

Table E25 Results of Included Randomized, Controlled Trials: Harms of Weight Loss Interventions Compared With Sham or Control (KQ 8)

Appendix E Table 26 Results of Included Randomized, Controlled Trials: Harms of Surgical Treatment (KQ 8)

Appendix E Table 27 Characteristics of Studies Excluded From KQ 2 Because of Poor Quality

Appendix E Table 28 Results of Studies Excluded Because of Poor Quality: Accuracy of Screening Questionnaires and Clinical Prediction Tools (KQ 2)

Appendix E Table 29 Results of Studies Excluded Because of Poor Quality: Accuracy of Screening Questionnaires and Clinical Prediction Tools (KQ 2)

Appendix E Table 30 Characteristics of Randomized, Controlled Trials of Mandibular Advancement Devices Excluded Because of Poor Quality

Appendix E Table 31 Results of Randomized, Controlled Trials That Evaluated Mandibular Advancement Devices and Reported Health Outcomes That Were Excluded Because of Poor Quality (KQ 5)

Appendix E Table 32 Characteristics of Prospective Cohort Studies Excluded From KQ 6 Because of Poor Quality

Appendix E Table 33 Results of Prospective Cohort Studies Excluded From KQ 6 Because of Poor Quality That Reported Cardiovascular Events, Cerebrovascular Events, or Cognitive Impairment by AHI

Appendix E Table 34 Results of Randomized, Controlled Trials That Reported Harms (KQ 8) of Mandibular Advancement Devices But Were Excluded Because of Poor Quality