# Appendix D Quality Assessments

Appendix D Table 1 Quality Ratings of Studies of Screening Questionnaires and Clinical Prediction Tools (KQ 2)

Appendix D Table 2 Quality Ratings for Studies of Screening Questionnaires and Clinical Prediction Tools for KQ2

Appendix D Table 3 Quality Ratings of Systematic Reviews and Meta-Analyses for KQ 3

Appendix D Table 4 Quality Ratings of Newly Identified Included Studies for KQ 3

Table D5 Quality Ratings of Newly Identified Included Studies for KQ 3

Appendix D Table 6 Quality Ratings oIncluded Randomized, Controlled Trials of Interventions for OSA (KQs 4 and 5)

Appendix D Table 7 Quality Ratings of Studies of Included Randomized, Controlled Trials of Interventions for OSA (KQs 4 and 5)

Appendix D Table 8 Quality Ratings of Included Prospective Cohort Studies for KQ 6

Appendix D Table 9 Relevance of Systematic Reviews and Meta-Analyses for the Association Between AHI and Health Outcomes (KQ 6)

Appendix D Table 10 Quality Ratings for Systematic Reviews and Meta-Analyses for the Association Between AHI and Health Outcomes (KQ 6)

Appendix D Table 11 Quality Ratings of Prospective Cohort Studies Excluded From KQ 6 Due to Poor Quality

Appendix D Table 12 Quality Ratings for Included Randomized, Controlled Trials That Reported Harms (KQ 8^*^)