# Appendix C Excluded Studies

- X1: Non-English
- X2: Ineligible publication type
- X3: Ineligible study design
- X4: No relevant outcome reported
- X5: Poor quality
- X6: Superseded by other included article
- X7: Abstract only
- X8: Ineligible population
- X9: Ineligible test or intervention
- X10: Ineligible or no comparator
- X11: Title
- X12: Ineligible country
- X13: Full reference inaccessible
- X14: Non-surgical intervention in lab setting
- X15: Article retracted

1 (1999). Continuous positive airway pressure (CPAP) in sleep apnea syndrome - primary research. Health Technology Assessment Database.
2 (2001). Summaries for patients. Treatment for sleep apnea in people without symptoms. Ann Intern Med.
3 (2006). Polysomnography in patients with obstructive sleep apnea: an evidence-based analysis. Health Technology Assessment Database.
4 (2007). Value of mandibular advancement devices in cases of obstructive sleep apnea-syndrome. Health Technology Assessment Database.
5 (2008). Continuous positive airway pressure for the treatment of obstructive sleep apnoea/hypopnoea syndrome. Health Technology Assessment Database.
6 (2008). Continuous positive airways pressure for the treatment of obstructive sleep apnoea/hypopnoea syndrome. Health Technology Assessment Database.
7 (2010). A randomised controlled trial of continuous positive airway pressure treatment in older people with obstructive sleep apnoea hypopnoea syndrome (PREDICT) (Project record). Health Technology Assessment Database.
8 (2010). Pre-operative screening and post-operative monitoring in adult patients with obstructive sleep apnea: clinical effectiveness and guidelines. Health Technology Assessment Database.
9 (2010). An assessment of sleep disordered breathing diagnosis using Level I versus Level III sleep studies. Health Technology Assessment Database.
10 (2011). Rehabilitation Program as an Alternative Therapy for Moderate to Severe Obstructive Sleep Apnea Syndrome.
11 (2013). Level I and level III sleep studies for the diagnosis of Sleep Disordered Breathing (SDB) in adults (Project record). Health Technology Assessment Database.
12 (2013). GLYCOSA Study:Effect of PAP Treatment on Glycemic Control in Patients With Type 2 Diabetes.
13 (2014). Continuous Positive Airway Pressure (CPAP) in Patients With Acute Coronary Syndrome and Obstructive Sleep Apnea (OSA).
14 (2014). RCT of the Effect of Uvulopalatopharyngoplasty Compared to Expectancy in Patients With Obstructive Sleep Apnea.
15 (2014). Corrections to Continuous positive airway pressure in older people with obstructive sleep apnoea syndrome (PREDICT): Aa 12-month, multicentre, randomised trial [Lancet Respir Med, 2, (2014), 804-812]. Lancet Respiratory Medicine.
16 (2014). Comparative Effectiveness Research to Enhance Outcomes in African-Americans With Obstructive Sleep Apnea.
17 (2014). Obstructive Sleep Apnea (OSA), Sleepiness, and Activity in Diabetes Management.
18 (2014). Effects of Treating Obstructive Sleep Apnea in Epilepsy.
19 (2015). Lifestyle Modification Program to Treat Obstructive Sleep Apnea Patients.
20 (2015). Diagnosis, Cost and Therapeutic Decision-Making of Home Respiratory Polygraphy for Patients Without High Suspicion of OSA or With Comorbidity - Hospital Polysomnography in Comparison With Three Nights of Home Respiratory Polygraphy.
21 Aaronson JA, Nachtegaal J, van Bezeij T, et al. (2014). Can a prediction model combining self-reported symptoms, sociodemographic and clinical features serve as a reliable first screening method for sleep apnea syndrome in patients with stroke?. Arch Phys Med Rehabil.
22 Abbey NC, Block AJ, Green D, et al. (1990). A method for measuring pharyngeal volumes using magnetic resonance imaging in subjects who snore with and without nasal CPAP. Prog Clin Biol Res.
23 Abdullah H, Maddage NC, Cosic I, et al. (2010). Cross-correlation of EEG frequency bands and heart rate variability for sleep apnoea classification. Med Biol Eng Comput.
24 Abraham WT, Trupp RJ, Phillilps B, et al. (2006). Validation and clinical utility of a simple in-home testing tool for sleep-disordered breathing and arrhythmias in heart failure: results of the Sleep Events, Arrhythmias, and Respiratory Analysis in Congestive Heart Failure (SEARCH) study. Congest Heart Fail.
25 Acar M, Firat H, Acar U, et al. (2013). Ocular surface assessment in patients with obstructive sleep apnea-hypopnea syndrome. Sleep Breath.
26 Acharya UR, Chua EC, Faust O, et al. (2011). Automated detection of sleep apnea from electrocardiogram signals using nonlinear parameters. Physiol Meas.
27 (2015). ACTRN12605000066684. The effect of Obstructive Sleep Apnoea (OSA) and its treatment with Continuous Positive Airways Pressure (CPAP) on lipid metabolism.
28 (2015). ACTRN12608000301369. Metabolic and Neurobiological changes after Continuous Positive Airway Pressure treatment for Obstructive Sleep Apnea.
29 Adachi H, Mikami A, Kumano-go T, et al. (2003). Clinical significance of pulse rate rise during sleep as a screening marker for the assessment of sleep fragmentation in sleep-disordered breathing. Sleep Med.
30 Adesanya AO, Lee W, Greilich NB, et al. (2010). Perioperative management of obstructive sleep apnea. Chest.
31 Aggarwal S, Nadeem R, Loomba RS, et al. (2014). The effects of continuous positive airways pressure therapy on cardiovascular end points in patients with sleep-disordered breathing and heart failure: a meta-analysis of randomized controlled trials. Clin Cardiol.
32 Ahmadi N, Chung SA, Gibbs A, et al. (2008). The Berlin questionnaire for sleep apnea in a sleep clinic population: relationship to polysomnographic measurement of respiratory disturbance. Sleep Breath.
33 Aihara K, Oga T, Yoshimura C, et al. (2013). Measurement of dyspnea in patients with obstructive sleep apnea. Sleep Breath.
34 Akita Y, Kawakatsu K, Hattori C, et al. (2003). Posture of patients with sleep apnea during sleep. Acta Otolaryngol Suppl.
35 Akpinar ME, Celikoyar MM, Altundag A, et al. (2011). The comparison of cephalometric characteristics in nonobese obstructive sleep apnea subjects and primary snorers cephalometric measures in nonobese OSA and primary snorers. Eur Arch Otorhinolaryngol.
36 Al-Abed MA, Antich P, Watenpaugh DE, et al. (2011). In vivo characterization of ultrasonic transducers for the detection of airway occlusion in Sleep Disordered Breathing. Conf Proc IEEE Eng Med Biol Soc.
37 Alajmi M, Mulgrew AT, Fox J, et al. (2007). Impact of continuous positive airway pressure therapy on blood pressure in patients with obstructive sleep apnea hypopnea: a meta-analysis of randomized controlled trials. Lung.
38 Al-Angari HM, Sahakian AV. (2012). Automated recognition of obstructive sleep apnea syndrome using support vector machine classifier. IEEE Trans Inf Technol Biomed.
39 Albuquerque FN, Calvin AD, Sert Kuniyoshi FH, et al. (2012). Sleep-disordered breathing and excessive daytime sleepiness in patients with atrial fibrillation. Chest.
40 Alchanatis M, Zias N, Deligiorgis N, et al. (2005). Sleep apnea-related cognitive deficits and intelligence: an implication of cognitive reserve theory. J Sleep Res.
41 Alfonso-Fernandez A, Arias MA, Garcia-Rio F, et al. (2005). Impaired left ventricular performance during exercise in patients with obstructive sleep apnea-hypopnea syndrome improves with continuous positive airway pressure.
42 Alonso-Fernández A, García-Río F, Arias MA, et al. (2009). Effects of CPAP on oxidative stress and nitrate efficiency in sleep apnoea: a randomised trial. Thorax.
43 Alonso-Fernández A, García-Río F, Arias MA, et al. (2006). Obstructive sleep apnoea-hypoapnoea syndrome reversibly depresses cardiac response to exercise. Eur Heart J.
44 Alshaer H, Fernie GR, Maki E, et al. (2013). Validation of an automated algorithm for detecting apneas and hypopneas by acoustic analysis of breath sounds. Sleep Med.
45 Altekin RE, Yanikoglu A, Baktir AO, et al. (2012). Assessment of subclinical left ventricular dysfunction in obstructive sleep apnea patients with speckle tracking echocardiography. Int J Cardiovasc Imaging.
46 Altekin RE, Yanikoglu A, Karakas MS, et al. (2012). Assessment of left atrial dysfunction in obstructive sleep apnea patients with the two dimensional speckle-tracking echocardiography. Clin Res Cardiol.
47 Alvarez D, Gutierrez GC, Marcos JV, et al. (2010). Spectral analysis of single-channel airflow and oxygen saturation recordings in obstructive sleep apnea detection. Conf Proc IEEE Eng Med Biol Soc.
48 Alvarez D, Hornero R, Abasolo D, et al. (2006). Nonlinear characteristics of blood oxygen saturation from nocturnal oximetry for obstructive sleep apnoea detection. Physiol Meas.
49 Alvarez D, Hornero R, Marcos JV, et al. (2007). Obstructive sleep apnea detection using clustering classification of nonlinear features from nocturnal oximetry. Conf Proc IEEE Eng Med Biol Soc.
50 Alvarez D, Hornero R, Marcos JV, et al. (2013). Assessment of feature selection and classification approaches to enhance information from overnight oximetry in the context of apnea diagnosis. Int J Neural Syst.
51 Amaro AC, Duarte FH, Jallad RS, et al. (2012). The use of nasal dilator strips as a placebo for trials evaluating continuous positive airway pressure. Clinics (Sao Paulo).
52 Amin MM, Gold MS, Broderick JE, et al. (2011). The effect of nasal continuous positive airway pressure on the symptoms of Gulf War illness. Sleep Breath.
53 Amir O, Barak-Shinar D, Henry A, et al. (2012). Photoplethysmography as a single source for analysis of sleep-disordered breathing in patients with severe cardiovascular disease. J Sleep Res.
54 Anandam A, Akinnusi M, Kufel T, et al. (2013). Effects of dietary weight loss on obstructive sleep apnea: a meta-analysis. Sleep and Breathing.
55 Ancoli-Israel S, Kripke DF, Klauber MR, et al. (1991). Sleep-disordered breathing in community-dwelling elderly. Sleep.
56 Ancoli-Israel S, Mason W, Coy TV, et al. (1997). Evaluation of sleep disordered breathing with unattended recording: the Nightwatch System. J Med Eng Technol.
57 Ancoli-Israel S, Palmer BW, Cooke JR, et al. (2008). Cognitive effects of treating obstructive sleep apnea in Alzheimer's disease: a randomized controlled study. J Am Geriatr Soc.
58 Andreas S, Schulz R, Werner GS, et al. (1996). Prevalence of obstructive sleep apnoea in patients with coronary artery disease. Coron Artery Dis.
59 Andreas S, von Breska B, Magnusson K, et al. (1993). Validation of automated sleep stage and apnoea analysis in suspected obstructive sleep apnoea. Eur Respir J.
60 Andreu AL, Chiner E, Sancho-Chust JN, et al. (2012). Effect of an ambulatory diagnostic and treatment programme in patients with sleep apnoea. Eur Respir J.
61 Andries D, Haba-Rubio J, Bastardot F, et al. (2011). Berlin and STOP-BANG questionnaires for detecting sleep apnoea in the general population. Respiration.
62 Antonopoulos CN, Sergentanis TN, Daskalopoulou SS, et al. (2011). Nasal continuous positive airway pressure (nCPAP) treatment for obstructive sleep apnea, road traffic accidents and driving simulator performance: a meta-analysis. Sleep Med Rev.
63 Appleton SL, Vakulin A, McEvoy RD, et al. (2015). Undiagnosed obstructive sleep apnea is independently associated with reductions in quality of life in middle-aged, but not elderly men of a population cohort. Sleep and Breathing.
64 Argod J, Pepin JL, Levy P. (1998). Differentiating obstructive and central sleep respiratory events through pulse transit time. Am J Respir Crit Care Med.
65 Arias MA, García-Río F, Alonso-Fernández A, et al. (2006). Pulmonary hypertension in obstructive sleep apnoea: effects of continuous positive airway pressure: a randomized, controlled cross-over study. Eur Heart J.
66 Armistead JP, Bateman P, Chan CS, et al. (2009). Study of an auto-adjusting CPAP algorithm for the treatment of obstructive sleep apnoea.
67 Arroll B, Fernando A, Falloon K, et al. (2011). Development, validation (diagnostic accuracy) and audit of the Auckland Sleep Questionnaire: a new tool for diagnosing causes of sleep disorders in primary care. J Prim Health Care.
68 Arzt M, Schroll S, Series F, et al. (2013). Auto-servoventilation in heart failure with sleep apnoea: a randomised controlled trial. Eur Respir J.
69 Arzt M, Young T, Finn L, et al. (2005). Association of sleep-disordered breathing and the occurrence of stroke. Am J Respir Crit Care Med.
70 Asghari A, Mohammadi F, Kamrava SK, et al. (2013). Evaluation of quality of life in patients with obstructive sleep apnea. Eur Arch Otorhinolaryngol.
71 Asghari A, Mohammadi F, Kamrava SK, et al. (2012). Severity of depression and anxiety in obstructive sleep apnea syndrome. Eur Arch Otorhinolaryngol.
72 Assoumou HG, Gaspoz JM, Sforza E, et al. (2012). Obstructive sleep apnea and the metabolic syndrome in an elderly healthy population: the SYNAPSE cohort. Sleep Breath.
73 Aubert-Tulkens G, Culee C, Harmant-Van Rijckevorsel K, et al. (1987). Ambulatory evaluation of sleep disturbance and therapeutic effects in sleep apnea syndrome by wrist activity monitoring. Am Rev Respir Dis.
74 Aurora RN, Casey KR, Kristo D, et al. (2010). Practice parameters for the surgical modifications of the upper airway for obstructive sleep apnea in adults. Sleep.
75 Australian S, Efficacy Register of New Interventional Procedures S. (2008). Rapid Review - Upper airway surgery for the treatment of adult obstructive sleep apnoea. Report No. 67. Health Technology Assessment Database.
76 Avidan AY. (2006). The development of central sleep apnea with an oral appliance. Sleep Med.
77 Ayalon L, Ancoli-Israel S, Stepnowsky C, et al. (2006). Adherence to continuous positive airway pressure treatment in patients with Alzheimer's disease and obstructive sleep apnea. Am J Geriatr Psychiatry.
78 Ayappa I, Norman RG, Seelall V, et al. (2008). Validation of a self-applied unattended monitor for sleep disordered breathing. J Clin Sleep Med.
79 Ayappa I, Norman RG, Suryadevara M, et al. (2004). Comparison of limited monitoring using a nasal-cannula flow signal to full polysomnography in sleep-disordered breathing. Sleep.
80 Ayas NT, FitzGerald JM, Fleetham JA, et al. (2006). Cost-effectiveness of continuous positive airway pressure therapy for moderate to severe obstructive sleep apnea/hypopnea. Arch Intern Med.
81 Ayas NT, Pittman S, MacDonald M, et al. (2003). Assessment of a wrist-worn device in the detection of obstructive sleep apnea. Sleep Med.
82 Babaeizadeh S, Zhou SH, Pittman SD, et al. (2011). Electrocardiogram-derived respiration in screening of sleep-disordered breathing. J Electrocardiol.
83 Badia JR, Hernandez L, Leon C, et al. (1997). Efficacy of CPAP treatment in moderate to severe sleep apnea hypopnea syndrome (SAHS). European Respiratory Journal - Supplement.
84 Bagnato MC, Nery LE, Moura SM, et al. (2000). Comparison of AutoSet and polysomnography for the detection of apnea-hypopnea events. Braz J Med Biol Res.
85 BaHammam AS, Obeidat A, Barataman K, et al. (2014). A comparison between the AASM 2012 and 2007 definitions for detecting hypopnea. Sleep Breath.
86 BaHammam AS, Sharif M, Gacuan DE, et al. (2011). Evaluation of the accuracy of manual and automatic scoring of a single airflow channel in patients with a high probability of obstructive sleep apnea. Med Sci Monit.
87 Bailes S, Baltzan M, Rizzo D, et al. (2008). A diagnostic symptom profile for sleep disorder in primary care patients. J Psychosom Res.
88 Baisch A, Maurer JT, Hormann K. (2006). The effect of hyoid suspension in a multilevel surgery concept for obstructive sleep apnea. Otolaryngol Head Neck Surg.
89 Bakker JP, Campbell AJ, Neill AM. (2012). Increased mortality risk in congestive heart failure patients with comorbid sleep apnoea: 10-year follow up. Intern Med J.
90 Bakker JP, Edwards BA, Gautam SP, et al. (2014). Blood pressure improvement with continuous positive airway pressure is independent of obstructive sleep apnea severity. J Clin Sleep Med.
91 Balachandran JS, Bakker JP, Rahangdale S, et al. (2012). Effect of mild, asymptomatic obstructive sleep apnea on daytime heart rate variability and impedance cardiography measurements. Am J Cardiol.
92 Balakrishnan K, James KT, Weaver EM. (2013). Composite severity indices reflect sleep apnea disease burden more comprehensively than the apnea-hypopnea index. Otolaryngol Head Neck Surg.
93 Ballester E, Solans M, Vila X, et al. (2000). Evaluation of a portable respiratory recording device for detecting apnoeas and hypopnoeas in subjects from a general population. Eur Respir J.
94 Baltzan MA, Verschelden P, Al-Jahdali H, et al. (2000). Accuracy of oximetry with thermistor (OxiFlow) for diagnosis of obstructive sleep apnea and hypopnea. Sleep.
95 Banerjee D, Leong WB, Arora T, et al. (2013). The potential association between obstructive sleep apnea and diabetic retinopathy in severe obesity-the role of hypoxemia. PLoS One.
96 Banhiran W, Assanasen P, Nopmaneejumruslers C, et al. (2011). Epworth sleepiness scale in obstructive sleep disordered breathing: the reliability and validity of the Thai version. Sleep Breath.
97 Banhiran W, Chotinaiwattarakul W, Chongkolwatana C, et al. (2014). Home-based diagnosis of obstructive sleep apnea by polysomnography type 2: accuracy, reliability, and feasibility. Sleep and Breathing.
98 Bao X, Nelesen RA, Loredo JS, et al. (2002). Blood pressure variability in obstructive sleep apnea: role of sympathetic nervous activity and effect of continuous positive airway pressure. Blood Press Monit.
99 Bar A, Pillar G, Dvir I, et al. (2003). Evaluation of a portable device based on peripheral arterial tone for unattended home sleep studies. Chest.
100 Barbe F, Duran-Cantolla J, Sanchez-De-La-Torre M, et al. (2013). CPAP and hypertension in nonsleepy patients. J Clin Sleep Med.
101 Barbé F, Sunyer J, Peña A, et al. (2007). Effect of continuous positive airway pressure on the risk of road accidents in sleep apnea patients. Respiration.
102 Barbé F, Torrente E, Esquinas C, et al. (2012). Impact of day care centres in monitoring patients with Obstructive Sleep Apnea Syndrome (OSAS). Health Technology Assessment Database.
103 Barcelo X, Mirapeix RM, Buges J, et al. (2011). Oropharyngeal examination to predict sleep apnea severity. Arch Otolaryngol Head Neck Surg.
104 Bardwell WA, Ancoli-Israel S, Berry CC, et al. (2001). Neuropsychological effects of one-week continuous positive airway pressure treatment in patients with obstructive sleep apnea: a placebo-controlled study. Psychosom Med.
105 Barger LK, O'Brien CS, Rajaratnam SM, et al. (2016). Implementing a Sleep Health Education and Sleep Disorders Screening Program in Fire Departments: A Comparison of Methodology. J Occup Environ Med.
106 Barger LK, Rajaratnam SM, Wang W, et al. (2015). Common sleep disorders increase risk of motor vehicle crashes and adverse health outcomes in firefighters. J Clin Sleep Med.
107 Barnes M, Collins AL, Smart K, et al. (2014). Short term outcomes for obstructive sleep apnoea patients treated with hypoglossal nerve stimulation. J Sleep Res.
108 Barnes M, Houston D, Worsnop CJ, et al. (2002). A randomized controlled trial of continuous positive airway pressure in mild obstructive sleep apnea. Am J Respir Crit Care Med.
109 Barrera F, Hillyer P, Ascanio G, et al. (1973). The distribution of ventilation, diffusion, and blood flow in obese patients with normal and abnormal blood gases. Am Rev Respir Dis.
110 Basner RC. (2007). Continuous positive airway pressure for obstructive sleep apnea. N Engl J Med.
111 Basta M, Lin HM, Pejovic S, et al. (2008). Lack of regular exercise, depression, and degree of apnea are predictors of excessive daytime sleepiness in patients with sleep apnea: sex differences. J Clin Sleep Med.
112 Batchelder KA, Mannheimer PD, Mecca RS, et al. (2011). Pulse oximetry saturation patterns detect repetitive reductions in airflow. J Clin Monit Comput.
113 Batool-Anwar S, Goodwin JL, Drescher AA, et al. (2014). Impact of CPAP on activity patterns and diet in patients with Obstructive Sleep Apnea (OSA). J Clin Sleep Med.
114 Bausmer U, Gouveris H, Selivanova O, et al. (2010). Correlation of the Epworth Sleepiness Scale with respiratory sleep parameters in patients with sleep-related breathing disorders and upper airway pathology. Eur Arch Otorhinolaryngol.
115 Bearpark H, Elliott L, Grunstein R, et al. (1993). Occurrence and correlates of sleep disordered breathing in the Australian town of Busselton: a preliminary analysis. Sleep.
116 Beattie ZT, Hayes TL, Guilleminault C, et al. (2013). Accurate scoring of the apnea-hypopnea index using a simple non-contact breathing sensor. J Sleep Res.
117 Becker HF, Jerrentrup A, Ploch T, et al. (2003). Effect of nasal continuous positive airway pressure treatment on blood pressure in patients with obstructive sleep apnea. Circulation.
118 Beiske KK, Kjelsberg FN, Ruud EA, et al. (2009). Reliability and validity of a Norwegian version of the Epworth sleepiness scale. Sleep Breath.
119 Benz RL, Pressman MR, Wu X. (2011). Periodic limb movements in sleep revealed by treatment of sleep apnea with continuous positive airway pressure in the advanced chronic kidney disease population. Clin Nephrol.
120 Berger M, Varvarigou V, Rielly A, et al. (2012). Employer-mandated sleep apnea screening and diagnosis in commercial drivers. J Occup Environ Med.
121 Berlowitz DJ, Shafazand S. (2013). CPAP and cognition in OSA (APPLES). J Clin Sleep Med.
122 Berry DT, Phillips BA, Cook YR, et al. (1987). Sleep-disordered breathing in healthy aged persons: possible daytime sequelae. J Gerontol.
123 Berry DT, Phillips BA, Cook YR, et al. (1989). Sleep-disordered breathing in healthy aged persons: one-year follow-up of daytime sequelae. Sleep.
124 Berry DT, Webb WB, Block AJ, et al. (1986). Sleep-disordered breathing and its concomitants in a subclinical population. Sleep.
125 Berry RB, Block AJ. (1984). Positive nasal airway pressure eliminates snoring as well as obstructive sleep apnea. Chest.
126 Berry RB, Budhiraja R, Gottlieb DJ, et al. (2012). Rules for scoring respiratory events in sleep: update of the 2007 AASM Manual for the Scoring of Sleep and Associated Events. Deliberations of the Sleep Apnea Definitions Task Force of the American Academy of Sleep Medicine. J Clin Sleep Med.
127 Berry RB, Kryger MH, Massie CA. (2011). A novel nasal expiratory positive airway pressure (EPAP) device for the treatment of obstructive sleep apnea: a randomized controlled trial. Sleep.
128 Berry RB, Parish JM, Hartse KM. (2002). The use of auto-titrating continuous positive airway pressure for treatment of adult obstructive sleep apnea. An American Academy of Sleep Medicine review. Sleep.
129 Berry S, Roblin G, Williams A, et al. (2005). Validity of sleep nasendoscopy in the investigation of sleep related breathing disorders. Laryngoscope.
130 Bertolazi AN, Fagondes SC, Hoff LS, et al. (2011). Validation of the Brazilian Portuguese version of the Pittsburgh Sleep Quality Index. Sleep Med.
131 Bertolazi AN, Fagondes SC, Hoff LS, et al. (2009). Portuguese-language version of the Epworth sleepiness scale: validation for use in Brazil. J Bras Pneumol.
132 Bhalla V, Georgiopoulou VV, Kalogeropoulos AP, et al. (2013). Contemporary outcomes of optimally treated heart failure patients with sleep apnea. Case for urgency in evaluation of newer interventions? From the Atlanta Cardiomyopathy Consortium. Int J Cardiol.
133 Bianchi A, Betti E, Tarsitano A, et al. (2014). Volumetric three-dimensional computed tomographic evaluation of the upper airway in patients with obstructive sleep apnoea syndrome treated by maxillomandibular advancement. Br J Oral Maxillofac Surg.
134 Bianchi MT, Lipoma T, Darling C, et al. (2014). Automated sleep apnea quantification based on respiratory movement. Int J Med Sci.
135 Billings ME, Rosen CL, Auckley D, et al. (2014). Psychometric performance and responsiveness of the functional outcomes of sleep questionnaire and sleep apnea quality of life instrument in a randomized trial: the HomePAP study. Sleep.
136 Bitter T, Nolker G, Vogt J, et al. (2012). Predictors of recurrence in patients undergoing cryoballoon ablation for treatment of atrial fibrillation: the independent role of sleep-disordered breathing. J Cardiovasc Electrophysiol.
137 Bitter T, Westerheide N, Hossain SM, et al. (2012). Symptoms of sleep apnoea in chronic heart failure--results from a prospective cohort study in 1,500 patients. Sleep Breath.
138 Bitter T, Westerheide N, Prinz C, et al. (2011). Cheyne-Stokes respiration and obstructive sleep apnoea are independent risk factors for malignant ventricular arrhythmias requiring appropriate cardioverter-defibrillator therapies in patients with congestive heart failure. Eur Heart J.
139 Bjornsdottir E, Keenan BT, Eysteinsdottir B, et al. (2015). Quality of life among untreated sleep apnea patients compared with the general population and changes after treatment with positive airway pressure. J Sleep Res.
140 Blackman A, McGregor C, Dales R, et al. (2010). Canadian Sleep Society/Canadian Thoracic Society position paper on the use of portable monitoring for the diagnosis of obstructive sleep apnea/hypopnea in adults. Can Respir J.
141 Blanco J, Zamarron C, Abeleira Pazos MT, et al. (2005). Prospective evaluation of an oral appliance in the treatment of obstructive sleep apnea syndrome. Sleep Breath.
142 Bliwise DL, Carey E, Dement WC. (1983). Nightly variation in sleep-related respiratory disturbance in older adults. Exp Aging Res.
143 Bliwise DL, Feldman DE, Bliwise NG, et al. (1987). Risk factors for sleep disordered breathing in heterogeneous geriatric populations. J Am Geriatr Soc.
144 Bliwise DL, King AC. (1996). Sleepiness in clinical and nonclinical populations. Neuroepidemiology.
145 Bliwise DL, Nekich JC, Dement WC. (1991). Relative validity of self-reported snoring as a symptom of sleep apnea in a sleep clinic population. Chest.
146 Bloch KE, Schoch OD, Zhang JN, et al. (1999). German version of the Epworth Sleepiness Scale. Respiration.
147 Blomster H, Laitinen T, Lyyra-Laitinen T, et al. (2014). Endothelial function is well preserved in obese patients with mild obstructive sleep apnea. Sleep and Breathing.
148 Blomster HM, Tuomilehto H, Kemppainen T, et al. (2010). The association between weight reduction, nasal resistance and sleep-disordered breathing in overweight patients with obstructive sleep apnoea. J Sleep Res.
149 Boehning N, Blau A, Kujumdshieva B, et al. (2009). Preliminary results from a telemedicine referral network for early diagnosis of sleep apnoea in sleep laboratories. J Telemed Telecare.
150 Boese ML, Ransom RK, Roadfuss RJ, et al. (2014). Utility of the Berlin Questionnaire to screen for obstructive sleep apnea among patients receiving intravenous sedation for colonoscopy. AANA J.
151 Boland LL, Shahar E, Iber C, et al. (2002). Measures of cognitive function in persons with varying degrees of sleep-disordered breathing: the Sleep Heart Health Study. J Sleep Res.
152 Bonsignore G, Marrone O, Macaluso C, et al. (1990). Validation of oximetry as a screening test for obstructive sleep apnoea syndrome. Eur Respir J Suppl.
153 Boot H, van Wegen R, Poublon RM, et al. (2000). Long-term results of uvulopalatopharyngoplasty for obstructive sleep apnea syndrome. Laryngoscope.
154 Borel JC, Tamisier R, Gonzalez-Bermejo J, et al. (2012). Noninvasive ventilation in mild obesity hypoventilation syndrome: a randomized controlled trial. Chest.
155 Borges JG, Ginani GE, Hachul H, et al. (2013). Executive functioning in obstructive sleep apnea syndrome patients without comorbidities: focus on the fractionation of executive functions. J Clin Exp Neuropsychol.
156 Bossenbroek L, Kosse N, Ten Hacken N, et al. (2010). Validation of the DynaPort MiniMod during sleep: a pilot study. Percept Mot Skills.
157 Boudewyns A, Willemen M, De Cock W, et al. (1997). Does socially disturbing snoring and/or excessive daytime sleepiness warrant polysomnography?. Clin Otolaryngol Allied Sci.
158 Bouloukaki I, Komninos ID, Mermigkis C, et al. (2013). Translation and validation of Berlin questionnaire in primary health care in Greece. BMC Pulm Med.
159 Bozkurt NC, Karbek B, Cakal E, et al. (2012). The association between severity of obstructive sleep apnea and prevalence of Hashimoto's thyroiditis. Endocr J.
160 Bradley PA, Mortimore IL, Douglas NJ. (1995). Comparison of polysomnography with ResCare Autoset in the diagnosis of the sleep apnoea/hypopnoea syndrome. Thorax.
161 Bradshaw DA, Ruff GA, Murphy DP. (2006). An oral hypnotic medication does not improve continuous positive airway pressure compliance in men with obstructive sleep apnea. Chest.
162 Bratton DJ, Stradling JR, Barbe F, et al. (2014). Effect of CPAP on blood pressure in patients with minimally symptomatic obstructive sleep apnoea: a meta-analysis using individual patient data from four randomised controlled trials. Database of Abstracts of Reviews of Effects.
163 Brette C, Ramanantsoa H, Renouardiere J, et al. (2012). A mandibular advancement device for the treatment of obstructive sleep apnea: long-term use and tolerance. Int Orthod.
164 Brevi BC, Toma L, Magri AS, et al. (2011). Use of the mandibular distraction technique to treat obstructive sleep apnea syndrome. J Oral Maxillofac Surg.
165 Brevi BC, Toma L, Pau M, et al. (2011). Counterclockwise rotation of the occlusal plane in the treatment of obstructive sleep apnea syndrome. J Oral Maxillofac Surg.
166 Brostrom A, Johansson P. (2005). Sleep disturbances in patients with chronic heart failure and their holistic consequences-what different care actions can be implemented?. Eur J Cardiovasc Nurs.
167 Brostrom A, Sunnergren O, Nilsen P, et al. (2013). Gender differences in respiratory disturbance, sleep and daytime sleepiness in hypertensive patients with different degrees of obesity. Eur J Cardiovasc Nurs.
168 Brown TT, Patil SP, Jacobson LP, et al. (2010). Anthropometry in the prediction of sleep disordered breathing in HIV-positive and HIV-negative men. Antivir Ther.
169 Bruhova S, Nevsimal O, Ourednik A, et al. (1969). “Pickwickian syndrome” and the influence of weight reduction on the clinical state and polygraphic picture. Act Nerv Super (Praha).
170 Bruyneel M, Van den Broecke S, Libert W, et al. (2013). Real-time attended home-polysomnography with telematic data transmission. Int J Med Inform.
171 Buchwald H, Avidor Y, Braunwald E, et al. (2004). Bariatric surgery: a systematic review and meta-analysis. JAMA.
172 Burgess KR, Havryk A, Newton S, et al. (2013). Targeted case finding for OSA within the primary care setting. J Clin Sleep Med.
173 Burks SV, Anderson JE, Bombyk M, et al. (2016). Nonadherence with Employer-Mandated Sleep Apnea Treatment and Increased Risk of Serious Truck Crashes. Sleep.
174 Cadth. (2013). CPAP treatment for adults with obstructive sleep apnea: review of the clinical and cost-effectiveness and guidelines. Health Technology Assessment Database.
175 Cadth. (2013). Retesting patients with sleep apnea: guidelines and recommendations. Health Technology Assessment Database.
176 Caffo B, Diener-West M, Punjabi NM, et al. (2010). A novel approach to prediction of mild obstructive sleep disordered breathing in a population-based sample: the Sleep Heart Health Study. Sleep.
177 Cahali MB, Formigoni GG, Gebrim EM, et al. (2004). Lateral pharyngoplasty versus uvulopalatopharyngoplasty: a clinical, polysomnographic and computed tomography measurement comparison. Sleep.
178 Cai SJ, Chen R, Zhang YL, et al. (2013). Correlation of Epworth Sleepiness Scale with multiple sleep latency test and its diagnostic accuracy in assessing excessive daytime sleepiness in patients with obstructive sleep apnea hypopnea syndrome. Chin Med J (Engl).
179 Cairns A, Wickwire E, Schaefer E, et al. (2014). A pilot validation study for the NOX T3(TM) portable monitor for the detection of OSA. Sleep Breath.
180 Calleja JM, Esnaola S, Rubio R, et al. (2002). Comparison of a cardiorespiratory device versus polysomnography for diagnosis of sleep apnoea. Eur Respir J.
181 Campbell AJ, Marshall NS, Sheppard DS, et al. (2004). Randomised placebo controlled trial of humidified CPAP in mild obstructive sleep apnoea (OSA). Respirology (Carlton, Vic.).
182 Campos-Rodriguez F, Martinez-Garcia MA, de la Cruz-Moron I, et al. (2012). Cardiovascular mortality in women with obstructive sleep apnea with or without continuous positive airway pressure treatment: a cohort study. Ann Intern Med.
183 Campos-Rodriguez F, Martinez-Garcia MA, Reyes-Nunez N, et al. (2014). Role of sleep apnea and continuous positive airway pressure therapy in the incidence of stroke or coronary heart disease in women. Am J Respir Crit Care Med.
184 Canessa N, Castronovo V, Cappa SF, et al. (2011). Obstructive sleep apnea: brain structural changes and neurocognitive function before and after treatment. Am J Respir Crit Care Med.
185 Canessa N, Ferini-Strambi L. (2011). Sleep-disordered breathing and cognitive decline in older adults. JAMA.
186 Cano-Pumarega I, Duran-Cantolla J, Aizpuru F, et al. (2011). Obstructive sleep apnea and systemic hypertension: longitudinal study in the general population: the Vitoria Sleep Cohort. Am J Respir Crit Care Med.
187 Capampangan DJ, Wellik KE, Parish JM, et al. (2010). Is obstructive sleep apnea an independent risk factor for stroke? A critically appraised topic. Neurologist.
188 Capasso R, Kezirian E, Jacobowitz O, et al. (2014). Management of obstructive sleep apnea in adults. Ann Intern Med.
189 Caples SM, Rowley JA, Prinsell JR, et al. (2010). Surgical modifications of the upper airway for obstructive sleep apnea in adults: a systematic review and meta-analysis. Sleep.
190 Capobianco DM, Batilana A, Gandhi M, et al. (2014). Surgical treatment of sleep apnea: association between surgeon/hospital volume with outcomes. Laryngoscope.
191 Carmelli D, Swan GE, Bliwise DL. (2000). Relationship of 30-year changes in obesity to sleep-disordered breathing in the Western Collaborative Group Study. Obes Res.
192 Carmona Bernal C, Capote Gil F, Botebol Benhamou G, et al. (2000). Assessment of excessive day-time sleepiness in professional drivers with suspected obstructive sleep apnea syndrome. Arch Bronconeumol.
193 Carrasco O, Montserrat JM, Lloberes P, et al. (1996). Visual and different automatic scoring profiles of respiratory variables in the diagnosis of sleep apnoea-hypopnoea syndrome. Eur Respir J.
194 Carratu P, Karageorgiou G, Bonfitto P, et al. (2007). Long-term evaluation of mental fatigue by Maastricht Questionnaire in patients with OSAS treated with CPAP. Monaldi Arch Chest Dis.
195 Carrera M, Barbe F, Sauleda J, et al. (2004). Effects of obesity upon genioglossus structure and function in obstructive sleep apnoea. Eur Respir J.
196 Carroll D. (1974). Sleep, periodic breathing and snoring in the aged: control of ventilation in the aging and diseased respiratory system. J Am Geriatr Soc.
197 Cartwright R, Ristanovic R, Diaz F, et al. (1991). A comparative study of treatments for positional sleep apnea. Sleep.
198 Casale M, Rinaldi V, Bressi F, et al. (2008). A suitable test for identifying high risk adult patients of moderate-severe obstructive sleep apnea syndrome. Eur Rev Med Pharmacol Sci.
199 Catalan-Serra P, Martinez-Garcia MA, Campos-Rodriguez F, et al. (2013). Effect of continuous positive airway pressure on the incidence of nonfatal cardiovascular events in elderly with obstructive sleep apnea. Am J Respir Crit Care Med.
200 Catheline JM, Bihan H, Le Quang T, et al. (2008). Preoperative cardiac and pulmonary assessment in bariatric surgery. Obes Surg.
201 Cauley JA, Blackwell TL, Redline S, et al. (2014). Hypoxia during sleep and the risk of falls and fractures in older men: the Osteoporotic Fractures in Men Sleep Study. J Am Geriatr Soc.
202 Cayanan EA, Marshall NS, Hoyos CM, et al. (2014). Effectiveness of two maintenance diets following a very low energy diet to reduce cardiometabolic risk in obese sleep apnea patients: A randomised controlled trial. J Sleep Res.
203 Chai-Coetzer CL, Antic N, Eckermann S, et al. (2012). Cost-effectiveness analysis of a simplified model of care for obstructive sleep apnea in general practice. Sleep and Biological Rhythms.
204 Chai-Coetzer CL, Antic NA, Rowland LS, et al. (2011). A simplified model of screening questionnaire and home monitoring for obstructive sleep apnoea in primary care. Thorax.
205 Chaidas KS, Kaditis AG, Papadakis CE, et al. (2013). Tonsilloplasty versus tonsillectomy in children with sleep-disordered breathing: short- and long-term outcomes. Laryngoscope.
206 Chakhtoura M, Azar ST. (2012). Continuous positive airway pressure and type 2 diabetes mellitus. Diabetes Metab Syndr.
207 Chakravorty I, Cayton RM, Szczepura A. (2001). Cost effectiveness analysis of nasal CPAP and lifestyle intervention in obstructive sleep apnoea. Thorax.
208 Chami HA, Resnick HE, Quan SF, et al. (2011). Association of incident cardiovascular disease with progression of sleep-disordered breathing. Circulation.
209 Chan K, Cossa G, Birring S, et al. (2013). Impact of continuous positive airway pressure (CPAP) on chronic cough in obstructive sleep apnoea (OSA)-A randomized controlled trial. Sleep Med.
210 Chan K, Cossa G, Laks L, et al. (2011). Impact on objective cough severity by continuous positive airway pressure (CPAP) in subjects with chronic cough and obstructive sleep apnoea A randomized controlled trial.
211 Chan K, Cossa G, Laks L, et al. (2014). Impact of continuous positive airway pressure (CPAP) on chronic cough in obstructive sleep apnoea (OSA) ? a randomized controlled trial. Respirology (Carlton, Vic.).
212 Chan K, Laks L, Cossa G, et al. (2010). Impact of continuous positive airway pressure (CPAP) on chronic cough in obstructive sleep apnoea (OSA) - A randomized controlled trial.
213 Chang CC, Chuang HC, Lin CL, et al. (2014). High incidence of stroke in young women with sleep apnea syndrome. Sleep Med.
214 Chang ET, Shiao GM. (2008). Craniofacial abnormalities in Chinese patients with obstructive and positional sleep apnea. Sleep Med.
215 Chang ET, Yang MC, Wang HM, et al. (2014). Snoring in a sitting position and neck circumference are predictors of sleep apnea in Chinese patients. Sleep and Breathing.
216 Chao TF, Liu CJ, Chen SJ, et al. (2014). Incidence and risk of atrial fibrillation in sleep-disordered breathing without coexistent systemic disease. Circ J.
217 Charuzi I, Fraser D, Peiser J, et al. (1987). Sleep apnea syndrome in the morbidly obese undergoing bariatric surgery. Gastroenterol Clin North Am.
218 Chasens ER, Burke LE, Korytkowski M, et al. (2012). Use of sham-continuous positive airway pressure (CPAP) in a pilot study of treatment of obstructive sleep apnea in adults with diabetes. Am J Respir Crit Care Med.
219 Chasens ER, Burke LE, Korytkowski M, et al. (2012). Effect of continuous positive airway pressure (CPAP) treatment of obstructive sleep apnea on physical activity and glucose control in adults with type 2 diabetes: Results of a pilot study. Am J Respir Crit Care Med.
220 Chasens ER, Drumheller OJ, Strollo PJ. (2013). Success in blinding to group assignment with sham-CPAP. Biol Res Nurs.
221 Chatsis V, Spry C. (2009). Diagnosis of snoring and obstructive sleep apnea: a review of the accuracy. Health Technology Assessment Database.
222 Chediak AD, Acevedo-Crespo JC, Seiden DJ, et al. (1996). Nightly variability in the indices of sleep-disordered breathing in men being evaluated for impotence with consecutive night polysomnograms. Sleep.
223 Cheliout-Heraut F, Senny F, Djouadi F, et al. (2011). Obstructive sleep apnoea syndrome: comparison between polysomnography and portable sleep monitoring based on jaw recordings. Neurophysiol Clin.
224 Chen CY, Hsu CC, Pei YC, et al. (2011). Nocturia is an independent predictor of severe obstructive sleep apnea in patients with ischemic stroke. J Neurol.
225 Chen H, Lowe AA, Bai Y, et al. (2009). Evaluation of a portable recording device (ApneaLink) for case selection of obstructive sleep apnea. Sleep Breath.
226 Chen JC, Hwang JH. (2014). Sleep apnea increased incidence of primary central nervous system cancers: a nationwide cohort study. Sleep Med.
227 Chen NH, Chen MC, Li HY, et al. (2011). A two-tier screening model using quality-of-life measures and pulse oximetry to screen adults with sleep-disordered breathing. Sleep Breath.
228 Chen NH, Johns MW, Li HY, et al. (2002). Validation of a Chinese version of the Epworth sleepiness scale. Qual Life Res.
229 Chen NH, Li HY, Gliklich RE, et al. (2002). Validation assessment of the Chinese version of the Snore Outcomes Survey. Qual Life Res.
230 Chen R, Xiong KP, Huang JY, et al. (2011). Neurocognitive impairment in Chinese patients with obstructive sleep apnoea hypopnoea syndrome. Respirology.
231 Chen YH, Keller JK, Kang JH, et al. (2013). Obstructive sleep apnea and the subsequent risk of depressive disorder: a population-based follow-up study. J Clin Sleep Med.
232 Cherkassky T, Oksenberg A, Froom P, et al. (2003). Sleep-related breathing disorders and rehabilitation outcome of stroke patients: a prospective study. Am J Phys Med Rehabil.
233 Cherniack NS. (1981). Respiratory dysrhythmias during sleep. N Engl J Med.
234 Chervin RD, Aldrich MS. (1999). The Epworth Sleepiness Scale may not reflect objective measures of sleepiness or sleep apnea. Neurology.
235 Chilukuri K, Dalal D, Marine JE, et al. (2009). Predictive value of obstructive sleep apnoea assessed by the Berlin Questionnaire for outcomes after the catheter ablation of atrial fibrillation. Europace.
236 Chin K, Fukuhara S, Takahashi K, et al. (2004). Response shift in perception of sleepiness in obstructive sleep apnea-hypopnea syndrome before and after treatment with nasal CPAP. Sleep.
237 Chin K, Nakamura T, Takahashi K, et al. (2006). Falls in blood pressure in patients with obstructive sleep apnoea after long-term nasal continuous positive airway pressure treatment. J Hypertens.
238 Chiner E, Signes-Costa J, Arriero JM, et al. (1999). Nocturnal oximetry for the diagnosis of the sleep apnoea hypopnoea syndrome: a method to reduce the number of polysomnographies?. Thorax.
239 Cho YW, Lee JH, Son HK, et al. (2011). The reliability and validity of the Korean version of the Epworth sleepiness scale. Sleep Breath.
240 Choi S, Mullins R, Crosby JH, et al. (2001). Is (re)titration of nasal continuous positive airway pressure for obstructive sleep apnoea necessary?. Sleep Med.
241 Chokroverty S, Bhat S, Donnelly D, et al. (2015). Sleep spindle density increases after continuous positive airway pressure titration in severe obstructive sleep apnea: A preliminary study. Sleep Med.
242 Chouchou F, Poupard L, Philippe C, et al. (2013). Thoracic impedance, in association with oximetry, in a multi-modal ECG Holter system is useful for screening sleep disordered breathing. Int J Cardiol.
243 Chouchou F, Sforza E, Celle S, et al. (2011). Pulse transit time in screening sleep disordered breathing in an elderly population: the PROOF-SYNAPSE study. Sleep.
244 Christensen AS, Clark A, Salo P, et al. (2013). Symptoms of sleep disordered breathing and risk of cancer: a prospective cohort study. Sleep.
245 Christou K, Markoulis N, Moulas AN, et al. (2003). Reactive oxygen metabolites (ROMs) as an index of oxidative stress in obstructive sleep apnea patients. Sleep Breath.
246 Chung F, Chau E, Yang Y, et al. (2013). Serum bicarbonate level improves specificity of STOP-Bang screening for obstructive sleep apnea. Chest.
247 Chung F, Liao P, Elsaid H, et al. (2012). Oxygen desaturation index from nocturnal oximetry: a sensitive and specific tool to detect sleep-disordered breathing in surgical patients. Anesth Analg.
248 Chung F, Liao P, Sun Y, et al. (2011). Perioperative practical experiences in using a level 2 portable polysomnography. Sleep Breath.
249 Chung F, Subramanyam R, Liao P, et al. (2012). High STOP-Bang score indicates a high probability of obstructive sleep apnoea. Br J Anaesth.
250 Chung F, Ward B, Ho J, et al. (2007). Preoperative identification of sleep apnea risk in elective surgical patients, using the Berlin questionnaire. J Clin Anesth.
251 Chung F, Yang Y, Liao P. (2013). Predictive performance of the STOP-Bang score for identifying obstructive sleep apnea in obese patients. Obes Surg.
252 Chung F, Yegneswaran B, Liao P, et al. (2008). Validation of the Berlin questionnaire and American Society of Anesthesiologists checklist as screening tools for obstructive sleep apnea in surgical patients. Anesthesiology.
253 Chung F, Yegneswaran B, Liao P, et al. (2008). STOP questionnaire: a tool to screen patients for obstructive sleep apnea. Anesthesiology.
254 Chung SA, Jairam S, Hussain MR, et al. (2002). How, what, and why of sleep apnea. Perspectives for primary care physicians. Can Fam Physician.
255 Ciancio N, Maria A, Bivona L, et al. (2014). Effect of short-term treatment with CPAP on cardiopulmonary exercise test (CPX) in patients with severe obstructive sleep apnea syndrome (OSAS). Eur Respir J.
256 Cicek D, Lakadamyali H, Gokay S, et al. (2012). Effect of obstructive sleep apnea on heart rate, heart rate recovery and QTc and P-wave dispersion in newly diagnosed untreated patients. Am J Med Sci.
257 Cicek D, Lakadamyali H, Yagbasan BD, et al. (2011). Obstructive sleep apnoea and its association with left ventricular function and aortic root parameters in newly diagnosed, untreated patients: a prospective study. J Int Med Res.
258 Cilli A, Uzun R, Bilge U. (2013). The accuracy of autotitrating CPAP-determined residual apnea-hypopnea index. Sleep Breath.
259 Cillo JE, Finn R, Dasheiff RM. (2006). Combined open rhinoplasty with spreader grafts and laser-assisted uvuloplasty for sleep-disordered breathing: long-term subjective outcomes. J Oral Maxillofac Surg.
260 Cillo JE, Thayer S, Dasheiff RM, et al. (2012). Relations between obstructive sleep apnea syndrome and specific cephalometric measurements, body mass index, and apnea-hypopnea index. J Oral Maxillofac Surg.
261 Cintra F, Bittencourt LR, Santos-Silva R, et al. (2012). The association between the Framingham risk score and sleep: a Sao Paulo epidemiological sleep study. Sleep Med.
262 Cizza G, Jonge L, Piaggi P, et al. (2014). Neck circumference is a predictor of metabolic syndrome and obstructive sleep apnea in short-sleeping obese men and women. Metab Syndr Relat Disord.
263 Claman D, Murr A, Trotter K. (2001). Clinical validation of the Bedbugg in detection of obstructive sleep apnea. Otolaryngol Head Neck Surg.
264 Clark AL, Crabbe S, Aziz A, et al. (2009). Use of a screening tool for detection of sleep-disordered breathing. J Laryngol Otol.
265 ClinicalTrials.gov. (2015). NCT01988129. Fire Fighter Fatigue Management Program: Operation Healthy Sleep.
266 Cohen R, Pinheiro JS, Correa JL, et al. (2006). Laparoscopic Roux-en-Y gastric bypass for BMI < 35 kg/m(2): a tailored approach. Surg Obes Relat Dis.
267 Cohen-Zion M, Stepnowsky C, Marler, et al. (2001). Changes in cognitive function associated with sleep disordered breathing in older people. J Am Geriatr Soc.
268 Colish J, Walker JR, Elmayergi N, et al. (2012). Obstructive sleep apnea: effects of continuous positive airway pressure on cardiac remodeling as assessed by cardiac biomarkers, echocardiography, and cardiac MRI. Chest.
269 Coma-Del-Corral MJ, Alonso-Alvarez ML, Allende M, et al. (2013). Reliability of telemedicine in the diagnosis and treatment of sleep apnea syndrome. Telemed J E Health.
270 Comondore VR, Cheema R, Fox J, et al. (2009). The impact of CPAP on cardiovascular biomarkers in minimally symptomatic patients with obstructive sleep apnea: a pilot feasibility randomized crossover trial. Lung.
271 Cooke JR, Ancoli-Israel S, Liu L, et al. (2009). Continuous positive airway pressure deepens sleep in patients with Alzheimer's disease and obstructive sleep apnea. Sleep Med.
272 Cooke JR, Ayalon L, Palmer BW, et al. (2009). Sustained use of CPAP slows deterioration of cognition, sleep, and mood in patients with Alzheimer's disease and obstructive sleep apnea: a preliminary study. J Clin Sleep Med.
273 Cooper B, Rowland C, Berend N, et al. (2005). Does sleep disordered breathing contribute to uncontrolled hypertension? results of treatment with CPAP. Nephrology (Carlton, Vic.).
274 Cooper BG, Veale D, Griffiths CJ, et al. (1991). Value of nocturnal oxygen saturation as a screening test for sleep apnoea. Thorax.
275 Costa LE, Uchôa CHG, Harmon RR, et al. (2015). Potential underdiagnosis of obstructive sleep apnoea in the cardiology outpatient setting. Heart.
276 Coughlin SR, Mugarza JA, Mawdsley L, et al. (2004). Continuous positive airways pressure treatment reduces the cardiovascular risk factors associated with obstructive sleep apnoea.
277 Craig S, Kylintireas I, Kohler M, et al. (2015). Effect of CPAP on cardiac function in minimally symptomatic patients with OSA: Results from a subset of the MOSAIC randomized trial. J Clin Sleep Med.
278 Craig S, Pepperell JC, Kohler M, et al. (2009). Continuous positive airway pressure treatment for obstructive sleep apnoea reduces resting heart rate but does not affect dysrhythmias: a randomised controlled trial. J Sleep Res.
279 Craig SE, Kohler M, Nicoll D, et al. (2011). Does Continuous Positive Airways Pressure (CPAP) For Minimally Symptomatic Obstructive Sleep Apnoea (OSA) Reduce Calculated Cardiovascular Risk? Primary Results From Mosaic, A Randomized Controlled Trial. Am J Respir Crit Care Med.
280 Crawford MR, Bartlett DJ, Coughlin SR, et al. (2012). The effect of continuous positive airway pressure usage on sleepiness in obstructive sleep apnoea: Real effects or expectation of benefit?. Thorax.
281 Crawford-Achour E, Dauphinot V, Martin MS, et al. (2015). Protective effect of long-term CPAP therapy on cognitive performance in elderly patients with severe OSA: The PROOF study. J Clin Sleep Med.
282 Crocker BD, Olson LG, Saunders NA, et al. (1990). Estimation of the probability of disturbed breathing during sleep before a sleep study. Am Rev Respir Dis.
283 Cross MD, Al-Abri M, Newby DE, et al. (2005). Randomised controlled trial evidence that continuous positive airway pressure improves vascular function in obstructive in obstructive sleep apnoea syndrome. Thorax.
284 Cross MD, Al-Abri M, Newby DE, et al. RCT evidence that CPAP improves endothelial function in obstructive sleep apnea hypopnea syndrome (OSAHS).
285 Cross MD, Vennelle M, Engleman HM, et al. Predictors of poor titration and outcome in patients with obstructive sleep apnea/hypopnea syndrome 9OSAHS) after home or hospital automated CPAP titration.
286 Crowley KE, Rajaratnam SM, Shea SA, et al. (2013). Evaluation of a single-channel nasal pressure device to assess obstructive sleep apnea risk in laboratory and home environments. J Clin Sleep Med.
287 DÃ-az-Cambriles T, DÃ-az-Atauri MJ, PÃ©rez-Rojo R, et al. (2002). CPAP treatment for obstructive sleep apnoea syndrome after CPAP training term. Eur Respir J.
288 D'Addio G, De Felice A, Balzano G, et al. (2013). Diagnostic decision support of heart rate turbulence in sleep apnea syndrome. Stud Health Technol Inform.
289 Dahlqvist J, Dahlqvist A, Marklund M, et al. (2007). Physical findings in the upper airways related to obstructive sleep apnea in men and women. Acta Otolaryngol.
290 Dal-Fabbro C, Garbuio S, D'Almeida V, et al. (2014). Mandibular advancement device and CPAP upon cardiovascular parameters in OSA. Sleep and Breathing.
291 Dalmases M, Sole-Padulles C, Bartres-Faz D, et al. (2014). Obstructive sleep apnea in elderly patients: Neuroimage and cognitive function before and after treatment. Eur Respir J.
292 Damiani MF, Quaranta VN, Falcone VA, et al. (2013). The Epworth Sleepiness Scale: conventional self vs physician administration. Chest.
293 Damy T, Margarit L, Noroc A, et al. (2012). Prognostic impact of sleep-disordered breathing and its treatment with nocturnal ventilation for chronic heart failure. Eur J Heart Fail.
294 Danzi-Soares NJ, Genta PR, Nerbass FB, et al. (2012). Obstructive sleep apnea is common among patients referred for coronary artery bypass grafting and can be diagnosed by portable monitoring. Coron Artery Dis.
295 Davidson TM, Patel MR. (2008). Waist circumference and sleep disordered breathing. Laryngoscope.
296 Davies RJ, Harrington KJ, Ormerod OJ, et al. (1993). Nasal continuous positive airway pressure in chronic heart failure with sleep-disordered breathing. Am Rev Respir Dis.
297 Davies RJ, Vardi-Visy K, Clarke M, et al. (1993). Identification of sleep disruption and sleep disordered breathing from the systolic blood pressure profile. Thorax.
298 de Almeida FR, Ayas NT, Otsuka R, et al. (2006). Nasal pressure recordings to detect obstructive sleep apnea. Sleep Breath.
299 De Araujo MTM, Bissoli NS, Gouvea SA, et al. (2013). CPAP therapy prevents increase in blood pressure after upper airway surgery for obstructive sleep apnoea. Sleep and Breathing.
300 De Jesus Danzi-Soares N, Genta PR, Nerbass FB, et al. (2012). Obstructive sleep apnea is common among patients referred for coronary artery bypass grafting and can be diagnosed by portable monitoring. Coron Artery Dis.
301 de la Hoz RE, Aurora RN, Landsbergis P, et al. (2010). Snoring and obstructive sleep apnea among former World Trade Center rescue workers and volunteers. J Occup Environ Med.
302 de Oliveira AC, Martinez D, Massierer D, et al. (2014). The antihypertensive effect of positive airway pressure on resistant hypertension of patients with obstructive sleep apnea: a randomized, double-blind, clinical trial. Am J Respir Crit Care Med.
303 de Silva S, Abeyratne UR, Hukins C. (2011). A method to screen obstructive sleep apnea using multi-variable non-intrusive measurements. Physiol Meas.
304 Deegan PC, McNicholas WT. (1996). Predictive value of clinical features for the obstructive sleep apnoea syndrome. Eur Respir J.
305 Dehkordi P, Marzencki M, Tavakolian K, et al. (2011). Validation of respiratory signal derived from suprasternal notch acceleration for sleep apnea detection. Conf Proc IEEE Eng Med Biol Soc.
306 Dehkordi P, Marzencki M, Tavakolian K, et al. (2012). Monitoring torso acceleration for estimating the respiratory flow and efforts for sleep apnea detection. Conf Proc IEEE Eng Med Biol Soc.
307 Delko T, Kostler T, Peev M, et al. (2013). Influence of additional resection of the gastric fundus on excessive weight loss in laparoscopic very very long limb Roux-en-Y gastric bypass. Obes Surg.
308 Della Marca G, Pantanali F, Frusciante R, et al. (2011). Cephalometric findings in facioscapulohumeral muscular dystrophy patients with obstructive sleep apneas. Sleep Breath.
309 DeMolles DA, Sparrow D, Gottlieb DJ, et al. (2004). A pilot trial of a telecommunications system in sleep apnea management. Med Care.
310 Denotti AL, Wong KK, Dungan GC, et al. (2012). Residual sleep-disordered breathing during autotitrating continuous positive airway pressure therapy. Eur Respir J.
311 Dette FG, Hildebrandt O, Arntz W, et al. (2015). Dtsch Med Wochenschr.
312 Devouassoux G, Lévy P, Rossini E, et al. (2007). Sleep apnea is associated with bronchial inflammation and continuous positive airway pressure-induced airway hyperresponsiveness. J Allergy Clin Immunol.
313 Deyoung PN, Bakker JP, Sands SA, et al. (2013). Acoustic pharyngometry measurement of minimal cross-sectional airway area is a significant independent predictor of moderate-to-severe obstructive sleep apnea. J Clin Sleep Med.
314 Diaferia G, Badke L, Santos-Silva R, et al. (2013). Effect of speech therapy as adjunct treatment to continuous positive airway pressure on the quality of life of patients with obstructive sleep apnea. Sleep Med.
315 Dick R, Penzel T, Fietze I, et al. (2010). AASM standards of practice compliant validation of actigraphic sleep analysis from SOMNOwatch versus polysomnographic sleep diagnostics shows high conformity also among subjects with sleep disordered breathing. Physiol Meas.
316 Dickel MJ, Mosko SS. (1990). Morbidity cut-offs for sleep apnea and periodic leg movements in predicting subjective complaints in seniors. Sleep.
317 Dimsdale JE, Loredo JS, Profant J. (2000). Effect of continuous positive airway pressure on blood pressure : a placebo trial. Hypertension.
318 Dinc AE, Yilmaz M, Tutar H, et al. (2014). Reliability of SleepStrip as a screening test in obstructive sleep apnea patients. Eur Arch Otorhinolaryngol.
319 Ding X, Zhang J, Bian Q, et al. (2014). Zhonghua Yi Xue Za Zhi.
320 Dingli K, Coleman EL, Vennelle M, et al. (2003). Evaluation of a portable device for diagnosing the sleep apnoea/hypopnoea syndrome. Eur Respir J.
321 Dixon J, Schachter L, O'Brien P, et al. (2012). Surgical versus conventional therapy for weight loss treatment of obstructive sleep apnea: A randomized controlled trial. Obesity Research and Clinical Practice.
322 Dixon JB, Dixon ME, Anderson ML, et al. (2007). Daytime sleepiness in the obese: not as simple as obstructive sleep apnea. Obesity (Silver Spring).
323 Dixon JB, Schachter LM, O'Brien PE. (2003). Predicting sleep apnea and excessive day sleepiness in the severely obese: indicators for polysomnography. Chest.
324 Doff MH, Veldhuis SK, Hoekema A, et al. (2012). Long-term oral appliance therapy in obstructive sleep apnea syndrome: a controlled study on temporomandibular side effects. Clin Oral Investig.
325 Dorman RB, Miller CJ, Leslie DB, et al. (2012). Risk for hospital readmission following bariatric surgery. PLoS One.
326 Dort L, Brant R. (2008). A randomized, controlled, crossover study of a noncustomized tongue retaining device for sleep disordered breathing. Schlaf & Atmung.
327 Dosman JA, Hagel L, Skomro R, et al. (2013). Loud snoring is a risk factor for occupational injury in farmers. Can Respir J.
328 Douglas NJ, Engleman HM. (2000). Effects of CPAP on vigilance and related functions in patients with the sleep apnea/hypopnea syndrome. Sleep.
329 Douglas NJ, Thomas S, Jan MA. (1992). Clinical value of polysomnography. Lancet.
330 Drager LF, Bortolotto LA, Figueiredo AC, et al. (2007). Effects of continuous positive airway pressure on early signs of atherosclerosis in obstructive sleep apnea. Am J Respir Crit Care Med.
331 Drager LF, Genta PR, Pedrosa RP, et al. (2010). Characteristics and predictors of obstructive sleep apnea in patients with systemic hypertension. Am J Cardiol.
332 Drager LF, Pedrosa RP, Diniz PM, et al. (2011). The effects of continuous positive airway pressure on prehypertension and masked hypertension in men with severe obstructive sleep apnea. Hypertension.
333 Dreher A, de la Chaux R, Klemens C, et al. (2005). Correlation between otorhinolaryngologic evaluation and severity of obstructive sleep apnea syndrome in snorers. Arch Otolaryngol Head Neck Surg.
334 Driver HS, Pereira EJ, Bjerring K, et al. (2011). Validation of the MediByte(R) type 3 portable monitor compared with polysomnography for screening of obstructive sleep apnea. Can Respir J.
335 Duarte FH, Jallad RS, Amaro AC, et al. (2013). The impact of sleep apnea treatment on carbohydrate metabolism in patients with acromegaly. Pituitary.
336 Duong L, Jayaram L, Camferman D, et al. (2004). Does heated humidification during initial nasal CPAP titration in obstructive sleep apnoea (OSA) reduce morning nasal airway resistance (NAR) and nasal symptoms or improve subjective response to therapy?. Internal medicine journal.
337 Duong M, Jayaram L, Camfferman D, et al. (2005). Use of heated humidification during nasal CPAP titration in obstructive sleep apnoea syndrome. Eur Respir J.
338 Duran CJ, Aizpuru F, Egea C, et al. (2010). Diagnosis Supersimplified of Patients With Suspected Obstructive Sleep Apnoea-hypopnoea (OSAH). Am J Respir Crit Care Med.
339 Duran J, Esnaola S, Rubio R, et al. (2001). Obstructive sleep apnea-hypopnea and related clinical features in a population-based sample of subjects aged 30 to 70 yr. Am J Respir Crit Care Med.
340 Duran J, Torre G, Martinez Null C, et al. (2007). Efficacy of continuous positive pressure (CPAP) on de novo hypertension with sleep apnea hypopnea syndrome (SAHS).
341 Duran JJ, Esnaola S, Ubio R, et al. (2002). A randomised, double blind, crossover, placebo-controlled trial of mandibular advancement device for the treatment of snoring and mild obstructive sleep apnoea-hypopnoea syndrome. Eur Respir J.
342 Duran-Cantolla J, Aizpuru F, Martinez C, et al. (2008). Efficacy of continuous positive pressure (CPAP) on patients with recently diagnosed systemic hypertension (SH) and obstructive sleep apnea-hypopnea (OSAH).
343 Duran-Cantolla J, Aizpuru F, Martinez-Nulll C, et al. (2008). CPAP treatment reduce blood pressure in patients with recent diagnosis of systemic hypertension and obstructive sleep apnoea hypopnoea (OSAH) A controlled study.
344 Dursunoglu N, Ozkurt S, Sarikaya S. (2009). Is the clinical presentation different between men and women admitting to the sleep laboratory?. Sleep Breath.
345 Dyugovskaya L, Lavie P, Hirsh M, et al. (2005). Activated CD8+ T-lymphocytes in obstructive sleep apnoea. The European respiratory journal.
346 Ecri. (2002). Mandibular advancement devices for obstructive sleep apnea. Health Technology Assessment Database.
347 Eiseman NA, Westover MB, Mietus JE, et al. (2012). Classification algorithms for predicting sleepiness and sleep apnea severity. J Sleep Res.
348 Ekinci M, Huseyinoglu N, Cagatay HH, et al. (2013). Is there a relationship between sleep apnea and central corneal thickness?. Curr Eye Res.
349 ElKholy SH, Amer HA, Nada MM, et al. (2012). Sleep-related breathing disorders in cerebrovascular stroke and transient ischemic attacks: a comparative study. J Clin Neurophysiol.
350 el-Solh AA, Mador MJ, Ten-Brock E, et al. (1999). Validity of neural network in sleep apnea. Sleep.
351 Emsellem HA, Corson WA, Rappaport BA, et al. (1990). Verification of sleep apnea using a portable sleep apnea screening device. South Med J.
352 Enciso R, Clark GT. (2011). Comparing the Berlin and the ARES questionnaire to identify patients with obstructive sleep apnea in a dental setting. Sleep Breath.
353 Endeshaw Y. (2006). Clinical characteristics of obstructive sleep apnea in community-dwelling older adults. J Am Geriatr Soc.
354 Engleman HM, Gough K, Martin SE, et al. (1996). Ambulatory blood pressure on and off continuous positive airway pressure therapy for the sleep apnea/hypopnea syndrome: effects in “non-dippers”. Sleep.
355 Epstein LJ, Strollo PJ, Donegan RB, et al. (1995). Obstructive sleep apnea in patients with human immunodeficiency virus (HIV) disease. Sleep.
356 Erman MK, Stewart D, Einhorn D, et al. (2007). Validation of the ApneaLink for the screening of sleep apnea: a novel and simple single-channel recording device. J Clin Sleep Med.
357 Esilva LO, Luz GP, Guimaraes TD, et al. (2014). Effectiveness of continuous positive airway pressure (CPAP) and oral appliance (OA) over mild obstructive sleep apnea syndrome (OSAS): A randomised, parallel, simple, blind, controlled study. Sleep.
358 Eskandari D, Zou D, Karimi M, et al. (2014). Zonisamide reduces obstructive sleep apnoea: a randomised placebo-controlled study. Eur Respir J.
359 Esnaola S, Duran J, Infante-Rivard C, et al. (1996). Diagnostic accuracy of a portable recording device (MESAM IV) in suspected obstructive sleep apnoea. Eur Respir J.
360 Esquinas C, Sanchez-de-la Torre M, Aldoma A, et al. (2013). Rationale and methodology of the impact of continuous positive airway pressure on patients with ACS and nonsleepy OSA: the ISAACC Trial. Clin Cardiol.
361 Eun YG, Kwon KH, Shin SY, et al. (2009). Multilevel surgery in patients with rapid eye movement-related obstructive sleep apnea. Otolaryngol Head Neck Surg.
362 Faccenda JF, Boon NA, Mackay TW, et al. (2000). CPAP effects on blood pressure in the sleep apnea/hypopnea syndrome (SAHS) during a randomized controlled trial. Am J Respir Crit Care Med.
363 Faccenda JF, Boon NA, Mackay TW, et al. (2000). Quality of life on and off CPAP in patients with sleep apnea/hypopnea syndrome. Am J Respir Crit Care Med.
364 Falcone VA, Damiani MF, Quaranta VN, et al. (2014). Polysomnograph Chart View by Patients: A New Educational Strategy to Improve CPAP Adherence in Sleep Apnea Therapy. Respir Care.
365 Faria AC, da Costa CH, Rufino R. (2015). Sleep apnea clinical score, Berlin questionnaire, or Epworth sleepiness scale: Which is the best obstructive sleep apnea predictor in patients with COPD?. Int J Gen Med.
366 Farney RJ, Walker BS, Farney RM, et al. (2011). The STOP-Bang equivalent model and prediction of severity of obstructive sleep apnea: relation to polysomnographic measurements of the apnea/hypopnea index. J Clin Sleep Med.
367 Farney RJ, Walker LE, Jensen RL, et al. (1986). Ear oximetry to detect apnea and differentiate rapid eye movement (REM) and non-REM (NREM) sleep. Screening for the sleep apnea syndrome. Chest.
368 Farré R, Hernández L, Montserrat JM, et al. (1999). Sham continuous positive airway pressure for placebo-controlled studies in sleep apnoea. Lancet.
369 Fava C, Dorigoni S, Dalle Vedove F, et al. (2013). Effect of continuous positive airway pressure (CPAP) on blood pressure in patients with obstructive sleep apnea/hypopnea. a systematic review and meta-analysis. Chest.
370 Feigel-Guiller B, Drui D, Dimet J, et al. (2015). Laparoscopic Gastric Banding in Obese Patients with Sleep Apnea: A 3-Year Controlled Study and Follow-up After 10 Years. Obes Surg.
371 Feng J, He QY, Zhang XL, et al. (2012). Epworth Sleepiness Scale may be an indicator for blood pressure profile and prevalence of coronary artery disease and cerebrovascular disease in patients with obstructive sleep apnea. Sleep Breath.
372 Fenton ME, Heathcote K, Bryce R, et al. (2014). The utility of the elbow sign in the diagnosis of OSA. Chest.
373 Feres MC, Fonseca FAH, Cintra FD, et al. (2015). An assessment of oxidized LDL in the lipid profiles of patients with obstructive sleep apnea and its association with both hypertension and dyslipidemia, and the impact of treatment with CPAP. Atherosclerosis.
374 Ferrier K, Neill A, Campbell A, et al. (2004). Nasal continuous positive airway pressure (NCPAP) in obstructive sleep apnoea (OSA) and heart failure (HF). Internal medicine journal.
375 Ferrier KA, Neill AM, O'Meeghan T, et al. (2008). Continuous positive airway pressure in heart failure patients with obstructive sleep apnoea. Intern Med J.
376 Ficker JH, Clarenbach CF, Neukirchner C, et al. (2003). Auto-CPAP therapy based on the forced oscillation technique. Biomed Tech (Berl).
377 Ficker JH, Fischer C, Wiest GM, et al. (1997). Efficacy of auto-CPAP in the treatment of obstructive sleep apnoea syndrome (OSA). European Respiratory Journal - Supplement.
378 Ficker JH, Wiest GH, Wilpert J, et al. (2001). Evaluation of a portable recording device (Somnocheck) for use in patients with suspected obstructive sleep apnoea. Respiration.
379 Fietze I, Glos M, Rottig J, et al. (2002). Automated analysis of data is inferior to visual analysis of ambulatory sleep apnea monitoring. Respiration.
380 Filtness AJ, Reyner LA, Horne JA. (2012). One night's CPAP withdrawal in otherwise compliant OSA patients: marked driving impairment but good awareness of increased sleepiness. Sleep Breath.
381 Finkel KJ, Searleman AC, Tymkew H, et al. (2009). Prevalence of undiagnosed obstructive sleep apnea among adult surgical patients in an academic medical center. Sleep Med.
382 Firat H, Yuceege M, Demir A, et al. (2012). Comparison of four established questionnaires to identify highway bus drivers at risk for obstructive sleep apnea in Turkey. Sleep Biol Rhythms.
383 Fischer MK, Martinez D, Cassol CM, et al. (2012). Immediate and overnight recumbence-dependent changes of neck circumference: relationship with OSA severity in obese and nonobese subjects. Sleep Med.
384 Fisher D, Pillar G, Malhotra A, et al. (2002). Long-term follow-up of untreated patients with sleep apnoea syndrome. Respir Med.
385 Fisher JG, de la Pena AM. (1981). Sleep apnea: a clinical perspective. South Med J.
386 Fleetham J, Ayas N, Bradley D, et al. (2011). Canadian Thoracic Society 2011 guideline update: diagnosis and treatment of sleep disordered breathing. Can Respir J.
387 Flemons WW, Whitelaw WA, Brant R, et al. (1994). Likelihood ratios for a sleep apnea clinical prediction rule. Am J Respir Crit Care Med.
388 Fleury B, Rakotonanahary D, Hausser-Hauw C, et al. (1996). A laboratory validation study of the diagnostic mode of the Autoset system for sleep-related respiratory disorders. Sleep.
389 Flick K, Umlauf F, Igel J, et al. (1998). Auto-CPAP in the therapy of obstructive sleep apnoea syndrome. Pneumologie (Stuttgart, Germany).
390 Foldvary-Schaefer N, Andrews ND, Pornsriniyom D, et al. (2012). Sleep apnea and epilepsy: who's at risk?. Epilepsy Behav.
391 Franceschi M, Zamproni P, Crippa D, et al. (1982). Excessive daytime sleepiness: a 1-year study in an unselected inpatient population. Sleep.
392 Franklin KA, Haglund B, Axelsson S, et al. (2011). Frequency of serious complications after surgery for snoring and sleep apnea. Acta Otolaryngol.
393 Fraser CL, Bliwise DL, Newman NJ, et al. (2013). A prospective photographic study of the ocular fundus in obstructive sleep apnea. J Neuroophthalmol.
394 Fredheim JM, Roislien J, Hjelmesaeth J. (2014). Validation of a portable monitor for the diagnosis of obstructive sleep apnea in morbidly obese patients. J Clin Sleep Med.
395 Fredheim JM, Rollheim J, Hjelmesaeth J. (2011). Effect of bariatric surgery and intensive lifestyle intervention on obstructive sleep apnea: A controlled clinical trial. Obesity Reviews.
396 Fredheim JM, Rollheim J, Sandbu R, et al. (2013). Obstructive sleep apnea after weight loss: a clinical trial comparing gastric bypass and intensive lifestyle intervention. J Clin Sleep Med.
397 Freire AO, Sugai GC, Chrispin FS, et al. (2007). Treatment of moderate obstructive sleep apnea syndrome with acupuncture: a randomised, placebo-controlled pilot trial. Sleep Med.
398 Freire AO, Sugai GC, Togeiro SM, et al. (2010). Immediate effect of acupuncture on the sleep pattern of patients with obstructive sleep apnoea. Acupunct Med.
399 Friedman M, Ibrahim H, Joseph NJ. (2004). Staging of obstructive sleep apnea/hypopnea syndrome: a guide to appropriate treatment. Laryngoscope.
400 Friedman M, Maley A, Taylor D, et al. (2011). Treatment of pediatric obstructive sleep apnea beyond tonsillectomy and adenoidectomy. Otolaryngology - Head and Neck Surgery.
401 Friedman M, Schalch P, Joseph NJ. (2006). Palatal implant for the treatment of OSAHS and snoring. Otolaryngology - Head and Neck Surgery.
402 Friedman M, Schalch P, Lin HC, et al. (2008). Palatal implants for the treatment of snoring and obstructive sleep apnea/hypopnea syndrome. Otolaryngol Head Neck Surg.
403 Friedman M, Tanyeri H, La Rosa M, et al. (1999). Clinical predictors of obstructive sleep apnea. Laryngoscope.
404 Friedman M, Wilson MN, Pulver T, et al. (2010). Screening for obstructive sleep apnea/hypopnea syndrome: subjective and objective factors. Otolaryngol Head Neck Surg.
405 Fry JM, DiPhillipo MA, Curran K, et al. (1998). Full polysomnography in the home. Sleep.
406 Fuller JM, Wong KK, Grunstein R, et al. (2014). A comparison of screening methods for sleep disorders in Australian community pharmacies: A randomized controlled trial. PLoS One.
407 Fung CH, Martin JL, Dzierzewski JM, et al. (2013). Prevalence and symptoms of occult sleep disordered breathing among older veterans with insomnia. J Clin Sleep Med.
408 Fung MM, Peters K, Redline S, et al. (2011). Decreased slow wave sleep increases risk of developing hypertension in elderly men. Hypertension.
409 Furukawa T, Suzuki M, Funatogawa I, et al. (2009). Screening method for severe sleep-disordered breathing in hypertensive patients without daytime sleepiness. J Cardiol.
410 Gabbay IE, Lavie P. (2012). Age- and gender-related characteristics of obstructive sleep apnea. Sleep Breath.
411 Gagnadoux F, Le Vaillant M, Goupil F, et al. (2014). Depressive symptoms before and after long-term CPAP therapy in patients with sleep apnea. Chest.
412 Gagnadoux F, Pelletier-Fleury N, Philippe C, et al. (2002). Home unattended vs hospital telemonitored polysomnography in suspected obstructive sleep apnea syndrome: A randomized crossover trial. Chest.
413 Gali B, Whalen FX, Schroeder DR, et al. (2009). Identification of patients at risk for postoperative respiratory complications using a preoperative obstructive sleep apnea screening tool and postanesthesia care assessment. Anesthesiology.
414 Gami AS, Hodge DO, Herges RM, et al. (2007). Obstructive sleep apnea, obesity, and the risk of incident atrial fibrillation. J Am Coll Cardiol.
415 Gami AS, Olson EJ, Shen WK, et al. (2013). Obstructive sleep apnea and the risk of sudden cardiac death: a longitudinal study of 10,701 adults. J Am Coll Cardiol.
416 Gami AS, Pressman G, Caples SM, et al. (2004). Association of atrial fibrillation and obstructive sleep apnea. Circulation.
417 Gantner D, Ge JY, Li LH, et al. (2010). Diagnostic accuracy of a questionnaire and simple home monitoring device in detecting obstructive sleep apnoea in a Chinese population at high cardiovascular risk. Respirology.
418 Garbarino S, Guglielmi O, Sanna A, et al. (2016). Risk of occupational accidents in workers with obstructive sleep apnea: Systematic review and meta-analysis. Sleep.
419 Garbarino S, Magnavita N. (2014). Obstructive Sleep Apnea Syndrome (OSAS), metabolic syndrome and mental health in small enterprise workers. feasibility of an Action for Health. PLoS One.
420 Garcia-Campos EP, Labra A, Galicia-Polo L, et al. (2014). Decrease of respiratory events in patients with OSAS, using a mandibular advancement device (MAD), assessed with split night polysomnography, in a Mexican population. J Sleep Res.
421 Garcia-Diaz E, Quintana-Gallego E, Ruiz A, et al. (2007). Respiratory polygraphy with actigraphy in the diagnosis of sleep apnea-hypopnea syndrome. Chest.
422 Garcia-Rio F, Alonso-Fernandez A, Armada E, et al. (2013). CPAP effect on recurrent episodes in patients with sleep apnea and myocardial infarction. Int J Cardiol.
423 Gasa M, Salord N, Fortuna AM, et al. (2013). Optimizing screening of severe obstructive sleep apnea in patients undergoing bariatric surgery. Surg Obes Relat Dis.
424 Gasa M, Tamisier R, Launois SH, et al. (2013). Residual sleepiness in sleep apnea patients treated by continuous positive airway pressure. J Sleep Res.
425 Gast H, Schwalen S, Ringendahl H, et al. (2006). Sleep-related breathing disorders and continuous positive airway pressure-related changes in cognition. Sleep Med Clin.
426 Gauthier L, Laberge L, Beaudry M, et al. (2009). Efficacy of two mandibular advancement appliances in the management of snoring and mild-moderate sleep apnea: a cross-over randomized study. Sleep Med.
427 Ge X, Han F, Huang Y, et al. (2013). Is obstructive sleep apnea associated with cardiovascular and all-cause mortality?. PLoS One.
428 Geiger-Brown J, Rogers VE, Han K, et al. (2013). Occupational screening for sleep disorders in 12-h shift nurses using the Berlin Questionnaire. Sleep Breath.
429 Gelir E, Budak MT, Ardic S. (2014). The relationship between CPAP usage and corneal thickness. PLoS One.
430 Ghiciuc CM, Dima Cozma LC, Bercea RM, et al. (2013). Restoring the salivary cortisol awakening response through nasal continuous positive airway pressure therapy in obstructive sleep apnea. Chronobiol Int.
431 Ghuman M, Ludwig MJ, Anna LS. (2011). FPIN's clinical inquiries. Clinical indicators of obstructive sleep apnea. Am Fam Physician.
432 Gilat H, Vinker S, Buda I, et al. (2014). Obstructive sleep apnea and cardiovascular comorbidities: a large epidemiologic study. Medicine (Baltimore).
433 Gillespie MB, Wylie PE, Lee-Chiong T, et al. (2011). Effect of palatal implants on continuous positive airway pressure and compliance. Otolaryngol Head Neck Surg.
434 Gilman MP, Floras JS, Usui K, et al. (2008). Continuous positive airway pressure increases heart rate variability in heart failure patients with obstructive sleep apnoea. Clinical science (London, England : 1979).
435 Giordani I, Malandrucco I, Picconi F, et al. (2013). Preliminary evidence that obese patients with obstructive sleep apnea/hypopnea syndrome are refractory to the acute beneficial metabolic effects of a very low calorie diet. Acta Diabetol.
436 Gislason T, Almqvist M, Eriksson G, et al. (1988). Prevalence of sleep apnea syndrome among Swedish men--an epidemiological study. J Clin Epidemiol.
437 Gjevre JA, Taylor-Gjevre RM, Nair BV, et al. (2012). Do sleepy rheumatoid arthritis patients have a sleep disorder?. Musculoskeletal Care.
438 Gjevre JA, Taylor-Gjevre RM, Skomro R, et al. (2011). Comparison of polysomnographic and portable home monitoring assessments of obstructive sleep apnea in Saskatchewan women. Can Respir J.
439 Glebocka A, Kossowska A, Bednarek M. (2006). Obstructive sleep apnea and the quality of life. J Physiol Pharmacol.
440 Glidewell RN, Roby EK, Orr WC. (2012). Is insomnia an independent predictor of obstructive sleep apnea?. J Am Board Fam Med.
441 Gold AR, Schwartz AR, Bleecker ER, et al. (1986). The effect of chronic nocturnal oxygen administration upon sleep apnea. Am Rev Respir Dis.
442 Golding-Wood DG, Brockbank MJ, Swanston AR, et al. (1990). Assessment of chronic snorers. J R Soc Med.
443 Golpe R, Jiménez A, Carpizo R. (2002). Home sleep studies in the assessment of sleep apnea/hypopnea syndrome. Chest.
444 Gondim LM, Matumoto LM, Melo Junior MA, et al. (2007). Comparative study between clinical history and polysomnogram in the obstructive sleep apnea/ hypopnea syndrome. Braz J Otorhinolaryngol.
445 González-Muniesa P, Lopez-Pascual A, de Andrés J, et al. (2015). Impact of intermittent hypoxia and exercise on blood pressure and metabolic features from obese subjects suffering sleep apnea-hypopnea syndrome. J Physiol Biochem.
446 Gonzalez-Rothi RJ, Foresman GE, Block AJ. (1988). Do patients with sleep apnea die in their sleep?. Chest.
447 Goodrich S, Orr WC. (2009). An investigation of the validity of the Lifeshirt in comparison to standard polysomnography in the detection of obstructive sleep apnea. Sleep Med.
448 Gottlieb DJ, Whitney CW, Bonekat WH, et al. (1999). Relation of sleepiness to respiratory disturbance index: the Sleep Heart Health Study. Am J Respir Crit Care Med.
449 Green BT, Broughton WA, O'Connor JB. (2003). Marked improvement in nocturnal gastroesophageal reflux in a large cohort of patients with obstructive sleep apnea treated with continuous positive airway pressure. Arch Intern Med.
450 Greenburg DL, Lettieri CJ, Eliasson AH. (2009). Effects of surgical weight loss on measures of obstructive sleep apnea: a meta-analysis. Am J Med.
451 Grimm W, Apelt S, Timmesfeld N, et al. (2013). Sleep-disordered breathing in patients with implantable cardioverter-defibrillator. Europace.
452 Grote L, Hedner J, Peter JH. (2000). Sleep-related breathing disorder is an independent risk factor for uncontrolled hypertension. J Hypertens.
453 Gruber A, Horwood F, Sithole J, et al. (2006). Obstructive sleep apnoea is independently associated with the metabolic syndrome but not insulin resistance state. Cardiovasc Diabetol.
454 Grunstein R, Wilcox I, Yang TS, et al. (1993). Snoring and sleep apnoea in men: association with central obesity and hypertension. Int J Obes Relat Metab Disord.
455 Grunstein RR, Stenlof K, Hedner JA, et al. (2007). Two year reduction in sleep apnea symptoms and associated diabetes incidence after weight loss in severe obesity. Sleep.
456 Grunstein RR, Stenlof K, Hedner JA, et al. (1995). Impact of self-reported sleep-breathing disturbances on psychosocial performance in the Swedish Obese Subjects (SOS) Study. Sleep.
457 Gubbi J, Khandoker A, Palaniswami M. (2012). Classification of sleep apnea types using wavelet packet analysis of short-term ECG signals. J Clin Monit Comput.
458 Guest JF, Panca M, Sladkevicius E, et al. (2014). Clinical outcomes and cost-effectiveness of continuous positive airway pressure to manage obstructive sleep apnea in patients with type 2 diabetes in the U.K. Diabetes Care.
459 Gugger M. (1997). Comparison of ResMed AutoSet (version 3.03) with polysomnography in the diagnosis of the sleep apnoea/hypopnoea syndrome. Eur Respir J.
460 Gugger M, Mathis J, Bassetti C. (1995). Accuracy of an intelligent CPAP machine with in-built diagnostic abilities in detecting apnoeas: a comparison with polysomnography. Thorax.
461 Guilleminault C, Davis K, Huynh NT. (2008). Prospective randomized study of patients with insomnia and mild sleep disordered breathing. Sleep.
462 Guilleminault C, Stoohs R, Clerk A, et al. (1993). Excessive daytime somnolence in women with abnormal respiratory efforts during sleep. Sleep.
463 Guimaraes KC, Drager LF, Genta PR, et al. (2009). Effects of oropharyngeal exercises on patients with moderate obstructive sleep apnea syndrome. Am J Respir Crit Care Med.
464 Gulati A, Chate RA, Howes TQ. (2010). Can a single cephalometric measurement predict obstructive sleep apnea severity?. J Clin Sleep Med.
465 Gupta S. (1974). Caarcio-pulmonary mainfestations in obesity. J Assoc Physicians India.
466 Guralnick AS, Pant M, Minhaj M, et al. (2012). CPAP adherence in patients with newly diagnosed obstructive sleep apnea prior to elective surgery. J Clin Sleep Med.
467 Gurubhagavatula I, Maislin G, Nkwuo JE, et al. (2004). Occupational screening for obstructive sleep apnea in commercial drivers. Am J Respir Crit Care Med.
468 Gutierrez Iglesias B, Jacas Escarceller C, Bardes Robles I, et al. (2013). Effectiveness of 6-months continuous positive airway pressure treactment in OSAS-related cognitive deficit in older adults. Behav Neurol.
469 Gutierrez-Tobal GC, Alvarez D, Marcos JV, et al. (2013). Pattern recognition in airflow recordings to assist in the sleep apnoea-hypopnoea syndrome diagnosis. Med Biol Eng Comput.
470 Gutierrez-Tobal GC, Hornero R, Alvarez D, et al. (2012). Linear and nonlinear analysis of airflow recordings to help in sleep apnoea-hypopnoea syndrome diagnosis. Physiol Meas.
471 Gylling H. (2014). The impact of weight reduction in the prevention of the progression of obstructive sleep apnea: an explanatory analysis of a 5-year observational follow-up trial. Sleep Med.
472 Gyulay S, Gould D, Sawyer B, et al. (1987). Evaluation of a microprocessor-based portable home monitoring system to measure breathing during sleep. Sleep.
473 Gyulay S, Olson LG, Hensley MJ, et al. (1993). A comparison of clinical assessment and home oximetry in the diagnosis of obstructive sleep apnea. Am Rev Respir Dis.
474 Hack M, Choi R, Mullins R, et al. (1999). Performance of patients with obstructive sleep apnoea (OSA) on a steering simulation after six months treatment with nasal continuous positive airway pressure (NCPAP). Thorax.
475 Hack MA, Davies RJO, Stradling JR. (1998). Randomised, sham placebo, parallel study of the effect of nasal continuous positive airway pressure (NCPAP) on steering performance in patients with obstructive sleep apnoea (OSA) - interim analysis. Thorax.
476 Hader C, Hinz M, Welz-Barth A, et al. (2006). Sleep disordered breathing in the elderly: a three year longitudinal cohort study. J Physiol Pharmacol.
477 Hailey D, Jacobs P, Mayers I, et al. (2003). Auto-titrating nasal continuous positive airway pressure systems in the management of obstructive sleep apnea. Health Technology Assessment Database.
478 Hall AB, Ziadi MC, Leech J, et al. (2012). Does short term continuous positive airway pressure alter myocardial energetics and presynaptic sympathetic nerve function in patients with heart failure and obstructive sleep apnea? A randomized study. Canadian Journal of Cardiology.
479 Hall AB, Ziadi MC, Leech J, et al. (2011). Determination of the impact of short term continuous positive airway pressure on myocardial energetics in a randomized study of patients with chronic stable heart failure and obstructive sleep apnea. Circulation.
480 Hall AB, Ziadi MC, Leech JA, et al. (2014). Effects of short-term continuous positive airway pressure on myocardial sympathetic nerve function and energetics in patients with heart failure and obstructive sleep apnea: a randomized study. Circulation.
481 Hallikainen M, Tuomilehto H, Martikainen T, et al. (2013). Cholesterol metabolism and weight reduction in subjects with mild obstructive sleep apnoea: A randomised, controlled study. Cholesterol.
482 Hammerstingl C, Schueler R, Wiesen M, et al. (2012). Effects of untreated obstructive sleep apnea on left and right ventricular myocardial function. Int J Cardiol.
483 Hans MG, Nelson S, Luks VG, et al. (1997). Comparison of two dental devices for treatment of obstructive sleep apnea syndrome (OSAS). Am J Orthod Dentofacial Orthop.
484 Hans MG, Nelson S, Pracharktam N, et al. (2001). Subgrouping persons with snoring and/or apnea by using anthropometric and cephalometric measures. Sleep Breath.
485 Haponik EF, Bleecker ER, Allen RP, et al. (1981). Abnormal inspiratory flow-volume curves in patients with sleep-disordered breathing. Am Rev Respir Dis.
486 Haraldsson PO, Carenfelt C, Diderichsen F, et al. (1990). Clinical symptoms of sleep apnea syndrome and automobile accidents. ORL J Otorhinolaryngol Relat Spec.
487 Hashizume Y, Kuwahara H, Uchimura N, et al. (2001). Examination of accuracy of sleep stages by means of an automatic sleep analysis system ‘Sleep Ukiha’. Psychiatry Clin Neurosci.
488 Hayano J, Carney RM, Watanabe E, et al. (2012). Interactive associations of depression and sleep apnea with adverse clinical outcomes after acute myocardial infarction. Psychosom Med.
489 Hayano J, Tsukahara T, Watanabe E, et al. (2013). Accuracy of ECG-based screening for sleep-disordered breathing: a survey of all male workers in a transport company. Sleep Breath.
490 Hayano J, Watanabe E, Saito Y, et al. (2011). Diagnosis of sleep apnea by the analysis of heart rate variation: a mini review. Conf Proc IEEE Eng Med Biol Soc.
491 Hayashida K, Inoue Y, Chiba S, et al. (2007). Factors influencing subjective sleepiness in patients with obstructive sleep apnea syndrome. Psychiatry Clin Neurosci.
492 Hayes, Inc. (2007). Powered intracapsular tonsillectomy and adenoidectomy (PITA) for treatment of obstructive sleep apnea. Health Technology Assessment Database.
493 Hayes, Inc. (2010). Repose Tongue and Hyoid Suspension (THS) system (Medtronic Xomed Inc.) for obstructive sleep apnea. Health Technology Assessment Database.
494 Hayes, Inc. (2011). Provent sleep apnea therapy (Ventus Medical Inc.) for obstructive sleep apnea. Health Technology Assessment Database.
495 Hayes, Inc. (2012). Provent sleep apnea therapy (Ventus Medical Inc.). Health Technology Assessment Database.
496 Hayes, Inc. (2013). Bilevel positive airway pressure for the treatment of obstructive sleep apnea in adults. Health Technology Assessment Database.
497 Hayes, Inc. (2013). Provent sleep apnea therapy (Ventus Medical Inc.) for obstructive sleep apnea. Health Technology Assessment Database.
498 Hayes, Inc. (2014). Apnea Risk Evaluation System (ARES; Watermark Medical Inc.) for diagnosis of obstructive sleep apnea. Health Technology Assessment Database.
499 He J, Kryger MH, Zorick FJ, et al. (1988). Mortality and apnea index in obstructive sleep apnea. Experience in 385 male patients. Chest.
500 He QY, Feng J, Zhang XL, et al. (2010). Relationship of daytime blood pressure and severity of obstructive sleep apnea among Chinese: a multi-center investigation in China. Chin Med J (Engl).
501 Hecht L, Mohler R, Meyer G. (2011). Effects of CPAP-respiration on markers of glucose metabolism in patients with obstructive sleep apnoea syndrome: a systematic review and meta-analysis. Ger Med Sci.
502 Hedner J, White DP, Malhotra A, et al. (2011). Sleep staging based on autonomic signals: a multi-center validation study. J Clin Sleep Med.
503 Henderson MJ, Sadlier K, Currie BG. (2006). Obesity in older adults. A major contributor to chronicity. Adv Nurse Pract.
504 Heneghan C, de Chazal P, Ryan S, et al. (2008). Electrocardiogram recording as a screening tool for sleep disordered breathing. J Clin Sleep Med.
505 Henke KG, Grady JJ, Kuna ST. (2001). Effect of nasal continuous positive airway pressure on neuropsychological function in sleep apnea-hypopnea syndrome. A randomized, placebo-controlled trial. Am J Respir Crit Care Med.
506 Herer B, Roche N, Carton M, et al. (1999). Value of clinical, functional, and oximetric data for the prediction of obstructive sleep apnea in obese patients. Chest.
507 Hermans MP, Ahn SA, Mahadeb YP, et al. (2013). Sleep apnoea syndrome and 10-year cardiovascular risk in females with type 2 diabetes: relationship with insulin secretion and insulin resistance. Diabetes Metab Res Rev.
508 Hermida RC, Zamarrón C, Ayala DE, et al. (2004). Effect of continuous positive airway pressure on ambulatory blood pressure in patients with obstructive sleep apnoea. Blood Press Monit.
509 Hernandez L, Torrella M, Roger N, et al. (2007). Management of sleep apnea: concordance between nonreference and reference centers. Chest.
510 Hernández-Vásquez A, López A, Pichon-Riviere A, et al. (2015). Temperature-controlled radiofrequency tissue ablation in obstructive sleep apnea. Health Technology Assessment Database.
511 Herzog M, Metz T, Schmidt A, et al. (2006). The prognostic value of simulated snoring in awake patients with suspected sleep-disordered breathing: introduction of a new technique of examination. Sleep.
512 Hida W, Okabe S, Tatsumi K, et al. (2003). Nasal continuous positive airway pressure improves quality of life in obesity hypoventilation syndrome. Sleep Breath.
513 Hida W, Shindoh C, Miki H, et al. (1993). Prevalence of sleep apnea among Japanese industrial workers determined by a portable sleep monitoring system. Respiration.
514 Hillerdal G, Hetta J, Lindholm CE, et al. (1991). Symptoms in heavy snorers with and without obstructive sleep apnea. Acta Otolaryngol.
515 Hilton MF, Bates RA, Godfrey KR, et al. (1999). Evaluation of frequency and time-frequency spectral analysis of heart rate variability as a diagnostic marker of the sleep apnoea syndrome. Med Biol Eng Comput.
516 Hira HS. (1998). Obstructive sleep apnea syndrome: evaluation of subcritical continuous positive airway pressure. J Assoc Physicians India.
517 Hishikawa Y, Furuya E, Wakamatsu H, et al. (1972). A polygraphic study of hypersomnia with periodic breathing and primary alveolar hypoventilation. Bull Physiopathol Respir (Nancy).
518 Hla KM, Young T, Finn L, et al. (2008). Longitudinal association of sleep-disordered breathing and nondipping of nocturnal blood pressure in the Wisconsin Sleep Cohort Study. Sleep.
519 Hla KM, Young TB, Bidwell T, et al. (1994). Sleep apnea and hypertension. A population-based study. Ann Intern Med.
520 Hnin K, Antic NA, Anderson CS, et al. (2014). Predictors of obstructive sleep apnoea severity in patients enrolled in the sleep apnoea cardiovascular endpoint “save” trial. Sleep Biol Rhythms.
521 Hoekema A, Stegenga B, Bakker M, et al. (2007). Simulated driving in obstructive sleep apnoea-hypopnoea; effects of oral appliances and continuous positive airway pressure. Schlaf & Atmung.
522 Hoekema A, Stel AL, Stegenga B, et al. (2007). Sexual function and obstructive sleep apnea-hypopnea: a randomized clinical trial evaluating the effects of oral-appliance and continuous positive airway pressure therapy. J Sex Med.
523 Hoekema A, Voors AA, Wijkstra PJ, et al. (2008). Effects of oral appliances and CPAP on the left ventricle and natriuretic peptides. Int J Cardiol.
524 Hoffstein V, Mateika S. (1992). Differences in abdominal and neck circumferences in patients with and without obstructive sleep apnoea. Eur Respir J.
525 Holmdahl C, Schollin IL, Alton M, et al. (2010). Erratum to “CPAP treatment in obstructive sleep apnoea: A randomised, controlled trial of follow-up with a focus on patient satisfaction” [Sleep Medicine 10 (2009) 869-874] (DOI:10.1016/j.sleep.2008.08.008). Sleep Med.
526 Holmlund T, Levring-Jaghagen E, Franklin KA, et al. (2014). Effects of Radiofrequency versus sham surgery of the soft palate on daytime sleepiness. Laryngoscope.
527 Holmqvist F, Guan N, Zhu Z, et al. (2015). Impact of obstructive sleep apnea and continuous positive airway pressure therapy on outcomes in patients with atrial fibrillation-Results from the Outcomes Registry for Better Informed Treatment of Atrial Fibrillation (ORBIT-AF). Am Heart J.
528 Hood MM, Corsica J, Cvengros J, et al. (2013). Impact of a brief dietary self-monitoring intervention on weight change and CPAP adherence in patients with obstructive sleep apnea. J Psychosom Res.
529 Hossen A, Jaju D, Al-Ghunaimi B, et al. (2013). Classification of sleep apnea using wavelet-based spectral analysis of heart rate variability. Technol Health Care.
530 Hoth KF, Zimmerman ME, Meschede KA, et al. (2013). Obstructive sleep apnea: impact of hypoxemia on memory. Sleep Breath.
531 Hou HM, Hagg U, Sam K, et al. (2006). Dentofacial characteristics of Chinese obstructive sleep apnea patients in relation to obesity and severity. Angle Orthod.
532 Hoyos C, Killick R, Yee B, et al. (2011). Cardiometabolic and neurobehavioural changes after continuous positive airway pressure (CPAP) treatment for obstructive sleep apnea (OSA): A 12-week randomised sham-controlled study. Journal of Sleep Research.
533 Hoyos C, Sullivan D, Liu P. (2013). Effect of CPAP on the metabolic syndrome: a randomised sham-controlled study. Thorax.
534 Hoyos CM, Killick R, Keenan DM, et al. (2014). Continuous positive airway pressure increases pulsatile growth hormone secretion and circulating insulin-like growth factor-1 in a time-dependent manner in men with obstructive sleep apnea: A randomized sham-controlled study. Sleep.
535 Hrubos-Strom H, Einvik G, Nordhus IH, et al. (2012). Sleep apnoea, anxiety, depression and somatoform pain: a community-based high-risk sample. Eur Respir J.
536 Hsieh SW, Lai CL, Liu CK, et al. (2012). Obstructive sleep apnea linked to wake-up strokes. J Neurol.
537 Hsieh YJ, Liao YF. (2013). Effects of maxillomandibular advancement on the upper airway and surrounding structures in patients with obstructive sleep apnoea: a systematic review. Br J Oral Maxillofac Surg.
538 Hsu CY, Vennelle M, Li HY, et al. (2006). Sleep-disordered breathing after stroke: a randomised controlled trial of continuous positive airway pressure. J Neurol Neurosurg Psychiatry.
539 Hsu K, Tyler L, Lambert S, et al. (2010). CPAP therapy used to treat obstructive sleep apnoea (OSA) during the multiple sleep latency test (MSLT) does not consistently change the sleep latency. Sleep Biol Rhythms.
540 Huang Z, Liu Z, Luo Q, et al. (2015). Long-term effects of continuous positive airway pressure on blood pressure and prognosis in hypertensive patients with coronary heart disease and obstructive sleep apnea: A randomized controlled trial. Am J Hypertens.
541 Hudgel DW, Lamerato LE, Jacobsen GR, et al. (2012). Assessment of multiple health risks in a single obstructive sleep apnea population. J Clin Sleep Med.
542 Hui DS, Ko FW, Chan JK, et al. (2006). Sleep-disordered breathing and continuous positive airway pressure compliance in a group of commercial bus drivers in Hong Kong. Respirology.
543 Hui DS, Shang Q, Ko FW, et al. (2012). A prospective cohort study of the long-term effects of CPAP on carotid artery intima-media thickness in obstructive sleep apnea syndrome. Respir Res.
544 Hui DS, To KW, Ko FW, et al. (2006). A randomized subtherapeutic CPAP controlled study of the effects of nasal CPAP on 24-hour systemic blood pressure in obstructive sleep apnoea syndrome. Proc Am Thorac Soc.
545 Hussain SF, Fleetham JA. (2003). Overnight home oximetry: can it identify patients with obstructive sleep apnea-hypopnea who have minimal daytime sleepiness?. Respir Med.
546 Huupponen E, Himanen SL, Hasan J, et al. (2003). Automatic analysis of electro-encephalogram sleep spindle frequency throughout the night. Med Biol Eng Comput.
547 Huynh NT, Prilipko O, Kushida CA, et al. (2014). Volumetric brain morphometry changes in patients with obstructive sleep apnea syndrome: Effects of CPAP treatment and literature review. Front Neurol.
548 Hwang SH, Lee HJ, Yoon HN, et al. (2014). Unconstrained sleep apnea monitoring using polyvinylidene fluoride film-based sensor. IEEE Trans Biomed Eng.
549 Iber C, Redline S, Kaplan Gilpin AM, et al. (2004). Polysomnography performed in the unattended home versus the attended laboratory setting--Sleep Heart Health Study methodology. Sleep.
550 Ibrahim AS, Almohammed AA, Allangawi MH, et al. (2007). Predictors of obstructive sleep apnea in snorers. Ann Saudi Med.
551 Iftikhar IH, Blankfield RP. (2012). Effect of continuous positive airway pressure on hemoglobin A1c in patients with obstructive sleep apnea: a systematic review and meta-analysis. Lung.
552 Iftikhar IH, Kline CE, Youngstedt SD. (2013). Effects of exercise training on sleep apnea: a meta-analysis. Lung.
553 Igelstrom H, Emtner M, Lindberg E, et al. (2014). Tailored behavioral medicine intervention for enhanced physical activity and healthy eating in patients with obstructive sleep apnea syndrome and overweight. Sleep Breath.
554 Ikeda Y, Kasai T, Kawana F, et al. (2012). Comparison between the apnea-hypopnea indices determined by the REMstar Auto M series and those determined by standard in-laboratory polysomnography in patients with obstructive sleep apnea. Intern Med.
555 Imadojemu VA, Mawji Z, Kunselman A, et al. (2007). Sympathetic chemoreflex responses in obstructive sleep apnea and effects of continuous positive airway pressure therapy. Chest.
556 Issa FG, Morrison D, Hadjuk E, et al. (1993). Digital monitoring of sleep-disordered breathing using snoring sound and arterial oxygen saturation. Am Rev Respir Dis.
557 Izci B, Ardic S, Firat H, et al. (2008). Reliability and validity studies of the Turkish version of the Epworth Sleepiness Scale. Sleep Breath.
558 Izci B, Firat H, Ardic S, et al. (2004). Adaptation of functional outcomes of sleep questionnaire (FOSQ) to Turkish population. Tuberk Toraks.
559 Jager L, Gunther E, Gauger J, et al. (1998). Fluoroscopic MR of the pharynx in patients with obstructive sleep apnea. AJNR Am J Neuroradiol.
560 Jaspers GW, Booij A, de Graaf J, et al. (2013). Long-term results of maxillomandibular advancement surgery in patients with obstructive sleep apnoea syndrome. Br J Oral Maxillofac Surg.
561 Jauhar S, Orchardson R, Banham SW, et al. (2012). The Kushida Index as a screening tool for obstructive sleep apnoea-hypopnoea syndrome. Br Dent J.
562 Javadi HR, Jalilolghadr S, Yazdi Z, et al. (2014). Correlation between obstructive sleep apnea syndrome and cardiac disease severity. Cardiovasc Psychiatry Neurol.
563 Jenkinson C, Davies RJ, Mullins R, et al. (2001). Long-term benefits in self-reported health status of nasal continuous positive airway pressure therapy for obstructive sleep apnoea. QJM.
564 Jennum P, Sjol A. (1993). Snoring, sleep apnoea and cardiovascular risk factors: the MONICA II Study. Int J Epidemiol.
565 Jilek C, Krenn M, Sebah D, et al. (2011). Prognostic impact of sleep disordered breathing and its treatment in heart failure: an observational study. Eur J Heart Fail.
566 Jimenez Caballero PE, Coloma Navarro R, Ayo Martin O, et al. (2013). Cerebral hemodynamic changes in obstructive sleep apnea syndrome after continuous positive airway pressure treatment. Sleep Breath.
567 Jin J, Sanchez-Sinencio E. (2015). A home sleep apnea screening device with time-domain signal processing and autonomous scoring capability. IEEE Trans Biomed Circuits Syst.
568 Jniene A, el Ftouh M, Fihry MT. (2012). Sleep apnea syndrome: experience of the pulmonology department in Ibn Sina Hospital, Rabat, Morocco. Pan Afr Med J.
569 Johal A, Battagel J, Hector M. (2011). Controlled, prospective trial of psychosocial function before and after mandibular advancement splint therapy. Am J Orthod Dentofacial Orthop.
570 Johansson K, Neovius M, Lagerros YT, et al. (2010). Effect of a very low energy diet on moderate and severe obstructive sleep apnoea in obese men: A randomised controlled trial. Clin Otolaryngol.
571 Johansson P, Alehagen U, Svanborg E, et al. (2012). Clinical characteristics and mortality risk in relation to obstructive and central sleep apnoea in community-dwelling elderly individuals: a 7-year follow-up. Age Ageing.
572 Johns MW. (1991). A new method for measuring daytime sleepiness: the Epworth Sleepiness Scale. Sleep.
573 Johns MW. (1992). Reliability and factor analysis of the Epworth Sleepiness Scale. Sleep.
574 Johns MW. (1993). Daytime sleepiness, snoring, and obstructive sleep apnea. The Epworth Sleepiness Scale. Chest.
575 Joshi GP, Ankichetty SP, Gan TJ, et al. (2012). Society for Ambulatory Anesthesia consensus statement on preoperative selection of adult patients with obstructive sleep apnea scheduled for ambulatory surgery. Anesth Analg.
576 Julia-Serda G, Perez-Penate G, Saavedra-Santana P, et al. (2006). Usefulness of cephalometry in sparing polysomnography of patients with suspected obstructive sleep apnea. Sleep Breath.
577 Jung HH, Lee JH, Baek HJ, et al. (2010). Nocturnal hypoxemia and periodic limb movement predict mortality in patients on maintenance hemodialysis. Clin J Am Soc Nephrol.
578 Jung K, Ayalon L, Loredo JS, et al. (2006). Influence of treating alzheimer's patients sleep disordered breathing on the quality of caregivers sleep. Sleep.
579 Kajaste S, Brander PE, Telakivi T, et al. (2004). A cognitive-behavioral weight reduction program in the treatment of obstructive sleep apnea syndrome with or without initial nasal CPAP: a randomized study. Sleep Med.
580 Kallweit U, Hidalgo H, Uhl V, et al. (2011). Continuous positive airway pressure therapy is effective for migraines in sleep apnea syndrome. Neurology.
581 Känel R, Loredo JS, Ancoli-Israel S, et al. (2006). Association between sleep apnea severity and blood coagulability: Treatment effects of nasal continuous positive airway pressure. Schlaf & Atmung.
582 Kang JH, Lin HC. (2012). Obstructive sleep apnea and the risk of autoimmune diseases: a longitudinal population-based study. Sleep Med.
583 Kang K, Park KS, Kim JE, et al. (2013). Usefulness of the Berlin Questionnaire to identify patients at high risk for obstructive sleep apnea: a population-based door-to-door study. Sleep Breath.
584 Karaca S, Fidan F, Erkan F, et al. (2013). Might psoriasis be a risk factor for obstructive sleep apnea syndrome?. Sleep Breath.
585 Karakoc O, Akcam T, Genc H, et al. (2014). Use of the Berlin Questionnaire to screen at-risk patients for obstructive sleep apnea. B-ent.
586 Karakoc O, Akcam T, Gerek M, et al. (2012). The upper airway evaluation of habitual snorers and obstructive sleep apnea patients. ORL J Otorhinolaryngol Relat Spec.
587 Karatayli-Ozgursoy S, Demireller A. (2012). Hyoid suspension surgery with UPPP for the treatment of hypopharyngeal airway obstruction in obstructive sleep apnea. Ear Nose Throat J.
588 Karimi M, Hedner J, Habel H, et al. (2015). Sleep apnea-related risk of motor vehicle accidents is reduced by continuous positive airway pressure: Swedish Traffic Accident Registry data. Sleep.
589 Karimi M, Hedner J, Lombardi C, et al. (2014). Driving habits and risk factors for traffic accidents among sleep apnea patients--a European multi-centre cohort study. J Sleep Res.
590 Karunajeewa AS, Abeyratne UR, Hukins C. (2011). Multi-feature snore sound analysis in obstructive sleep apnea-hypopnea syndrome. Physiol Meas.
591 Kasiakogias A, Tsioufis C, Thomopoulos C, et al. (2013). Effects of continuous positive airway pressure on blood pressure in hypertensive patients with obstructive sleep apnea: a 3-year follow-up. J Hypertens.
592 Katz I, Stradling J, Slutsky AS, et al. (1990). Do patients with obstructive sleep apnea have thick necks?. Am Rev Respir Dis.
593 Kaw R, Chung F, Pasupuleti V, et al. (2012). Meta-analysis of the association between obstructive sleep apnoea and postoperative outcome. Br J Anaesth.
594 Kawaguchi Y, Fukumoto S, Inaba M, et al. (2011). Different impacts of neck circumference and visceral obesity on the severity of obstructive sleep apnea syndrome. Obesity (Silver Spring).
595 Keenan SP, Anderson B, Wiggs B, et al. (1993). The predictive accuracy of home oximetry in patients with suspected obstructive sleep apnea. Sleep.
596 Kemppainen T, Ruoppi P, Seppa J, et al. (2008). Effect of weight reduction on rhinometric measurements in overweight patients with obstructive sleep apnea. Am J Rhinol.
597 Kendzerska T, Gershon AS, Hawker G, et al. (2014). Obstructive sleep apnea and risk of cardiovascular events and all-cause mortality: a decade-long historical cohort study. PLoS Med.
598 Kendzerska T, Leung RS, Hawker G, et al. (2014). Obstructive sleep apnea and the prevalence and incidence of cancer. CMAJ.
599 Kendzerska T, Mollayeva T, Gershon AS, et al. (2014). Untreated obstructive sleep apnea and the risk for serious long-term adverse outcomes: a systematic review. Sleep Med Rev.
600 Kesper K, Canisius S, Penzel T, et al. (2012). ECG signal analysis for the assessment of sleep-disordered breathing and sleep pattern. Med Biol Eng Comput.
601 Kezirian EJ, Harrison SL, Ancoli-Israel S, et al. (2007). Behavioral correlates of sleep-disordered breathing in older women. Sleep.
602 Khan A, King WC, Patterson EJ, et al. (2013). Assessment of obstructive sleep apnea in adults undergoing bariatric surgery in the longitudinal assessment of bariatric surgery-2 (LABS-2) study. J Clin Sleep Med.
603 Khan A, King WC, Patterson EJ, et al. (2011). Obstructive sleep apnea prior to bariatric surgery: Diagnostic testing, prevalence and predictive value of the berlin sleep questionnaire in the longitudinal assessment of bariatric surgery-2 (LABS-2) cohort. Am J Respir Crit Care Med.
604 Khandoker AH, Palaniswami M, Karmakar CK. (2009). Support vector machines for automated recognition of obstructive sleep apnea syndrome from ECG recordings. IEEE Trans Inf Technol Biomed.
605 Khoo SM, Poh HK, Chan YH, et al. (2011). Diagnostic characteristics of clinical prediction models for obstructive sleep apnea in different clinic populations. Sleep Breath.
606 Kiely JL, Delahunty C, Matthews S, et al. (1996). Comparison of a limited computerized diagnostic system (ResCare Autoset) with polysomnography in the diagnosis of obstructive sleep apnoea syndrome. Eur Respir J.
607 Kim H, Kim MS, Lee JE, et al. (2013). Treatment outcomes and compliance according to obesity in patients with obstructive sleep apnea. Eur Arch Otorhinolaryngol.
608 Kim MJ, Kim BY, Lee DC, et al. (2013). A modified uvulopalatal flap with lateral pharyngoplasty for treatment in 92 adults with obstructive sleep apnoea syndrome. Clin Otolaryngol.
609 Kimoff RJ, Sforza E, Champagne V, et al. (2001). Upper airway sensation in snoring and obstructive sleep apnea. Am J Respir Crit Care Med.
610 Kingshott RN, Douglas NJ. (2000). The effect of in-laboratory polysomnography on sleep and objective daytime sleepiness. Sleep.
611 Kingshott RN, Sime PJ, Engleman HM, et al. (1995). Self assessment of daytime sleepiness: patient versus partner. Thorax.
612 Kinoshita LM, Yesavage JA, Noda A, et al. (2012). Modeling the effects of obstructive sleep apnea and hypertension in Vietnam veterans with PTSD. Sleep Breath.
613 Kirsch DB. (2013). PRO: sliding into home: portable sleep testing is effective for diagnosis of obstructive sleep apnea. J Clin Sleep Med.
614 Kline CE, Crowley EP, Ewing GB, et al. (2011). The effect of exercise training on obstructive sleep apnea and sleep quality: a randomized controlled trial. Sleep.
615 Kline CE, Milton DN, Kane CJ, et al. (2011). Exercise training significantly reduces obstructive sleep apnea severity and improves sleep quality in untreated adults: A randomized controlled trial. Sleep.
616 Ko MT, Su CY. (2008). Computer-assisted quantitative evaluation of obstructive sleep apnea using digitalized endoscopic imaging with Muller maneuver. Laryngoscope.
617 Kobayashi M, Namba K, Tsuiki S, et al. (2013). Validity of sheet-type portable monitoring device for screening obstructive sleep apnea syndrome. Sleep Breath.
618 Kobukai Y, Koyama T, Watanabe H, et al. (2014). Morning pentraxin3 levels reflect obstructive sleep apnea-related acute inflammation. J Appl Physiol (1985).
619 Kohler M, Ayers L, Pepperell JC, et al. (2009). Effects of continuous positive airway pressure on systemic inflammation in patients with moderate to severe obstructive sleep apnoea: a randomised controlled trial. Thorax.
620 Kohler M, Craig S, Pepperell JC, et al. (2013). CPAP improves endothelial function in patients with minimally symptomatic OSA: results from a subset study of the MOSAIC trial. Chest.
621 Kohler M, Pepperell JC, Davies RJ, et al. (2009). Continuous positive airway pressure and liver enzymes in obstructive sleep apnoea: data from a randomized controlled trial. Respiration; international review of thoracic diseases.
622 Kohler M, Stoewhas AC, Ayers L, et al. (2011). Effects of continuous positive airway pressure therapy withdrawal in patients with obstructive sleep apnea: a randomized controlled trial. Am J Respir Crit Care Med.
623 Koley BL, Dey D. (2014). On-line detection of apnea/hypopnea events using SpO2 signal: a rule-based approach employing binary classifier models. IEEE J Biomed Health Inform.
624 Kolotkin RL, LaMonte MJ, Walker JM, et al. (2011). Predicting sleep apnea in bariatric surgery patients. Surg Obes Relat Dis.
625 Kooblall M, Lane SJ, Moloney E. (2015). The role of oximetry in patients with obstructive sleep apnea. Ir Med J.
626 Korczynski P, Gorska K, Przybylowski T, et al. (2009). Continuous positive airway pressure treatment increases bronchial reactivity in obstructive sleep apnea patients. Respiration; international review of thoracic diseases.
627 Korkuyu E, Duzlu M, Karamert R, et al. (2015). The efficacy of Watch PAT in obstructive sleep apnea syndrome diagnosis. Eur Arch Otorhinolaryngol.
628 Korostovtseva LS, Sviryaev YV, Zvartau NE, et al. (2011). Prognosis and cardiovascular morbidity and mortality in prospective study of hypertensive patients with obstructive sleep apnea syndrome in St Petersburg, Russia. Med Sci Monit.
629 Kotzian ST, Stanek JK, Pinter MM, et al. (2012). Subjective evaluation of sleep apnea is not sufficient in stroke rehabilitation. Top Stroke Rehabil.
630 Koutsourelakis I, Minaritzoglou A, Zakynthinos G, et al. (2013). The effect of nasal tramazoline with dexamethasone in obstructive sleep apnoea patients. Eur Respir J.
631 Koutsourelakis I, Perraki E, Bonakis A, et al. (2008). Determinants of subjective sleepiness in suspected obstructive sleep apnoea. J Sleep Res.
632 Koyama RG, Esteves AM, Oliveira e Silva L, et al. (2012). Prevalence of and risk factors for obstructive sleep apnea syndrome in Brazilian railroad workers. Sleep Med.
633 Koziej M, Cieslicki JK, Gorzelak K, et al. (1994). Hand-scoring of MESAM 4 recordings is more accurate than automatic analysis in screening for obstructive sleep apnoea. Eur Respir J.
634 Krekmanov L, Andersson L, Ringqvist M, et al. (1998). Anterior-inferior mandibular osteotomy in treatment of obstructive sleep apnea syndrome. Int J Adult Orthodon Orthognath Surg.
635 Kreutzer ML, Guilleminault C. (2003). Adherence to nasal continuous positive airway pressure (CPAP) in patients with congestive heat failure. Sleep.
636 Kreuz J, Skowasch D, Horlbeck F, et al. (2013). Usefulness of sleep-disordered breathing to predict occurrence of appropriate and inappropriate implantable-cardioverter defibrillator therapy in patients with implantable cardioverter-defibrillator for primary prevention of sudden cardiac death. Am J Cardiol.
637 Krieger J, Meslier N, Lebrun T, et al. (1997). Accidents in obstructive sleep apnea patients treated with nasal continuous positive airway pressure: a prospective study. The Working Group ANTADIR, Paris and CRESGE, Lille, France. Association Nationale de Traitement a Domicile des Insuffisants Respiratoires. Chest.
638 Kristiansen HA, Kvaerner KJ, Akre H, et al. (2012). Sleep apnoea headache in the general population. Cephalalgia.
639 Kritikou I, Basta M, Tappouni R, et al. (2013). Sleep apnoea and visceral adiposity in middle-aged male and female subjects. Eur Respir J.
640 Kulkarni GV, Horst A, Eberhardt JM, et al. (2014). Obstructive sleep apnea in general surgery patients: is it more common than we think?. Am J Surg.
641 Kulkas A, Leppanen T, Sahlman J, et al. (2013). Novel parameters reflect changes in morphology of respiratory events during weight loss. Physiol Meas.
642 Kulkas A, Tiihonen P, Julkunen P, et al. (2013). Novel parameters indicate significant differences in severity of obstructive sleep apnea with patients having similar apnea-hypopnea index. Med Biol Eng Comput.
643 Kumar R, Nagar D, Mallick A, et al. (2013). Obstructive sleep apnoea and atopy among middle aged chronic obstructive pulmonary disease and bronchial asthma patients. J Assoc Physicians India.
644 Kump K, Whalen C, Tishler PV, et al. (1994). Assessment of the validity and utility of a sleep-symptom questionnaire. Am J Respir Crit Care Med.
645 Kuna ST, Benca R, Kushida CA, et al. (2013). Agreement in computer-assisted manual scoring of polysomnograms across sleep centers. Sleep.
646 Kuna ST, Gurubhagavatula I, Maislin G, et al. (2011). Noninferiority of functional outcome in ambulatory management of obstructive sleep apnea. Am J Respir Crit Care Med.
647 Kuna ST, Shuttleworth D, Chi L, et al. (2015). Web-based access to positive airway pressure usage with or without an initial financial incentive improves treatment use in patients with obstructive sleep apnea. Sleep.
648 Kushida CA, Efron B, Guilleminault C. (1997). A predictive morphometric model for the obstructive sleep apnea syndrome. Ann Intern Med.
649 Kushida CA, Nichols DA, Quan SF, et al. (2006). The Apnea Positive Pressure Long-term Efficacy Study (APPLES): rationale, design, methods, and procedures. Journal of clinical sleep medicine : JCSM : official publication of the American Academy of Sleep Medicine.
650 Kylstra WA, Aaronson JA, Hofman WF, et al. (2013). Neuropsychological functioning after CPAP treatment in obstructive sleep apnea: a meta-analysis. Sleep Med Rev.
651 Lahav Y, Rosenzweig E, Heyman Z, et al. (2009). Tongue base ultrasound: a diagnostic tool for predicting obstructive sleep apnea. Ann Otol Rhinol Laryngol.
652 Lamberts M, Nielsen OW, Lip GY, et al. (2014). Cardiovascular risk in patients with sleep apnoea with or without continuous positive airway pressure therapy: follow-up of 4.5 million Danish adults. J Intern Med.
653 Laporta R, Anandam A, El-Solh AA. (2012). Screening for obstructive sleep apnea in veterans with ischemic heart disease using a computer-based clinical decision-support system. Clin Res Cardiol.
654 Larrosa F, Hernandez L, Morello A, et al. (2004). Laser-assisted uvulopalatoplasty for snoring: does it meet the expectations?. Eur Respir J.
655 Lavie L, Lotan R, Hochberg I, et al. (2003). Haptoglobin polymorphism is a risk factor for cardiovascular disease in patients with obstructive sleep apnea syndrome. Sleep.
656 Lavie P. (1983). Incidence of sleep apnea in a presumably healthy working population: a significant relationship with excessive daytime sleepiness. Sleep.
657 Lavie P, Ben-Yosef R, Rubin AE. (1984). Prevalence of sleep apnea syndrome among patients with essential hypertension. Am Heart J.
658 Lavie P, Herer P, Peled R, et al. (1995). Mortality in sleep apnea patients: a multivariate analysis of risk factors. Sleep.
659 Lavie P, Lavie L. (2009). Unexpected survival advantage in elderly people with moderate sleep apnoea. J Sleep Res.
660 Lavie P, Lavie L, Herer P. (2005). All-cause mortality in males with sleep apnoea syndrome: declining mortality rates with age. Eur Respir J.
661 Le Bon O, Hoffmann G, Tecco J, et al. (2000). Mild to moderate sleep respiratory events: one negative night may not be enough. Chest.
662 Ledereich P, Thorpy M, Lovinsky P. (1988). Five-year follow-up of daytime sleepinessand snoring after tracheotomy in patients with obstructive sleep apnea. Chronic Rhoncopathy.
663 Lee CH, Khoo SM, Chan MY, et al. (2011). Severe obstructive sleep apnea and outcomes following myocardial infarction. J Clin Sleep Med.
664 Lee IS, Bardwell W, Ancoli-Israel S, et al. (2012). Effect of three weeks of continuous positive airway pressure treatment on mood in patients with obstructive sleep apnoea: a randomized placebo-controlled study. Sleep Med.
665 Lee IS, Bardwell W, Ancoli-Israel S, et al. (2011). The relationship between psychomotor vigilance performance and quality of life in obstructive sleep apnea. J Clin Sleep Med.
666 Lee JE, Lee CH, Lee SJ, et al. (2013). Mortality of patients with obstructive sleep apnea in Korea. J Clin Sleep Med.
667 Lee YC, Eun YG, Shin SY, et al. (2013). Prevalence of snoring and high risk of obstructive sleep apnea syndrome in young male soldiers in Korea. J Korean Med Sci.
668 Lee YH, Johan A, Wong KK, et al. (2009). Prevalence and risk factors for obstructive sleep apnea in a multiethnic population of patients presenting for bariatric surgery in Singapore. Sleep Med.
669 Leitzen KP, Brietzke SE, Lindsay RW. (2014). Correlation between nasal anatomy and objective obstructive sleep apnea severity. Otolaryngol Head Neck Surg.
670 Leng PH, Low SY, Hsu A, et al. (2003). The clinical predictors of sleepiness correlated with the multiple sleep latency test in an Asian Singapore population. Sleep.
671 Leonetti F, Capoccia D, Coccia F, et al. (2012). Obesity, type 2 diabetes mellitus, and other comorbidities: a prospective cohort study of laparoscopic sleeve gastrectomy vs medical treatment. Arch Surg.
672 Lettieri CJ, Eliasson AH, Greenburg DL. (2008). Persistence of obstructive sleep apnea after surgical weight loss. J Clin Sleep Med.
673 Levy P, Pepin JL, Deschaux-Blanc C, et al. (1996). Accuracy of oximetry for detection of respiratory disturbances in sleep apnea syndrome. Chest.
674 Lewis EF, Wang R, Quan S, et al. (2014). Impact of treatment modalities on health status in patients with obstructive sleep apnea. J Am Coll Cardiol.
675 Li HY, Huang YS, Chen NH, et al. (2004). Mood improvement after surgery for obstructive sleep apnea. Laryngoscope.
676 Li HY, Lee LA, Wang PC, et al. (2009). Can nasal surgery improve obstructive sleep apnea: subjective or objective?. Am J Rhinol Allergy.
677 Li HY, Lin Y, Chen NH, et al. (2008). Improvement in quality of life after nasal surgery alone for patients with obstructive sleep apnea and nasal obstruction. Arch Otolaryngol Head Neck Surg.
678 Li HY, Wang PC, Chen YP, et al. (2011). Critical appraisal and meta-analysis of nasal surgery for obstructive sleep apnea. Am J Rhinol Allergy.
679 Li KK, Powell NB, Riley RW, et al. (2002). Temperature-controlled radiofrequency tongue base reduction for sleep-disordered breathing: Long-term outcomes. Otolaryngol Head Neck Surg.
680 Li KK, Riley R, Powell N. (2003). Complications of obstructive sleep apnea surgery. Oral Maxillofac Surg Clin North Am.
681 Li QY, Berry RB, Goetting MG, et al. (2015). Detection of upper airway status and respiratory events by a current generation positive airway pressure device. Sleep.
682 Li Y, Chongsuvivatwong V, Geater A, et al. (2009). Exhaled breath condensate cytokine level as a diagnostic tool for obstructive sleep apnea syndrome. Sleep Med.
683 Liao P, Luo Q, Elsaid H, et al. (2013). Perioperative auto-titrated continuous positive airway pressure treatment in surgical patients with obstructive sleep apnea: a randomized controlled trial. Anesthesiology.
684 Liesching TN, Carlisle C, Marte A, et al. (2004). Evaluation of the accuracy of SNAP technology sleep sonography in detecting obstructive sleep apnea in adults compared to standard polysomnography. Chest.
685 Lim J, Lasserson Toby J, Fleetham J, et al. (2006). Oral appliances for obstructive sleep apnoea. Cochrane Database of Systematic Reviews.
686 Lim PV, Curry AR. (2000). The role of history, Epworth Sleepiness Scale Score and body mass index in identifying non-apnoeic snorers. Clin Otolaryngol Allied Sci.
687 Lin GM, Colangelo LA, Lloyd-Jones DM, et al. (2015). Association of Sleep Apnea and Snoring With Incident Atrial Fibrillation in the Multi-Ethnic Study of Atherosclerosis. Am J Epidemiol.
688 Lin SW, Chen NH, Li HY, et al. (2006). A comparison of the long-term outcome and effects of surgery or continuous positive airway pressure on patients with obstructive sleep apnea syndrome. Laryngoscope.
689 Lindberg E, Berne C, Elmasry A, et al. (2006). CPAP treatment of a population-based sample--what are the benefits and the treatment compliance?. Sleep Med.
690 Lindberg E, Carter N, Gislason T, et al. (2001). Role of snoring and daytime sleepiness in occupational accidents. Am J Respir Crit Care Med.
691 Lindberg E, Theorell-Haglow J, Svensson M, et al. (2012). Sleep apnea and glucose metabolism: a long-term follow-up in a community-based sample. Chest.
692 Lindman R, Bondemark L. (2001). A review of oral devices in the treatment of habitual snoring and obstructive sleep apnoea. Swed Dent J.
693 Litvin AY, Sukmarova ZN, Elfimova EM, et al. (2013). Effects of CPAP on “vascular” risk factors in patients with obstructive sleep apnea and arterial hypertension. Vasc Health Risk Manag.
694 Liu D, Yang X, Wang G, et al. (2012). HHT based cardiopulmonary coupling analysis for sleep apnea detection. Sleep Med.
695 Liu SR, Yi HL, Yin SK, et al. (2012). Primary maxillomandibular advancement with concomitant revised uvulopalatopharyngoplasty with uvula preservation for severe obstructive sleep apnea-hypopnea syndrome. J Craniofac Surg.
696 Liu X, Feng L, Cao G, et al. (2014). Cardiac structure and function improvements in coronary artery disease combined with severe obstructive sleep apnea/hypopnea syndrome patients via noninvasive positive pressure ventilation therapy. Coron Artery Dis.
697 Lloberes P, Montserrat JM, Ascaso A, et al. (1996). Comparison of partially attended night time respiratory recordings and full polysomnography in patients with suspected sleep apnoea/hypopnoea syndrome. Thorax.
698 Lloberes P, Sampol G, Espinel E, et al. (2014). A randomized controlled study of CPAP effect on plasma aldosterone concentration in patients with resistant hypertension and obstructive sleep apnea. J Hypertens.
699 Lockhart EM, Willingham MD, Abdallah AB, et al. (2013). Obstructive sleep apnea screening and postoperative mortality in a large surgical cohort. Sleep Med.
700 Lojander J, Kajaste S, Maasilta P, et al. (1999). Cognitive function and treatment of obstructive sleep apnea syndrome. J Sleep Res.
701 Lojander J, Maasilta P, Partinen M, et al. (1996). Nasal-CPAP, surgery, and conservative management for treatment of obstructive sleep apnea syndrome. A randomized study. Chest.
702 Lojander J, Mustajoki P, Ronka S, et al. (1998). A nurse-managed weight reduction programme for obstructive sleep apnoea syndrome. J Intern Med.
703 Loke YK, Brown JW, Kwok CS, et al. (2012). Association of obstructive sleep apnea with risk of serious cardiovascular events: a systematic review and meta-analysis. Circ Cardiovasc Qual Outcomes.
704 Lombardi C, Parati G, Cortelli P, et al. (2008). Daytime sleepiness and neural cardiac modulation in sleep-related breathing disorders. J Sleep Res.
705 Lopes C, Esteves AM, Bittencourt LR, et al. (2008). Relationship between the quality of life and the severity of obstructive sleep apnea syndrome. Braz J Med Biol Res.
706 Lopez-Padilla D, Alonso-Moralejo R, De La Torre Carazo S, et al. (2013). Survival and adherence to CPAP in the elderly. Sleep Med.
707 Lord S, Sawyer B, O'Connell D, et al. (1991). Night-to-night variability of disturbed breathing during sleep in an elderly community sample. Sleep.
708 Lord S, Sawyer B, Pond D, et al. (1989). Interrater reliability of computer-assisted scoring of breathing during sleep. Sleep.
709 Lozano L, Tovar JL, Sampol G, et al. (2010). Continuous positive airway pressure treatment in sleep apnea patients with resistant hypertension: a randomized, controlled trial. J Hypertens.
710 Lugaresi E, Coccagna G, Mantovani M, et al. (1972). Hypersomnia with periodic breathing: periodic apneas and alveolar hypoventilation during sleep. Bull Physiopathol Respir (Nancy).
711 Lugaresi E, Coccagna G, Mantovani M, et al. (1972). Some periodic phenomena arising during drowsiness and sleep in man. Electroencephalogr Clin Neurophysiol.
712 Luo JM, Huang R, Zhong X, et al. (2014). STOP-bang questionnaire is superior to epworth sleepiness scales, Berlin questionnaire, And STOP questionnaire in screening obstructive sleep apnea hypopnea syndrome patients. Chin Med J.
713 Luo JM, Huang R, Zhong X, et al. (2014). Value of STOP-Bang questionnaire in screening patients with obstructive sleep apnea hypopnea syndrome in sleep disordered breathing clinic. Chin Med J.
714 Lweesy K, Fraiwan L, Khasawneh N, et al. (2011). New automated detection method of OSA based on artificial neural networks using P-wave shape and time changes. J Med Syst.
715 Macavei VM, Spurling KJ, Loft J, et al. (2013). Diagnostic predictors of obesity-hypoventilation syndrome in patients suspected of having sleep disordered breathing. J Clin Sleep Med.
716 Machado MC, Vollmer WM, Togeiro SM, et al. (2010). CPAP and survival in moderate-to-severe obstructive sleep apnoea syndrome and hypoxaemic COPD. Eur Respir J.
717 Mahakit P. (2012). A comparative study of two-hour daytime and overnight polysomnography in high risk snorers. J Med Assoc Thai.
718 Maier C, Dickhaus H. (2014). Extraction of respiratory myogram interference from the ECG and its application to characterize sleep-related breathing disorders in atrial fibrillation. J Electrocardiol.
719 Maier C, Wenz H, Dickhaus H. (2011). Steps toward subject-specific classification in ECG-based detection of sleep apnea. Physiol Meas.
720 Mair EA, Day RH. (2000). Cautery-assisted palatal stiffening operation. Otolaryngol Head Neck Surg.
721 Maislin G, Pack AI, Kribbs NB, et al. (1995). A survey screen for prediction of apnea. Sleep.
722 Maki-Nunes C, Toschi-Dias E, Cepeda FX, et al. (2015). Diet and exercise improve chemoreflex sensitivity in patients with metabolic syndrome and obstructive sleep apnea. Obesity.
723 Malbois M, Giusti V, Suter M, et al. (2010). Oximetry alone versus portable polygraphy for sleep apnea screening before bariatric surgery. Obes Surg.
724 Malhotra A, Younes M, Kuna ST, et al. (2013). Performance of an automated polysomnography scoring system versus computer-assisted manual scoring. Sleep.
725 Man GC, Kang BV. (1995). Validation of a portable sleep apnea monitoring device. Chest.
726 Mansfield DR, Gollogly NC, Kaye DM, et al. (2004). Controlled trial of continuous positive airway pressure in obstructive sleep apnea and heart failure. Am J Respir Crit Care Med.
727 Maranate T, Pongpullponsak A, Ruttanaumpawan P. (2015). The Prioritization of Clinical Risk Factors of Obstructive Sleep Apnea Severity Using Fuzzy Analytic Hierarchy Process. Comput Math Methods Med.
728 Marcos JV, Hornero R, Alvarez D, et al. (2012). Automated prediction of the apnea-hypopnea index from nocturnal oximetry recordings. IEEE Trans Biomed Eng.
729 Marcos JV, Hornero R, Alvarez D, et al. (2010). Automated detection of obstructive sleep apnoea syndrome from oxygen saturation recordings using linear discriminant analysis. Med Biol Eng Comput.
730 Marcos JV, Hornero R, Alvarez D, et al. (2010). The classification of oximetry signals using Bayesian neural networks to assist in the detection of obstructive sleep apnoea syndrome. Physiol Meas.
731 Marcos JV, Hornero R, Nabney IT, et al. (2011). Analysis of nocturnal oxygen saturation recordings using kernel entropy to assist in sleep apnea-hypopnea diagnosis. Conf Proc IEEE Eng Med Biol Soc.
732 Margallo VS, Muxfeldt ES, Guimarães GM, et al. (2014). Diagnostic accuracy of the Berlin questionnaire in detecting obstructive sleep apnea in patients with resistant hypertension. J Hypertens.
733 Margarit L, Drouot X, Bokar-Thire A, et al. (2012). Validation of polygraphy versus polysomnography in the diagnosis of sleep disordered breathing, with special emphasis on heart failure patients. Journal of Sleep Research.
734 Marin JM, Agusti A, Villar I, et al. (2012). Association between treated and untreated obstructive sleep apnea and risk of hypertension. JAMA.
735 Marrone O, Lo Bue A, Salvaggio A, et al. (2013). Comorbidities and survival in obstructive sleep apnoea beyond the age of 50. Eur J Clin Invest.
736 Marrone O, Salvaggio A, Insalaco G, et al. (2001). Evaluation of the POLYMESAM system in the diagnosis of obstructive sleep apnea syndrome. Monaldi Arch Chest Dis.
737 Marshall N, Sheppard D, Campbell A, et al. (2004). Randomised controlled crossover trial of continuous positive airway pressure in the treatment of mild-moderate obstructive sleep apnoea using a mechanical placebo. Internal medicine journal.
738 Marshall NS, Barnes M, Travier N, et al. (2006). Continuous positive airway pressure reduces daytime sleepiness in mild to moderateobstructive sleep apnoea: a meta-analysis. Thorax.
739 Marshall NS, Delling L, Grunstein RR, et al. (2011). Self-reported sleep apnoea and mortality in patients from the Swedish Obese Subjects study. Eur Respir J.
740 Marshall NS, Grunstein RR. (2009). Losing weight in moderate to severe obstructive sleep apnoea. BMJ (Online).
741 Marshall NS, Wong KK, Cullen SR, et al. (2012). Snoring is not associated with all-cause mortality, incident cardiovascular disease, or stroke in the Busselton Health Study. Sleep.
742 Martinez D, Breitenbach TC, Lumertz MS, et al. (2011). Repeating administration of Epworth Sleepiness Scale is clinically useful. Sleep Breath.
743 Martinez D, da Silva RP, Klein C, et al. (2012). High risk for sleep apnea in the Berlin questionnaire and coronary artery disease. Sleep Breath.
744 Martinez-Garcia MA, Campos-Rodriguez F, Catalan-Serra P, et al. (2011). All-cause and cardiovascular mortality in elderly patients with sleep apnea. Role of CPAP treatment. A 6-year follow-up study. Am J Respir Crit Care Med.
745 Martinez-Garcia MA, Campos-Rodriguez F, Catalan-Serra P, et al. (2012). Cardiovascular mortality in obstructive sleep apnea in the elderly: Role of long-term continuous positive airway pressure treatment: A prospective observational study. Am J Respir Crit Care Med.
746 Martinez-Garcia MA, Campos-Rodriguez F, Duran-Cantolla J, et al. (2014). Obstructive sleep apnea is associated with cancer mortality in younger patients. Sleep Med.
747 Martínez-García MA, Chiner E, Hernández L, et al. (2015). Obstructive sleep apnoea in the elderly: Role of continuous positive airway pressure treatment. Eur Respir J.
748 Martínez-García MA, Galiano-Blancart R, Román-Sánchez P, et al. (2005). Continuous positive airway pressure treatment in sleep apnea prevents new vascular events after ischemic stroke. Chest.
749 Martinez-Garcia MA, Martorell-Calatayud A, Nagore E, et al. (2014). Association between sleep disordered breathing and aggressiveness markers of malignant cutaneous melanoma. Eur Respir J.
750 Martinez-Rivera C, Abad J, Fiz JA, et al. (2008). Usefulness of truncal obesity indices as predictive factors for obstructive sleep apnea syndrome. Obesity (Silver Spring).
751 Martinho FL, Tangerina RP, Moura SM, et al. (2008). Systematic head and neck physical examination as a predictor of obstructive sleep apnea in class III obese patients. Braz J Med Biol Res.
752 Masa JF, Corral J, Gomez de Terreros J, et al. (2013). Significance of including a surrogate arousal for sleep apnea-hypopnea syndrome diagnosis by respiratory polygraphy. Sleep.
753 Masa JF, Corral J, Pereira R, et al. (2011). Therapeutic Decision For Sleep Apnea And Hypopnea Syndrome By Home Respiratory Polygraphy. Am J Respir Crit Care Med.
754 Masa JF, Corral J, Pereira R, et al. (2012). Significance Of Including A Subrogated Arousal For Sleep Apnea-Hypopnea Syndrome Diagnosis By Respiratory Polygrafy. Am J Respir Crit Care Med.
755 Masa JF, Corral J, Pereira R, et al. (2011). Therapeutic decision-making for sleep apnea and hypopnea syndrome using home respiratory polygraphy: a large multicentric study. Am J Respir Crit Care Med.
756 Masa JF, Corral J, Pereira R, et al. (2012). Cost-Effectiveness of the teletransmission of home respiratory polygraphy for the diagnosis of sleep apnoea and hypopnoea syndrome. Journal of Sleep Research.
757 Masa JF, Corral J, Pereira R, et al. (2011). Therapeutic decision-making for sleep apnea and hypopnea syndrome using home respiratory polygraphy. Sleep and Biological Rhythms.
758 Masa JF, Corral J, Sanchez de Cos J, et al. (2013). Effectiveness of three sleep apnea management alternatives. Sleep.
759 Masa JF, Duran-Cantolla J, Capote F, et al. (2015). Efficacy of home single-channel nasal pressure for recommending continuous positive airway pressure treatment in sleep apnea. Sleep.
760 Masa JF, Duran-Cantolla J, Capote F, et al. (2014). Effectiveness of home single-channel nasal pressure for sleep apnea diagnosis. Sleep.
761 Masa JF, Rubio M, Findley LJ. (2000). Habitually sleepy drivers have a high frequency of automobile crashes associated with respiratory disorders during sleep. Am J Respir Crit Care Med.
762 Mason WJ, Ancoli-Israel S, Kripke DF. (1989). Apnea revisited: a longitudinal follow-up. Sleep.
763 Massie CA, Hart RW, Peralez K, et al. (1999). Effects of humidification on nasal symptoms and compliance in sleep apnea patients using continuous positive airway pressure. Chest.
764 Matiello M, Nadal M, Tamborero D, et al. (2010). Low efficacy of atrial fibrillation ablation in severe obstructive sleep apnoea patients. Europace.
765 Maurer JT, Sommer JU, Hein G, et al. (2012). Palatal implants in the treatment of obstructive sleep apnea: a randomised, placebo-controlled single-centre trial. Eur Arch Otorhinolaryngol.
766 Maury G, Cambron L, Jamart J, et al. (2013). Added value of a mandible movement automated analysis in the screening of obstructive sleep apnea. J Sleep Res.
767 Maury G, Senny F, Cambron L, et al. (2014). Mandible behaviour interpretation during wakefulness, sleep and sleep-disordered breathing. J Sleep Res.
768 Mayer P, Meurice JC, Philip-Joet F, et al. (1998). Simultaneous laboratory-based comparison of ResMed Autoset with polysomnography in the diagnosis of sleep apnoea/hypopnoea syndrome. Eur Respir J.
769 Mayer P, Pepin JL, Bettega G, et al. (1996). Relationship between body mass index, age and upper airway measurements in snorers and sleep apnoea patients. Eur Respir J.
770 Maziere S, Pepin JL, Siyanko N, et al. (2014). Usefulness of oximetry for sleep apnea screening in frail hospitalized elderly. J Am Med Dir Assoc.
771 Mazzuca E, Battaglia S, Marrone O, et al. (2014). Gender-specific anthropometric markers of adiposity, metabolic syndrome and visceral adiposity index (VAI) in patients with obstructive sleep apnea. J Sleep Res.
772 McDaid C, Griffin S, Weatherly H, et al. (2009). Continuous positive airway pressure devices for the treatment of obstructive sleep apnoea-hypopnoea syndrome: a systematic review and economic analysis. Health Technol Assess.
773 McEwen B, Phillips C, Morel-Kopp MC, et al. (2011). Effects of continuous positive airway pressure on coagulation parameters in obstructive sleep apnoea: A randomised, placebo-controlled crossover study. Journal of Sleep Research.
774 McEwen BJ, Phillips CL, Morel-Kopp MC, et al. (2012). Diurnal changes and levels of fibrin generation are not altered by continuous positive airway pressure (CPAP) in obstructive sleep apnoea (OSA). A randomised, placebo-controlled crossover study. Thromb Haemost.
775 McFadyen TA, Espie CA, McArdle N, et al. (2001). Controlled, prospective trial of psychosocial function before and after continuous positive airway pressure therapy. The European respiratory journal.
776 McIsaac DI, Gershon A, Wijeysundera D, et al. (2015). Identifying Obstructive Sleep Apnea in Administrative Data: A Study of Diagnostic Accuracy. Anesthesiology.
777 McMahon JP, Foresman BH, Chisholm RC. (2003). The influence of CPAP on the neurobehavioral performance of patients with obstructive sleep apnea hypopnea syndrome: a systematic review. Wis Med J.
778 McMillan A, Bratton DJ, Faria R, et al. (2015). A multicentre randomised controlled trial and economic evaluation of continuous positive airway pressure for the treatment of obstructive sleep apnoea syndrome in older people: PREDICT. Health Technol Assess.
779 McMillan A, Paniccia L, Glasser M, et al. (2013). The impact of continuous positive airway pressure (CPAP) therapy on cognitive function in older people with sleep disordered breathing (SDB) and co morbidity. Thorax.
780 McNicholas WT. (2008). Diagnosis of obstructive sleep apnea in adults. Proc Am Thorac Soc.
781 Mehta A, Qian J, Petocz P, et al. (2001). A randomized, controlled study of a mandibular advancement splint for obstructive sleep apnea. Am J Respir Crit Care Med.
782 Mehta V, Subramanyam R, Shapiro CM, et al. (2012). Health effects of identifying patients with undiagnosed obstructive sleep apnea in the preoperative clinic: a follow-up study. Can J Anaesth.
783 Mehta V, Vasu TS, Phillips B, et al. (2013). Obstructive sleep apnea and oxygen therapy: a systematic review of the literature and meta-analysis. J Clin Sleep Med.
784 Meissner WG, Flabeau O, Perez P, et al. (2014). Accuracy of portable polygraphy for the diagnosis of sleep apnea in multiple system atrophy. Sleep Med.
785 Mendelson WB. (1994). Use of the sleep laboratory in suspected sleep apnea syndrome: is one night enough?. Cleve Clin J Med.
786 Mendez MO, Corthout J, Van Huffel S, et al. (2010). Automatic screening of obstructive sleep apnea from the ECG based on empirical mode decomposition and wavelet analysis. Physiol Meas.
787 Mendonca E, Mello-Fujita L, Cintra F, et al. (2010). An association between age and compliance to CPAP treatment of obstructive sleep apnoea: A controlled study. J Sleep Res.
788 Merlin T, Liufu Z, Wang S. (2010). Unattended sleep studies in the diagnosis and reassessment of obstructive sleep apnoea. Health Technology Assessment Database.
789 Merritt SL, Berger BE. (2004). Obstructive sleep apnea-hypopnea syndrome. The American journal of nursing.
790 Mesarwi OA, Shin MK, Drager LF, et al. (2015). Lysyl oxidase as a serum biomarker of liver fibrosis in patients with severe obesity and obstructive sleep Apnea. Sleep.
791 Meslemani D, Jones LR. (2011). Skeletal surgery in sleep apnea. Curr Opin Otolaryngol Head Neck Surg.
792 Mesquita J, Fiz JA, Sola-Soler J, et al. (2010). Regular and non regular snore features as markers of SAHS. Conf Proc IEEE Eng Med Biol Soc.
793 Meston N, Davies RJ, Mullins R, et al. (2003). Endocrine effects of nasal continuous positive airway pressure in male patients with obstructive sleep apnoea. J Intern Med.
794 Meyer TJ, Eveloff SE, Kline LR, et al. (1993). One negative polysomnogram does not exclude obstructive sleep apnea. Chest.
795 Michaelson PG, Allan P, Chaney J, et al. (2006). Validations of a portable home sleep study with twelve-lead polysomnography: comparisons and insights into a variable gold standard. Ann Otol Rhinol Laryngol.
796 Middelkoop HA, Knuistingh Neven A, van Hilten JJ, et al. (1995). Wrist actigraphic assessment of sleep in 116 community based subjects suspected of obstructive sleep apnoea syndrome. Thorax.
797 Milleron O, Pilliere R, Foucher A, et al. (2004). Benefits of obstructive sleep apnoea treatment in coronary artery disease: a long-term follow-up study. Eur Heart J.
798 Min HJ, Cho YJ, Kim CH, et al. (2015). Clinical features of obstructive sleep apnea that determine its high prevalence in resistant hypertension. Yonsei Med J.
799 Mitchell LJ, Davidson ZE, Bonham M, et al. (2014). Weight loss from lifestyle interventions and severity of sleep apnoea: a systematic review and meta-analysis. Database of Abstracts of Reviews of Effects.
800 Monaca C, Duhamel A, Jacquesson JM, et al. (2006). Vigilance troubles in Parkinson's disease: a subjective and objective polysomnographic study. Sleep Med.
801 Monasterio C, Vidal S, Duran J, et al. (2001). Effectiveness of continuous positive airway pressure in mild sleep apnea-hypopnea syndrome. Am J Respir Crit Care Med.
802 Montesi SB, Edwards BA, Malhotra A, et al. (2012). The effect of continuous positive airway pressure treatment on blood pressure: a systematic review and meta-analysis of randomized controlled trials. J Clin Sleep Med.
803 Morillo D, Rojas Ojeda JL, Crespo Foix LF, et al. (2010). An accelerometer-based device for sleep apnea screening. IEEE Trans Inf Technol Biomed.
804 Morrell MJ, Finn L, McMillan A, et al. (2012). The impact of ageing and sex on the association between sleepiness and sleep disordered breathing. Eur Respir J.
805 Morris LG, Kleinberger A, Lee KC, et al. (2008). Rapid risk stratification for obstructive sleep apnea, based on snoring severity and body mass index. Otolaryngol Head Neck Surg.
806 Mosko SS, Dickel MJ, Ashurst J. (1988). Night-to-night variability in sleep apnea and sleep-related periodic leg movements in the elderly. Sleep.
807 Moss J, Tew GA, Copeland RJ, et al. (2012). Effects of a lifestyle intervention in obese obstructive sleep apnoea patients treated with continuous positive airway pressure. Journal of Sleep Research.
808 Mulgrew AT, Fox N, Ayas NT, et al. (2007). Diagnosis and initial management of obstructive sleep apnea without polysomnography: a randomized validation study. Ann Intern Med.
809 Mundy L, Sullivan T, Merlin T, et al. (2006). Pillar procedure for the treatment of obstructive sleep apnoea and snoring. Health Technology Assessment Database.
810 Mungan U, Ozeke O, Mavioglu L, et al. (2013). The role of the preoperative screening of sleep apnoea by Berlin Questionnaire and Epworth Sleepiness Scale for postoperative atrial fibrillation. Heart Lung Circ.
811 Munish M, Sharma V, Yarussi KM, et al. (2012). The use of practice guidelines by the American Society of Anesthesiologists for the identification of surgical patients at high risk of sleep apnea. Chron Respir Dis.
812 Munoz A, Mayoralas LR, Barbe F, et al. (2000). Long-term effects of CPAP on daytime functioning in patients with sleep apnoea syndrome. Eur Respir J.
813 Munoz R, Duran-Cantolla J, Martinez-Vila E, et al. (2006). Severe sleep apnea and risk of ischemic stroke in the elderly. Stroke.
814 Muraja-Murro A, Eskola K, Kolari T, et al. (2013). Mortality in middle-aged men with obstructive sleep apnea in Finland. Sleep Breath.
815 Muraja-Murro A, Kulkas A, Hiltunen M, et al. (2013). The severity of individual obstruction events is related to increased mortality rate in severe obstructive sleep apnea. J Sleep Res.
816 Musman S, Passos VM, Silva IB, et al. (2011). Evaluation of a prediction model for sleep apnea in patients submitted to polysomnography. J Bras Pneumol.
817 Muxfeldt ES, Margallo V, Costa LM, et al. (2015). Effects of continuous positive airway pressure treatment on clinic and ambulatory blood pressures in patients with obstructive sleep apnea and resistant hypertension: a randomized controlled trial. Hypertension.
818 Myers KA, Mrkobrada M, Simel DL. (2013). Does this patient have obstructive sleep apnea? The Rational Clinical Examination systematic review. JAMA.
819 Myhill PC, Davis WA, Peters KE, et al. (2012). Effect of continuous positive airway pressure therapy on cardiovascular risk factors in patients with type 2 diabetes and obstructive sleep apnea. J Clin Endocrinol Metab.
820 Mykytyn IJ, Sajkov D, Neill AM, et al. (1999). Portable computerized polysomnography in attended and unattended settings. Chest.
821 Nakano H, Ikeda T, Hayashi M, et al. (2004). Effect of body mass index on overnight oximetry for the diagnosis of sleep apnea. Respir Med.
822 Nakano H, Tanigawa T, Furukawa T, et al. (2007). Automatic detection of sleep-disordered breathing from a single-channel airflow record. Eur Respir J.
823 Nakano H, Tanigawa T, Ohnishi Y, et al. (2008). Validation of a single-channel airflow monitor for screening of sleep-disordered breathing. Eur Respir J.
824 Naughton M, Pierce R. (1991). Effects of nasal continuous positive airway pressure on blood pressure and body mass index in obstructive sleep apnoea. Aust N Z J Med.
825 (2015). NCT00127348. Effect of Continuous Positive Airway Pressure (CPAP) on Hypertension and Cardiovascular Morbidity-Mortality in Patients With Sleep Apnea and no Daytime Sleepiness.
826 (2015). NCT00477828. Effect of Treating Sleep Apnea on Cognition in Patients With Dementia.
827 (2015). NCT01156116. Effective Treatment of Sleep Apnea in Prediabetes to Reduce Cardiometabolic Risk.
828 (2015). NCT01196117. Sleepiness and the Effects of CPAP on Salivary Cortisol and Alpha-Amylase Levels in Patients With Sleep Apnea.
829 Ndegwa S, Clark M, Argaez C. (2009). Portable monitoring devices for diagnosis of obstructive sleep apnea at home: review of accuracy, cost effectiveness, guidelines, and coverage in Canada. Health Technology Assessment Database.
830 Neill A, Campbell A, Richards M, et al. (2004). Nasal CPAP improves echocardiographic indices in patients with obstructive sleep apnoea and heart failure. Respirology (Carlton, Vic.).
831 Nelesen RA, Yu H, Ziegler MG, et al. (2001). Continuous positive airway pressure normalizes cardiac autonomic and hemodynamic responses to a laboratory stressor in apneic patients. Chest.
832 Neligan PJ, Malhotra G, Fraser M, et al. (2009). Continuous positive airway pressure via the Boussignac system immediately after extubation improves lung function in morbidly obese patients with obstructive sleep apnea undergoing laparoscopic bariatric surgery. Anesthesiology.
833 Nena E, Tsara V, Steiropoulos P, et al. (2008). Sleep-disordered breathing and quality of life of railway drivers in Greece. Chest.
834 Nerfeldt P, Aoki F, Friberg D. (2014). Polygraphy vs. polysomnography: missing osas in symptomatic snorers--a reminder for clinicians. Sleep Breath.
835 Nerfeldt P, Nilsson BY, Mayor L, et al. (2010). A two-year weight reduction program in obese sleep apnea patients. J Clin Sleep Med.
836 Nerfeldt P, Nilsson BY, Udden J, et al. (2008). Weight reduction improves nocturnal respiration in obese sleep apnoea patients - a randomized controlled pilot study. Obes Res Clin Pract.
837 Nettleton D, Muniz J. (2001). Processing and representation of meta-data for sleep apnea diagnosis with an artificial intelligence approach. Int J Med Inform.
838 Netzer NC, Stoohs RA, Netzer CM, et al. (1999). Using the Berlin Questionnaire to identify patients at risk for the sleep apnea syndrome. Ann Intern Med.
839 Newall C, McCauley TM, Stockley J, et al. (2006). Changes in health status after a trial of continuous positive airway pressure in patients with obstructive sleep apnoea: 2 week v 4 week trial. Thorax.
840 Ng SS, Chan TO, To KW, et al. (2009). Validation of a portable recording device (ApneaLink) for identifying patients with suspected obstructive sleep apnoea syndrome. Intern Med J.
841 Ng SS, Chan TO, To KW, et al. (2010). Validation of Embletta portable diagnostic system for identifying patients with suspected obstructive sleep apnoea syndrome (OSAS). Respirology.
842 Nguyen AT, Baltzan MA, Small D, et al. (2006). Clinical reproducibility of the Epworth Sleepiness Scale. J Clin Sleep Med.
843 Nguyen NT, Nguyen B, Smith B, et al. (2013). Proposal for a bariatric mortality risk classification system for patients undergoing bariatric surgery. Surg Obes Relat Dis.
844 Nicholl DD, Ahmed SB, Loewen AH, et al. (2012). Clinical presentation of obstructive sleep apnea in patients with chronic kidney disease. J Clin Sleep Med.
845 Nicholl DD, Ahmed SB, Loewen AH, et al. (2013). Diagnostic value of screening instruments for identifying obstructive sleep apnea in kidney failure. J Clin Sleep Med.
846 Nickerson JE, Krieger AC, Simon EP, et al. (2012). Feasibility of portable technology to diagnose sleep apnea in underserved communities. J Gen Intern Med.
847 Nigro CA, Aimaretti S, Gonzalez S, et al. (2009). Validation of the WristOx 3100 oximeter for the diagnosis of sleep apnea/hypopnea syndrome. Sleep Breath.
848 Nigro CA, Dibur E, Aragone MR, et al. (2015). Can CPAP be indicated in adult patients with suspected obstructive sleep apnea only on the basis of clinical data?. Sleep and Breathing.
849 Nigro CA, Gonzalez S, Arce A, et al. (2015). Accuracy of a novel auto-CPAP device to evaluate the residual apnea-hypopnea index in patients with obstructive sleep apnea. Sleep and Breathing.
850 Nishiyama T, Mizuno T, Kojima M, et al. (2014). Criterion validity of the Pittsburgh Sleep Quality Index and Epworth Sleepiness Scale for the diagnosis of sleep disorders. Sleep Med.
851 Noda A, Nakata S, Koike Y, et al. (2007). Continuous positive airway pressure improves daytime baroreflex sensitivity and nitric oxide production in patients with moderate to severe obstructive sleep apnea syndrome. Hypertens Res.
852 Nordgard S, Hein G, Stene BK, et al. (2007). One-year results: palatal implants for the treatment of obstructive sleep apnea. Otolaryngol Head Neck Surg.
853 Norman MB, Middleton S, Erskine O, et al. (2014). Validation of the Sonomat: a contactless monitoring system used for the diagnosis of sleep disordered breathing. Sleep.
854 Nuckton TJ, Glidden DV, Browner WS, et al. (2006). Physical examination: Mallampati score as an independent predictor of obstructive sleep apnea. Sleep.
855 Nunes FS, Danzi-Soares NJ, Genta PR, et al. (2015). Critical evaluation of screening questionnaires for obstructive sleep apnea in patients undergoing coronary artery bypass grafting and abdominal surgery. Sleep Breath.
856 Oeverland B, Akre H, Kvaerner KJ, et al. (2005). Patient discomfort in polysomnography with esophageal pressure measurements. Eur Arch Otorhinolaryngol.
857 O'Gorman SM, Gay PC, Morgenthaler TI. (2013). Does autotitrating positive airway pressure therapy improve postoperative outcome in patients at risk for obstructive sleep apnea syndrome? A randomized controlled clinical trial. Chest.
858 Ogretmenoglu O, Suslu AE, Yucel OT, et al. (2005). Body fat composition: a predictive factor for obstructive sleep apnea. Laryngoscope.
859 O'Hara R, Schroder CM, Kraemer HC, et al. (2005). Nocturnal sleep apnea/hypopnea is associated with lower memory performance in APOE epsilon4 carriers. Neurology.
860 Ohayon MM, Guilleminault C, Zulley J, et al. (1999). Validation of the sleep-EVAL system against clinical assessments of sleep disorders and polysomnographic data. Sleep.
861 Ohmura T, Iwama Y, Kasai T, et al. (2014). Impact of predischarge nocturnal pulse oximetry (sleep-disordered breathing) on postdischarge clinical outcomes in hospitalized patients with left ventricular systolic dysfunction after acute decompensated heart failure. Am J Cardiol.
862 Oktay B, Akbal E, Firat H, et al. (2009). CPAP treatment in the coexistence of obstructive sleep apnea syndrome and metabolic syndrome, results of one year follow up. Acta Clin Belg.
863 Oktay B, Rice TB, Atwood CW, et al. (2011). Evaluation of a single-channel portable monitor for the diagnosis of obstructive sleep apnea. J Clin Sleep Med.
864 Olaithe M, Skinner TC, Clarke J, et al. (2013). Can we get more from the Epworth Sleepiness Scale (ESS) than just a single score? A confirmatory factor analysis of the ESS. Sleep Breath.
865 Oliveira MG, Nery LE, Santos-Silva R, et al. (2012). Is portable monitoring accurate in the diagnosis of obstructive sleep apnea syndrome in chronic pulmonary obstructive disease?. Sleep Med.
866 Oliveira MG, Santos-Silva R, Borba P, et al. (2010). Validation of a cardio-respiratory device for the diagnosis of obstructive sleep apnoea in patients with chronic obstructive pulmonary disease - Preliminary results. J Sleep Res.
867 Oliveira W, Campos O, Cintra F, et al. (2009). Impact of continuous positive airway pressure treatment on left atrial volume and function in patients with obstructive sleep apnoea assessed by real-time three-dimensional echocardiography. Heart (British Cardiac Society).
868 Oliveira W, Poyares D, Cintra F, et al. (2012). Impact of continuous positive airway pressure treatment on right ventricle performance in patients with obstructive sleep apnoea, assessed by three-dimensional echocardiography. Echocardiography.
869 Oliveira W, Poyares D, Cintra F, et al. (2012). Impact of continuous positive airway pressure treatment on right ventricle performance in patients with obstructive sleep apnoea, assessed by three-dimensional echocardiography. Sleep Med.
870 Olson LG, King MT, Hensley MJ, et al. (1995). A community study of snoring and sleep-disordered breathing. Health outcomes. Am J Respir Crit Care Med.
871 Olson LG, King MT, Hensley MJ, et al. (1995). A community study of snoring and sleep-disordered breathing. Symptoms. Am J Respir Crit Care Med.
872 Olszewski K, Wolf D. (2013). Obstructive sleep apnea among commercial motor vehicle drivers: using evidence-based practice to identify risk factors. Workplace Health Saf.
873 Onder NS, Akpinar ME, Yigit O, et al. (2012). Watch peripheral arterial tonometry in the diagnosis of obstructive sleep apnea: influence of aging. Laryngoscope.
874 Onen F, Moreau T, Gooneratne NS, et al. (2013). Limits of the Epworth Sleepiness Scale in older adults. Sleep Breath.
875 Onen SH, Onen F, Albrand G, et al. (2010). Pain tolerance and obstructive sleep apnea in the elderly. J Am Med Dir Assoc.
876 Ong TH, Raudha S, Fook-Chong S, et al. (2010). Simplifying STOP-BANG: use of a simple questionnaire to screen for OSA in an Asian population. Sleep Breath.
877 Orr WC, Eiken T, Pegram V, et al. (1994). A laboratory validation study of a portable system for remote recording of sleep-related respiratory disorders. Chest.
878 Osman EZ, Osborne J, Hill PD, et al. (1999). The Epworth Sleepiness Scale: can it be used for sleep apnoea screening among snorers?. Clin Otolaryngol Allied Sci.
879 O'Sullivan RA, Hillman DR, Mateljan R, et al. (1993). Mandibular advancement splint: the effects on snoring and obstructive sleep apnea. Sleep.
880 O'Sullivan RA, Hillman DR, Mateljan R, et al. (1995). Mandibular advancement splint: an appliance to treat snoring and obstructive sleep apnea. Am J Respir Crit Care Med.
881 Otake K, Delaive K, Walld R, et al. (2002). Cardiovascular medication use in patients with undiagnosed obstructive sleep apnoea. Thorax.
882 Otero A, Felix P, Presedo J, et al. (2012). An evaluation of indexes as support tools in the diagnosis of sleep apnea. Ann Biomed Eng.
883 Ou Q, Chen YC, Zhuo SQ, et al. (2015). Continuous positive airway pressure treatment reduces mortality in elderly patients with moderate to severe obstructive severe sleep apnea: A cohort study. PLoS One.
884 Overland B, Bruskeland G, Akre H, et al. (2005). Evaluation of a portable recording device (Reggie) with actimeter and nasopharyngeal/esophagus catheter incorporated. Respiration.
885 Ozcan KM, Ozcan M, Ozdogan F, et al. (2013). The predictive value of Muller maneuver in REM-dependent obstructive sleep apnea. Eur Arch Otorhinolaryngol.
886 Ozdas T, Ozcan KM, Ozdogan F, et al. (2013). Investigation of lateral pharyngeal walls in OSAS. Eur Arch Otorhinolaryngol.
887 Ozmen OA, Tuzemen G, Kasapoglu F, et al. (2011). The reliability of SleepStrip as a screening test in obstructive sleep apnea syndrome. Kulak Burun Bogaz Ihtis Derg.
888 Pahkala R, Seppa J, Ikonen A, et al. (2014). The impact of pharyngeal fat tissue on the pathogenesis of obstructive sleep apnea. Sleep and Breathing.
889 Paim SL, Pires ML, Bittencourt LR, et al. (2008). Sleep complaints and polysomnographic findings: a study of nuclear power plant shift workers. Chronobiol Int.
890 Palla A, Digiorgio M, Carpene N, et al. (2009). Sleep apnea in morbidly obese patients: prevalence and clinical predictivity. Respiration.
891 Pallayova M, Steele KE, Magnuson TH, et al. (2011). Sleep apnea determines soluble TNF-alpha receptor 2 response to massive weight loss. Obes Surg.
892 Pallin M, O'Hare E, Zaffaroni A, et al. (2014). Comparison of a novel non-contact biomotion sensor with wrist actigraphy in estimating sleep quality in patients with obstructive sleep apnoea. J Sleep Res.
893 Palombini LO, Tufik S, Rapoport DM, et al. (2013). Inspiratory flow limitation in a normal population of adults in Sao Paulo, Brazil. Sleep.
894 Pamidi S, Knutson KL, Ghods F, et al. (2011). Depressive symptoms and obesity as predictors of sleepiness and quality of life in patients with REM-related obstructive sleep apnea: cross-sectional analysis of a large clinical population. Sleep Med.
895 Pan F, Liu J, Xie Y, et al. (2015). Zhonghua Yi Xue Za Zhi.
896 Pan YY, Deng Y, Xu X, et al. (2015). Effects of continuous positive airway pressure on cognitive deficits in middle-aged patients with obstructive sleep apnea syndrome: A meta-analysis of randomized controlled trials. Chin Med J.
897 Pang KP, Dillard TA, Blanchard AR, et al. (2006). A comparison of polysomnography and the SleepStrip in the diagnosis of OSA. Otolaryngol Head Neck Surg.
898 Pang KP, Gourin CG, Terris DJ. (2007). A comparison of polysomnography and the WatchPAT in the diagnosis of obstructive sleep apnea. Otolaryngol Head Neck Surg.
899 Pang KP, Siow JK, Tseng P. (2012). Safety of multilevel surgery in obstructive sleep apnea: a review of 487 cases. Arch Otolaryngol Head Neck Surg.
900 Pang KP, Woodson BT. (2007). Expansion sphincter pharyngoplasty: a new technique for the treatment of obstructive sleep apnea. Otolaryngol Head Neck Surg.
901 Papadimitriou V, Sofras F, Bouloukaki I, et al. (2010). CPAP versus CPAP plus low dose of PDE-inhibitor in men with obstructive sleep apnoea-hypopnoea syndrome and erectile dysfunction. J Sleep Res.
902 Papandreou C, Schiza SE, Bouloukaki I, et al. (2012). Effect of Mediterranean diet versus prudent diet combined with physical activity on OSAS: a randomised trial. Eur Respir J.
903 Park do Y, Kim HJ, Kim CH, et al. (2015). Reliability and validity testing of automated scoring in obstructive sleep apnea diagnosis with the Embletta X100. Laryngoscope.
904 Parks P, Durand G, Tsismenakis AJ, et al. (2009). Screening for obstructive sleep apnea during commercial driver medical examinations. J Occup Environ Med.
905 Parra i Ordaz O. (2012). AHI as an independent risk factor for sleepiness. Arch Bronconeumol.
906 Parra O, Garcia-Esclasans N, Montserrat JM, et al. (1997). Should patients with sleep apnoea/hypopnoea syndrome be diagnosed and managed on the basis of home sleep studies?. Eur Respir J.
907 Parra O, Sanchez-Armengol A, Bonnin M, et al. (2011). Early treatment of obstructive apnoea and stroke outcome: a randomised controlled trial. Eur Respir J.
908 Parra O, Sanchez-Armengol MA, Bonnin M, et al. (2009). Usefulness of nasal CPAP in patients with a first ever stroke and sleep disordered breathing: 2 years follow-up. Eur Respir J.
909 Partinen M, Guilleminault C. (1990). Daytime sleepiness and vascular morbidity at seven-year follow-up in obstructive sleep apnea patients. Chest.
910 Partinen M, Jamieson A, Guilleminault C. (1988). Long-term outcome for obstructive sleep apnea syndrome patients. Mortality. Chest.
911 Pastore AL, Palleschi G, Silvestri L, et al. (2015). Severe obstructive sleep apnoea syndrome and erectile dysfunction: A prospective randomised study to compare sildenafil vs. Nasal continuous positive airway pressure. J Urol.
912 Pataka A, Daskalopoulou E, Kalamaras G, et al. (2014). Evaluation of five different questionnaires for assessing sleep apnea syndrome in a sleep clinic. Sleep Med.
913 Patwardhan AA, Larson MG, Levy D, et al. (2006). Obstructive sleep apnea and plasma natriuretic peptide levels in a community-based sample. Sleep.
914 Pedrosa RP, Drager LF, de Paula LK, et al. (2013). Effects of OSA treatment on BP in patients with resistant hypertension: a randomized trial. Chest.
915 Peker Y, Carlson J, Hedner J. (2006). Increased incidence of coronary artery disease in sleep apnoea: a long-term follow-up. Eur Respir J.
916 Peker Y, Glantz H, Thunstrom E, et al. (2009). Rationale and design of the Randomized Intervention with CPAP in Coronary Artery Disease and Sleep Apnoea--RICCADSA trial. Scand Cardiovasc J.
917 Peker Y, Hedner J, Norum J, et al. (2002). Increased incidence of cardiovascular disease in middle-aged men with obstructive sleep apnea: a 7-year follow-up. Am J Respir Crit Care Med.
918 Pelechas E, Doina A. (2014). Impact of nasal continuous positive airway pressure on heart rhythm in patients with obstructive sleep apnea/hypopnea syndrome. Minerva Med.
919 Pelletier-Fleury N, Meslier N, Gagnadoux F, et al. (2004). Economic arguments for the immediate management of moderate-to-severe obstructive sleep apnoea syndrome. Eur Respir J.
920 Pendlebury ST, Pepin JL, Veale D, et al. (1997). Natural evolution of moderate sleep apnoea syndrome: significant progression over a mean of 17 months. Thorax.
921 Penzel T, Kesper K, Pinnow I, et al. (2004). Peripheral arterial tonometry, oximetry and actigraphy for ambulatory recording of sleep apnea. Physiol Meas.
922 Pepin JL, Defaye P, Vincent E, et al. (2009). Sleep apnea diagnosis using an ECG Holter device including a nasal pressure (NP) recording: validation of visual and automatic analysis of nasal pressure versus full polysomnography. Sleep Med.
923 Peppard PE, Young T, Palta M, et al. (2000). Longitudinal study of moderate weight change and sleep-disordered breathing. JAMA.
924 Pepperell JCT, Mullins B, Dow SR, et al. (2000). Blood pressure change after treatment for obstructive sleep apnoea (OSA) with continuous positive airway pressure (CPAP). Thorax.
925 Perleth M, Leyen Uvd, Schmitt H, et al. (2003). Diagnosis and treatment of sleep apnea - systematic review of diagnostics, therapy, and cost-effectiveness. Health Technology Assessment Database.
926 Permut I, Diaz-Abad M, Chatila W, et al. (2010). Comparison of positional therapy to CPAP in patients with positional obstructive sleep apnea. J Clin Sleep Med.
927 Persaud N. (2010). APNEIC: an easy-to-use screening tool for obstructive sleep apnea. Can Fam Physician.
928 Peter JV, Moran JL, Phillips-Hughes J, et al. (2002). Noninvasive ventilation in acute respiratory failure: a meta-analysis update. Crit Care Med.
929 Phillips B, Shafazand S. (2013). CPAP and hypertension in nonsleepy patients. J Clin Sleep Med.
930 Phillips CL, McEwen BJ, Morel-Kopp MC, et al. (2012). Effects of continuous positive airway pressure on coagulability in obstructive sleep apnoea: a randomised, placebo-controlled crossover study. Thorax.
931 Phillips CL, Yee BJ, Marshall NS, et al. (2010). Treatment of obstructive sleep apnoea reduces post-prandial lipidaemia: Evidence from a randomized, placebo-controlled trial of continuous positive airway pressure. J Sleep Res.
932 Phillips MC, Costello CA, White EJ, et al. (2013). Routine polysomnography in an epilepsy monitoring unit. Epilepsy Res.
933 Pichon Riviere A, Augustovski F, Alcaraz A, et al. (2006). Outpatient BiPAP (bi-level positive airway pressure) in obstructive sleep apnea. Health Technology Assessment Database.
934 Pichon Riviere A, Augustovski F, Garcia Marti S, et al. (2012). Upper respiratory tract surgical techniques for the treatment of patients with obstructive sleep apnea syndrome. Health Technology Assessment Database.
935 Pichon-Riviere A, Augustovski F, Garcia Marti S, et al. (2008). Autoset usefulness in the diagnosis of obstructive sleep apnea. Health Technology Assessment Database.
936 Pillar G, Bar A, Betito M, et al. (2003). An automatic ambulatory device for detection of AASM defined arousals from sleep: the WP100. Sleep Med.
937 Pillar G, Bar A, Shlitner A, et al. (2002). Autonomic arousal index: an automated detection based on peripheral arterial tonometry. Sleep.
938 Pinna GD, Robbi E, Pizza F, et al. (2014). Can cardiorespiratory polygraphy replace portable polysomnography in the assessment of sleep-disordered breathing in heart failure patients?. Sleep Breath.
939 Pinto JA, Godoy LB, Marquis VW, et al. (2011). Anthropometric data as predictors of Obstructive Sleep Apnea Severity. Braz J Otorhinolaryngol.
940 Piper AJ, Laks L, Sullivan CE. (1993). Effectiveness of short-term NIPPV in the management of patients with severe OSA and REM hypoventilation. Sleep.
941 Pittman SD, Ayas NT, MacDonald MM, et al. (2004). Using a wrist-worn device based on peripheral arterial tonometry to diagnose obstructive sleep apnea: in-laboratory and ambulatory validation. Sleep.
942 Pittman SD, MacDonald MM, Fogel RB, et al. (2004). Assessment of automated scoring of polysomnographic recordings in a population with suspected sleep-disordered breathing. Sleep.
943 Planes C, Leroy M, Bouach Khalil N, et al. (2010). Home diagnosis of obstructive sleep apnoea in coronary patients: validity of a simplified device automated analysis. Sleep Breath.
944 Platt AB, Wick LC, Hurley S, et al. (2013). Hits and misses: screening commercial drivers for obstructive sleep apnea using guidelines recommended by a joint task force. J Occup Environ Med.
945 Polese JF, Santos-Silva R, de Oliveira Ferrari PM, et al. (2013). Is portable monitoring for diagnosing obstructive sleep apnea syndrome suitable in elderly population?. Sleep Breath.
946 Pons Y, Ballivet de Regloix S, Maurin O, et al. (2011). Prevalence of and risk factors for obstructive syndrome apnea. Rev Laryngol Otol Rhinol (Bord).
947 Popovic D, Khoo M, Westbrook P. (2014). Automatic scoring of sleep stages and cortical arousals using two electrodes on the forehead: validation in healthy adults. J Sleep Res.
948 Porthan KM, Melin JH, Kupila JT, et al. (2004). Prevalence of sleep apnea syndrome in lone atrial fibrillation: a case-control study. Chest.
949 Portier F, Portmann A, Czernichow P, et al. (2000). Evaluation of home versus laboratory polysomnography in the diagnosis of sleep apnea syndrome. Am J Respir Crit Care Med.
950 Pouliot Z, Peters M, Neufeld H, et al. (1997). Using self-reported questionnaire data to prioritize OSA patients for polysomnography. Sleep.
951 Poupard L, Mathieu M, Goldman M, et al. (2012). Multi-modal ECG Holter system for sleep-disordered breathing screening: a validation study. Sleep Breath.
952 Powell NB, Zonato AI, Weaver EM, et al. (2001). Radiofrequency treatment of turbinate hypertrophy in subjects using continuous positive airway pressure: a randomized, double-blind, placebo-controlled clinical pilot trial. Laryngoscope.
953 Pradeep Kumar VG, Bhatia M, Tripathi M, et al. (2003). Obstructive sleep apnoea: a case-control study. Neurol India.
954 Pradhan PS, Gliklich RE, Winkelman J. (1996). Screening for obstructive sleep apnea in patients presenting for snoring surgery. Laryngoscope.
955 Pranathiageswaran S, Badr MS, Severson R, et al. (2013). The influence of race on the severity of sleep disordered breathing. J Clin Sleep Med.
956 Prasad B, Carley DW, Herdegen JJ. (2010). Continuous positive airway pressure device-based automated detection of obstructive sleep apnea compared to standard laboratory polysomnography. Sleep Breath.
957 Prilipko O, Huynh N, Schwartz S, et al. (2012). The Effects of CPAP Treatment on Task Positive and Default Mode Networks in Obstructive Sleep Apnea Patients: An fMRI Study. PLoS One.
958 Priou P, Hamel JF, Person C, et al. (2010). Long-term outcome of noninvasive positive pressure ventilation for obesity hypoventilation syndrome. Chest.
959 Profant J, Ancoli-Israel S, Dimsdale JE. (2003). A randomized, controlled trial of 1 week of continuous positive airway pressure treatment on quality of life. Heart Lung.
960 Proimos E, Kiagiadaki D, Kaprana A, et al. (2012). Clinical application of subjective measurements for OSAS assessment: predictive factors of syndrome severity. ORL J Otorhinolaryngol Relat Spec.
961 Prudon B, Roddy E, Stradling JR, et al. (2012). CPAP therapy does not reduce serum uric acid levels in obstructive sleep apnoea. Thorax.
962 Prudon B, Roddy E, Stradling JR, et al. (2013). Serum urate levels are unchanged with continuous positive airway pressure therapy for obstructive sleep apnea: a randomized controlled trial. Sleep Med.
963 Qaddoura A, Kabali C, Drew D, et al. (2014). Obstructive sleep apnea as a predictor of atrial fibrillation after coronary artery bypass grafting: a systematic review and meta-analysis. Database of Abstracts of Reviews of Effects.
964 Qaseem A, Dallas P, Owens DK, et al. (2014). Diagnosis of obstructive sleep apnea in adults: a clinical practice guideline from the American College of Physicians. Ann Intern Med.
965 Quan SF, Budhiraja R, Clarke DP, et al. (2013). Impact of treatment with continuous positive airway pressure (CPAP) on weight in obstructive sleep apnea. J Clin Sleep Med.
966 Quan SF, Griswold ME, Iber C, et al. (2002). Short-term variability of respiration and sleep during unattended nonlaboratory polysomnography--the Sleep Heart Health Study. [corrected]. Sleep.
967 Quan SF, Wright R, Baldwin CM, et al. (2006). Obstructive sleep apnea-hypopnea and neurocognitive functioning in the Sleep Heart Health Study. Sleep Med.
968 Quera-Salva MA, Guilleminault C, Partinen M, et al. (1988). Determinants of respiratory disturbance and oxygen saturation drop indices in obstructive sleep apnoea syndrome. Eur Respir J.
969 Querejeta Roca G, Redline S, Punjabi N, et al. (2013). Sleep apnea is associated with subclinical myocardial injury in the community. The ARIC-SHHS study. Am J Respir Crit Care Med.
970 Quinnell TG, Clutterbuck-James AL, Bennett M, et al. (2014). Randomised controlled trial of mandibular advancement devices for obstructive sleep apnoea (TOMADO): One year follow-up. J Sleep Res.
971 Quinnell TG, Pittman MA, Bennett M, et al. (2014). TOMADO: A crossover randomised controlled trial of oral mandibular advancement devices for obstructive sleep apnoea-hypopnoea. Thorax.
972 Quintana-Gallego E, Villa-Gil M, Carmona-Bernal C, et al. (2004). Home respiratory polygraphy for diagnosis of sleep-disordered breathing in heart failure. Eur Respir J.
973 Raff H, Ettema SL, Eastwood DC, et al. (2011). Salivary cortisol in obstructive sleep apnea: the effect of CPAP. Endocrine.
974 Ragette R, Wang Y, Weinreich G, et al. (2010). Diagnostic performance of single airflow channel recording (ApneaLink) in home diagnosis of sleep apnea. Sleep Breath.
975 Rakel RE. (2009). Clinical and societal consequences of obstructive sleep apnea and excessive daytime sleepiness. Postgrad Med.
976 Ramachandran SK, Josephs LA. (2009). A meta-analysis of clinical screening tests for obstructive sleep apnea. Anesthesiology.
977 Ramachandran SK, Kheterpal S, Consens F, et al. (2010). Derivation and validation of a simple perioperative sleep apnea prediction score. Anesth Analg.
978 Randerath W, David M, Feldmeyer F, et al. (1999). Prospective randomized study comparing impedance-controlled self-adjusting cpap therapy (apapfot) with constant cpap in the treatment of obstructive sleep apnoea syndrome (OSAS). European Respiratory Society.
979 Randerath WJ, Heise M, Hinz R, et al. (2002). An individually adjustable oral appliance vs continuous positive airway pressure in mild-to-moderate obstructive sleep apnea syndrome. Chest.
980 Randerath WJ, Treml M, Priegnitz C, et al. (2013). Evaluation of a noninvasive algorithm for differentiation of obstructive and central hypopneas. Sleep.
981 Rao A, Tey BH, Ramalingam G, et al. (2009). Obstructive sleep apnoea (OSA) patterns in bariatric surgical practice and response of OSA to weight loss after laparoscopic adjustable gastric banding (LAGB). Ann Acad Med Singapore.
982 Rasmussen JJ, Fuller WD, Ali MR. (2012). Sleep apnea syndrome is significantly underdiagnosed in bariatric surgical patients. Surg Obes Relat Dis.
983 Rauscher H, Popp W, Zwick H. (1991). Quantification of sleep disordered breathing by computerized analysis of oximetry, heart rate and snoring. Eur Respir J.
984 Rauscher H, Popp W, Zwick H. (1993). Model for investigating snorers with suspected sleep apnoea. Thorax.
985 Ravelo-Garcia AG, Saavedra-Santana P, Julia-Serda G, et al. (2014). Symbolic dynamics marker of heart rate variability combined with clinical variables enhance obstructive sleep apnea screening. Chaos.
986 Ravesloot MJ, de Vries N. (2011). One hundred consecutive patients undergoing drug-induced sleep endoscopy: results and evaluation. Laryngoscope.
987 Ravesloot MJ, van Maanen JP, Hilgevoord AA, et al. (2012). Obstructive sleep apnea is underrecognized and underdiagnosed in patients undergoing bariatric surgery. Eur Arch Otorhinolaryngol.
988 Raymond B, Cayton RM, Chappell MJ. (2003). Combined index of heart rate variability and oximetry in screening for the sleep apnoea/hypopnoea syndrome. J Sleep Res.
989 Redline S, Kump K, Tishler PV, et al. (1994). Gender differences in sleep disordered breathing in a community-based sample. Am J Respir Crit Care Med.
990 Redline S, Tosteson T, Boucher MA, et al. (1991). Measurement of sleep-related breathing disturbances in epidemiologic studies. Assessment of the validity and reproducibility of a portable monitoring device. Chest.
991 Redolfi S, Bettinzoli M, Venturoli N, et al. (2015). Attenuation of obstructive sleep apnea and overnight rostral fluid shift by physical activity. Am J Respir Crit Care Med.
992 Rees K, Wraith PK, Berthon-Jones M, et al. (1998). Detection of apnoeas, hypopnoeas and arousals by the AutoSet in the sleep apnoea/hypopnoea syndrome. Eur Respir J.
993 Reichert JA, Bloch DA, Cundiff E, et al. (2003). Comparison of the NovaSom QSG, a new sleep apnea home-diagnostic system, and polysomnography. Sleep Med.
994 Reichmuth KJ, Austin D, Skatrud JB, et al. (2005). Association of sleep apnea and type II diabetes: a population-based study. Am J Respir Crit Care Med.
995 Reinhard W, Plappert N, Zeman F, et al. (2013). Prognostic impact of sleep duration and sleep efficiency on mortality in patients with chronic heart failure. Sleep Med.
996 Reuveni H, Greenberg-Dotan S, Simon-Tuval T, et al. (2008). Elevated healthcare utilisation in young adult males with obstructive sleep apnoea. Eur Respir J.
997 Riad W, Chung F. (2013). Preoperative screening for obstructive sleep apnea in morbidly obese patients. Int Anesthesiol Clin.
998 Rich J, Raviv A, Raviv N, et al. (2012). All-cause mortality and obstructive sleep apnea severity revisited. Otolaryngol Head Neck Surg.
999 Riley RW, Powell NB, Li KK, et al. (2000). Surgery and obstructive sleep apnea: long-term clinical outcomes. Otolaryngol Head Neck Surg.
1000 Rizzi CF, Ferraz MB, Poyares D, et al. (2014). Quality-adjusted life-years gain and health status in patients with OSAS after one year of continuous positive airway pressure use. Sleep.
1001 Rizzi CF, Rios L, Mello-Fujita L, et al. (2010). Ambulatory blood pressure monitoring in patients with obstructive sleep apnoea after effective CPAP and sham treatments. J Sleep Res.
1002 Robinson GV, Pepperell JC, Segal HC, et al. (2004). Circulating cardiovascular risk factors in obstructive sleep apnoea: data from randomised controlled trials. Thorax.
1003 Robinson GV, Smith DM, Langford BA, et al. (2004). CPAP does not reduce 24 hour blood pressure in hypertensive obstructive sleep apnoea patients without daytime sleepiness. Thorax.
1004 Roche F, Sforza E, Hupin D. (2014). CPAP for excessive sleepiness in elderly patients. The Lancet Respiratory Medicine.
1005 Roche N, Durieux P. (1992). Evaluation of the application of nocturnal nasal continuous positive airway pressure (CPAP) in the treatment of obstructive sleep apnea. Health Technology Assessment Database.
1006 Rochford PD, Collins AL, Howard ME, et al. (2006). Comparison of two auto-titrating CPAP devices with fixed CPAP in obstructive sleep apnoea (OSA). Intern Med J.
1007 Rodriguez-Villegas E, Chen G, Radcliffe J, et al. (2014). A pilot study of a wearable apnoea detection device. BMJ Open.
1008 Rodsutti J, Hensley M, Thakkinstian A, et al. (2004). A clinical decision rule to prioritize polysomnography in patients with suspected sleep apnea. Sleep.
1009 Rodway GW, Weaver TE, Mancini C, et al. (2010). Evaluation of sham-CPAP as a placebo in CPAP intervention studies. Sleep.
1010 Roebuck T, Solin P, Kaye DM, et al. (2004). Increased long-term mortality in heart failure due to sleep apnoea is not yet proven. Eur Respir J.
1011 Romano S, Salvaggio A, Lo Bue A, et al. (2011). A negative expiratory pressure test during wakefulness for evaluating the risk of obstructive sleep apnea in patients referred for sleep studies. Clinics (Sao Paulo).
1012 Romem A, Koldobskiy D, Scharf SM. (2014). Diagnosis of obstructive sleep apnea using pulse oximeter derived photoplethysmographic signals. J Clin Sleep Med.
1013 Romero-Lopez Z, Ochoa-Vazquez MD, Mata-Marin JA, et al. (2011). Development and validation of a questionnaire to identify patients with sleep apnea in Mexican population: Mexican questionnaire to identify sleep apnea. Sleep Breath.
1014 Rosales-Mayor E, Rey de Castro J, Huayanay L, et al. (2012). Validation and modification of the Epworth Sleepiness Scale in Peruvian population. Sleep Breath.
1015 Rosenthal LD, Dolan DC. (2008). The Epworth sleepiness scale in the identification of obstructive sleep apnea. J Nerv Ment Dis.
1016 Ross SD, Allen IE, Harrison KJ, et al. (1999). Systematic review of the literature regarding the diagnosis of sleep apnea. Database of Abstracts of Reviews of Effects.
1017 Ross SD, Sheinhait IA, Harrison KJ, et al. (2000). Systematic review and meta-analysis of the literature regarding the diagnosis of sleep apnea. Sleep.
1018 Rossi VA, Stoewhas AC, Camen G, et al. (2012). The effects of continuous positive airway pressure therapy withdrawal on cardiac repolarization: data from a randomized controlled trial. Eur Heart J.
1019 Rossner S, Lagerstrand L, Persson HE, et al. (1991). The sleep apnoea syndrome in obesity: risk of sudden death. J Intern Med.
1020 Roth T, Zammit G, Kushida C, et al. (2002). A new quetionnaire to detect sleep disorders. Sleep Med.
1021 Rowley JA, Aboussouan LS, Badr MS. (2000). The use of clinical prediction formulas in the evaluation of obstructive sleep apnea. Sleep.
1022 Ruehland WR, O'Donoghue FJ, Pierce RJ, et al. (2011). The 2007 AASM recommendations for EEG electrode placement in polysomnography: impact on sleep and cortical arousal scoring. Sleep.
1023 Rusu A, Todea D, Rosca L, et al. (2012). The development of a sleep apnea screening program in Romanian type 2 diabetic patients: a pilot study. Acta Diabetol.
1024 Ryan CM, Bayley M, Green R, et al. (2011). Influence of continuous positive airway pressure on outcomes of rehabilitation in stroke patients with obstructive sleep apnea. Stroke.
1025 Ryan CM, Usui K, Floras JS, et al. (2005). Effect of continuous positive airway pressure on ventricular ectopy in heart failure patients with obstructive sleep apnoea. Thorax.
1026 Ryan PJ, Hilton MF, Boldy DA, et al. (1995). Validation of British Thoracic Society guidelines for the diagnosis of the sleep apnoea/hypopnoea syndrome: can polysomnography be avoided?. Thorax.
1027 Saarelainen S, Lahtela J, Kallonen E. (1997). Effect of nasal CPAP treatment on insulin sensitivity and plasma leptin. J Sleep Res.
1028 Sadeghniiat Haghighi K, Montazeri A, Khajeh Mehrizi A, et al. (2013). The Epworth Sleepiness Scale: translation and validation study of the Iranian version. Sleep Breath.
1029 Sagaspe P, Leger D, Taillard J, et al. (2010). Might the Berlin Sleep Questionnaire applied to bed partners be used to screen sleep apneic patients?. Sleep Med.
1030 Sahlman J, Seppa J, Herder C, et al. (2012). Effect of weight loss on inflammation in patients with mild obstructive sleep apnea. Nutr Metab Cardiovasc Dis.
1031 Sahlman J, Seppa J, Peltonen M, et al. (2009). Surgical intervention represents a feasible option for patients with mild obstructive sleep apnoea. Acta Otolaryngol.
1032 Sahlman J, Seppa J, Tuomilehto H. (2010). Effect of weight loss on inflammatory markers in overweight patients with mild obstructive sleep apnoea. J Sleep Res.
1033 Saint Martin M, Sforza E, Roche F, et al. (2015). Sleep breathing disorders and cognitive function in the elderly: an 8-year follow-up study. the proof-synapse cohort. Sleep.
1034 Saleh ABM, Ahmad MA, Awadalla NJ. (2011). Development of Arabic version of Berlin questionnaire to identify obstructive sleep apnea at risk patients. Ann Thorac Med.
1035 Salisbury JI, Sun Y. (2007). Rapid screening test for sleep apnea using a nonlinear and nonstationary signal processing technique. Med Eng Phys.
1036 Salord N, Mayos M, Fortuna AM, et al. (2013). Effect of continuous positive airway pressure therapy on metabolic control in patients with morbid obesity and obstructive sleep apnoea. European Respiratory Society Annual Congress, 2013 Sept 7-11, Barcelona, Spain.
1037 Sanders MH, Martin RJ, Pennock BE, et al. (1981). The detection of sleep apnea in the awake patient. The ‘saw-tooth’ sign. JAMA.
1038 Sangal RB. (2012). Evaluating sleepiness-related daytime function by querying wakefulness inability and fatigue: Sleepiness-Wakefulness Inability and Fatigue Test (SWIFT). J Clin Sleep Med.
1039 Sanna A. (2013). Obstructive sleep apnoea, motor vehicle accidents, and work performance. Chron Respir Dis.
1040 Sanner BM, Fluerenbrock N, Kleiber-Imbeck A, et al. (2001). Effect of continuous positive airway pressure therapy on infectious complications in patients with obstructive sleep apnea syndrome. Respiration.
1041 Sanner BM, Klewer J, Trumm A, et al. (2000). Long-term treatment with continuous positive airway pressure improves quality of life in obstructive sleep apnoea syndrome. Eur Respir J.
1042 Sanner BM, Kollhosser P, Buechner N, et al. (2004). Influence of treatment on leptin levels in patients with obstructive sleep apnoea. Eur Respir J.
1043 Santaolalla Montoya F, Iriondo Bedialauneta JR, Aguirre Larracoechea U, et al. (2007). The predictive value of clinical and epidemiological parameters in the identification of patients with obstructive sleep apnoea (OSA): a clinical prediction algorithm in the evaluation of OSA. Eur Arch Otorhinolaryngol.
1044 Santos-Silva R, Sartori DE, Truksinas V, et al. (2009). Validation of a portable monitoring system for the diagnosis of obstructive sleep apnea syndrome. Sleep.
1045 Sareli AE, Cantor CR, Williams NN, et al. (2011). Obstructive sleep apnea in patients undergoing bariatric surgery - A tertiary center experience. Obes Surg.
1046 Sarkhosh K, Switzer NJ, El-Hadi M, et al. (2013). The impact of bariatric surgery on obstructive sleep apnea: a systematic review. Obes Surg.
1047 Saunamaki T, Himanen SL, Polo O, et al. (2010). Executive dysfunction and learning effect after continuous positive airway pressure treatment in patients with obstructive sleep apnea syndrome. Eur Neurol.
1048 Scarlata S, Pedone C, Curcio G, et al. (2013). Pre-polysomnographic assessment using the Pittsburgh Sleep Quality Index questionnaire is not useful in identifying people at higher risk for obstructive sleep apnea. J Med Screen.
1049 Schafer H, Ewig S, Hasper E, et al. (1997). Predictive diagnostic value of clinical assessment and nonlaboratory monitoring system recordings in patients with symptoms suggestive of obstructive sleep apnea syndrome. Respiration.
1050 Schafer H, Pauleit D, Sudhop T, et al. (2002). Body fat distribution, serum leptin, and cardiovascular risk factors in men with obstructive sleep apnea. Chest.
1051 Scharf SM, Garshick E, Brown R, et al. (1990). Screening for subclinical sleep-disordered breathing. Sleep.
1052 Schellenberg JB, Maislin G, Schwab RJ. (2000). Physical findings and the risk for obstructive sleep apnea. The importance of oropharyngeal structures. Am J Respir Crit Care Med.
1053 Scheuller M, Weider D. (2001). Bariatric surgery for treatment of sleep apnea syndrome in 15 morbidly obese patients: long-term results. Otolaryngol Head Neck Surg.
1054 Schiza SE, Bouloukaki I, Mermigkis C, et al. (2011). Utility of formulas predicting the optimal nasal continuous positive airway pressure in a Greek population. Sleep Breath.
1055 Schiza SE, Mermigkis C, Bouloukaki I. (2014). The effect of weight loss on obstructive sleep apnea (OSA) severity and position dependence in the bariatric population. Sleep Breath.
1056 Schiza SE, Mermigkis C, Panagiotis P, et al. (2010). C-reactive protein evolution in obstructive sleep apnoea patients under CPAP therapy. Eur J Clin Invest.
1057 Schmittendorf E, Schultheib B, Bohning N. (2011). Analysis of nocturnal pulse oximetry in sleep medicine. Biomed Tech (Berl).
1058 Schulz R, Flototto C, Jahn A, et al. (2006). Circulating adrenomedullin in obstructive sleep apnoea. J Sleep Res.
1059 Scott AS, Baltzan MA, Wolkove N. (2014). Examination of pulse oximetry tracings to detect obstructive sleep apnea in patients with advanced chronic obstructive pulmonary disease. Can Respir J.
1060 Seicean S, Strohl KP, Seicean A, et al. (2013). Sleep disordered breathing as a risk of cardiac events in subjects with diabetes mellitus and normal exercise echocardiographic findings. Am J Cardiol.
1061 Sengul YS, Ozalevli S, Oztura I, et al. (2011). The effect of exercise on obstructive sleep apnea: a randomized and controlled trial. Sleep Breath.
1062 Series F, Marc I, Cormier Y, et al. (1993). Utility of nocturnal home oximetry for case finding in patients with suspected sleep apnea hypopnea syndrome. Ann Intern Med.
1063 Sert Kuniyoshi FH, Zellmer MR, Calvin AD, et al. (2011). Diagnostic accuracy of the Berlin Questionnaire in detecting sleep-disordered breathing in patients with a recent myocardial infarction. Chest.
1064 Sert-Kuniyoshi FH, Squires RW, Korenfeld YK, et al. (2011). Screening for obstructive sleep apnea in early outpatient cardiac rehabilitation: feasibility and results. Sleep Med.
1065 Servantes DM, Pelcerman A, Salvetti XM, et al. (2012). Effects of home-based exercise training for patients with chronic heart failure and sleep apnoea: a randomized comparison of two different programmes. Clin Rehabil.
1066 Sforza E, Addati G, Cirignotta F, et al. (1994). Natural evolution of sleep apnoea syndrome: a five year longitudinal study. Eur Respir J.
1067 Sforza E, Chouchou F, Pichot V, et al. (2011). Is the Berlin questionnaire a useful tool to diagnose obstructive sleep apnea in the elderly?. Sleep Med.
1068 Sforza E, Gauthier M, Crawford-Achour E, et al. (2012). A 3-year longitudinal study of sleep disordered breathing in the elderly. Eur Respir J.
1069 Shada AL, Hallowell PT, Schirmer BD, et al. (2013). Aerobic exercise is associated with improved weight loss after laparoscopic adjustable gastric banding. Obes Surg.
1070 Shah N, Redline S, Yaggi HK, et al. (2013). Obstructive sleep apnea and acute myocardial infarction severity: ischemic preconditioning?. Sleep Breath.
1071 Shah NA, Yaggi HK, Concato J, et al. (2010). Obstructive sleep apnea as a risk factor for coronary events or cardiovascular death. Sleep Breath.
1072 Shah RV, Abbasi SA, Heydari B, et al. (2014). Obesity and sleep apnea are independently associated with adverse left ventricular remodeling and clinical outcome in patients with atrial fibrillation and preserved ventricular function. Am Heart J.
1073 Sharkey KM, Orff HJ, Tosi C, et al. (2013). Subjective sleepiness and daytime functioning in bariatric patients with obstructive sleep apnea. Sleep Breath.
1074 Sharma B, Feinsilver S, Owens RL, et al. (2011). Obstructive airway disease and obstructive sleep apnea: effect of pulmonary function. Lung.
1075 Sharma SK, Agrawal S, Damodaran D, et al. (2011). Effect of continuous positive airway pressure on metabolic syndrome and cardiovascular markers in patients with obstructive sleep apnea in a north indian population. Am J Respir Crit Care Med.
1076 Sharma SK, Agrawal S, Damodaran D, et al. (2011). CPAP for the metabolic syndrome in patients with obstructive sleep apnea. N Engl J Med.
1077 Sharma SK, Malik V, Vasudev C, et al. (2006). Prediction of obstructive sleep apnea in patients presenting to a tertiary care center. Sleep Breath.
1078 Sharma SK, Vasudev C, Sinha S, et al. (2006). Validation of the modified Berlin questionnaire to identify patients at risk for the obstructive sleep apnoea syndrome. Indian J Med Res.
1079 Sharples L, Glover M, Clutterbuck-James A, et al. (2011). TOMADO: crossover randomised controlled Trial of Oral Mandibular Advancement Devices for Obstructive sleep apnoea-hypopnoea (Project record). Health Technology Assessment Database.
1080 Sharples L, Glover M, Clutterbuck-James A, et al. (2014). Clinical effectiveness and cost-effectiveness results from the randomised controlled Trial of Oral Mandibular Advancement Devices for Obstructive sleep apnoea-hypopnoea (TOMADO) and long-term economic analysis of oral devices and continuous positive airway pressure. Health Technol Assess.
1081 Shechter A, St-Onge M, Kuna ST, et al. (2014). Sleep architecture following a weight loss intervention in overweight and obese patients with obstructive sleep apnea and type 2 diabetes: Relationship to apnea-hypopnea index. Sleep.
1082 Shechter A, St-Onge MP, Kuna ST, et al. (2014). Sleep architecture following a weight loss intervention in overweight and obese patients with obstructive sleep apnea and type 2 diabetes: relationship to apnea-hypopnea index. J Clin Sleep Med.
1083 Shin JH, Chee YJ, Jeong DU, et al. (2010). Nonconstrained sleep monitoring system and algorithms using air-mattress with balancing tube method. IEEE Trans Inf Technol Biomed.
1084 Shin S, Lee HJ, Kim JH, et al. (2012). Polysomnography in the diagnosis of sleep-related breathing disorders. Health Technology Assessment Database.
1085 Shizuku H, Hori Y, Uemura T, et al. (2008). Combination of Bernouilli effect producing maneuver-induced pharyngeal narrowing rate with body mass index as predictive tool for obstructive sleep apnea syndrome. Acta Otolaryngol.
1086 Shneerson J, Wright John J. (2001). Lifestyle modification for obstructive sleep apnoea. Cochrane Database of Systematic Reviews.
1087 Shochat T, Hadas N, Kerkhofs M, et al. (2002). The SleepStrip: an apnoea screener for the early detection of sleep apnoea syndrome. Eur Respir J.
1088 Shpirer I, Elizur A, Shorer R, et al. (2012). Hypoxemia correlates with attentional dysfunction in patients with obstructive sleep apnea. Sleep Breath.
1089 Silecchia G, Boru C, Pecchia A, et al. (2006). Effectiveness of laparoscopic sleeve gastrectomy (first stage of biliopancreatic diversion with duodenal switch) on co-morbidities in super-obese high-risk patients. Obes Surg.
1090 Silva GE, An MW, Goodwin JL, et al. (2009). Longitudinal evaluation of sleep-disordered breathing and sleep symptoms with change in quality of life: the Sleep Heart Health Study (SHHS). Sleep.
1091 Silva GE, Vana KD, Goodwin JL, et al. (2011). Identification of patients with sleep disordered breathing: comparing the four-variable screening tool, STOP, STOP-Bang, and Epworth Sleepiness Scales. J Clin Sleep Med.
1092 Silva RS, Figueiredo AC, Mady C, et al. (2008). Breathing disorders in congestive heart failure: gender, etiology and mortality. Braz J Med Biol Res.
1093 Simpson L, Hillman DR, Cooper MN, et al. (2013). High prevalence of undiagnosed obstructive sleep apnoea in the general population and methods for screening for representative controls. Sleep Breath.
1094 Simpson L, Mukherjee S, Cooper MN, et al. (2010). Sex differences in the association of regional fat distribution with the severity of obstructive sleep apnea. Sleep.
1095 Simpson PJ, Hoyos CM, Celermajer D, et al. (2012). Continuous positive airway pressure does not improve circulating progenitor cell counts or endothelial function in obstructive sleep apnea: A randomised sham-controlled study. Circulation.
1096 Simpson PJL, Hoyos CM, Celermajer D, et al. (2013). Effects of continuous positive airway pressure on endothelial function and circulating progenitor cells in obstructive sleep apnoea: A randomised sham-controlled study. Int J Cardiol.
1097 Sin DD, Fitzgerald F, Parker JD, et al. (1999). Risk factors for central and obstructive sleep apnea in 450 men and women with congestive heart failure. Am J Respir Crit Care Med.
1098 Singh A, Al-Reefy H, Hewitt R, et al. (2008). Evaluation of ApneaGraph in the diagnosis of sleep-related breathing disorders. Eur Arch Otorhinolaryngol.
1099 Singh M, Liao P, Kobah S, et al. (2013). Proportion of surgical patients with undiagnosed obstructive sleep apnoea. Br J Anaesth.
1100 Sivalingam M, Chakravorty I, Mouatt S, et al. (2013). Obstructive sleep apnea in incremental hemodialysis: determinants, consequences, and impact on survival. Hemodial Int.
1101 Sivam S, Phillips CL, Trenell MI, et al. (2012). Effects of 8 weeks of continuous positive airway pressure on abdominal adiposity in obstructive sleep apnoea. Eur Respir J.
1102 Sivam S, Witting P, Hoyos C, et al. (2014). Effects of 8 weeks of CPAP on lipid-based oxidative markers in obstructive sleep apnoea: A randomised trial. Obes Rev.
1103 Sivam S, Witting PK, Hoyos CM, et al. (2015). Effects of 8 weeks of CPAP on lipid-based oxidative markers in obstructive sleep apnea: a randomized trial. J Sleep Res.
1104 Sjosten N, Vahtera J, Salo P, et al. (2009). Increased risk of lost workdays prior to the diagnosis of sleep apnea. Chest.
1105 Skinner MA, Kingshott RN, Filsell S, et al. (2008). Efficacy of the ‘tennis ball technique’ versus nCPAP in the management of position-dependent obstructive sleep apnoea syndrome. Respirology (Carlton, Vic.).
1106 Skomro RP, Gjevre J, Reid J, et al. (2010). Outcomes of home-based diagnosis and treatment of obstructive sleep apnea. Chest.
1107 Smith LA, Chong DW, Vennelle M, et al. (2007). Diagnosis of sleep-disordered breathing in patients with chronic heart failure: evaluation of a portable limited sleep study system. J Sleep Res.
1108 Smith LA, Vennelle M, Gardner RS, et al. (2006). Auto-titrating continuous positive airway pressure in patients with obstructive sleep apnoea and chronic heart failure: a randomised placebo controlled trial. Scott Med J.
1109 Smith R, Ronald J, Delaive K, et al. (2002). What are obstructive sleep apnea patients being treated for prior to this diagnosis?. Chest.
1110 Smith SS, Oei TP, Douglas JA, et al. (2008). Confirmatory factor analysis of the Epworth Sleepiness Scale (ESS) in patients with obstructive sleep apnoea. Sleep Med.
1111 Soares MC, de Azeredo Bittencourt LR, Zonato AI, et al. (2006). Application of the Kushida morphometric model in patients with sleep-disordered breathing. Braz J Otorhinolaryngol.
1112 Sommermeyer D, Zou D, Grote L, et al. (2012). Detection of sleep disordered breathing and its central/obstructive character using nasal cannula and finger pulse oximeter. J Clin Sleep Med.
1113 Song Y, Blackwell T, Yaffe K, et al. (2015). Relationships between sleep stages and changes in cognitive function in older men: the MrOS Sleep Study. Sleep.
1114 Sonsuwan N, Suchachaisri S, Chaloeykitti L. (2011). The relationships between cephalometric parameters and severity of obstructive sleep apnea. Auris Nasus Larynx.
1115 Sookoian S, Pirola CJ. (2013). Obstructive sleep apnea is associated with fatty liver and abnormal liver enzymes: a meta-analysis. Obes Surg.
1116 Spicuzza L, Bernardi L, Balsamo R, et al. (2006). Effect of treatment with nasal continuous positive airway pressure on ventilatory response to hypoxia and hypercapnia in patients with sleep apnea syndrome. Chest.
1117 Spiegel EP, Krahe JA. Sleep disordered breathing: orthodontics and sleep disorders dentistry. Funct Orthod.
1118 Spira AP, Stone KL, Rebok GW, et al. (2014). Sleep-disordered breathing and functional decline in older women. J Am Geriatr Soc.
1119 Steier J, Jolley CJ, Seymour J, et al. (2011). Screening for sleep-disordered breathing in neuromuscular disease using a questionnaire for symptoms associated with diaphragm paralysis. Eur Respir J.
1120 Steinshamn S, Nes B, Tjonna AE, et al. (2014). Aerobic interval exercise training improves apnea-hypopnea index in obstructive sleep apnea patients. Eur Respir J.
1121 Steward DL, Huntley TC, Woodson BT, et al. (2008). Palate implants for obstructive sleep apnea: multi-institution, randomized, placebo-controlled study. Otolaryngology--head and neck surgery.
1122 Stockx EM, Camilleri P, Skuza EM, et al. (2010). New acoustic method for detecting upper airway obstruction in patients with sleep apnoea. Respirology.
1123 Stoohs R, Guilleminault C. (1992). MESAM 4: an ambulatory device for the detection of patients at risk for obstructive sleep apnea syndrome (OSAS). Chest.
1124 Stoohs RA, Facchini FS, Philip P, et al. (1993). Selected cardiovascular risk factors in patients with obstructive sleep apnea: effect of nasal continuous positive airway pressure (n-CPAP). Sleep.
1125 Stoohs RA, Guilleminault C, Dement WC. (1993). Sleep apnea and hypertension in commercial truck drivers. Sleep.
1126 Stoohs RA, Guilleminault C, Itoi A, et al. (1994). Traffic accidents in commercial long-haul truck drivers: the influence of sleep-disordered breathing and obesity. Sleep.
1127 Stradling J, Roberts D, Wilson A, et al. (1997). Controlled trial of hypnotherapy for weight loss in patients with obstructive sleep apnoea (OSA). Thorax.
1128 Stradling J, Roberts D, Wilson A, et al. (1998). Controlled trial of hypnotherapy for weight loss in patients with obstructive sleep apnoea. International journal of obesity and related metabolic disorders : journal of the International Association for the Study of Obesity.
1129 Stradling JR, Craig SE, Kohler M, et al. (2015). Markers of inflammation: data from the MOSAIC randomised trial of CPAP for minimally symptomatic OSA. Thorax.
1130 Stradling JR, Crosby JH. (1991). Predictors and prevalence of obstructive sleep apnoea and snoring in 1001 middle aged men. Thorax.
1131 Stradling JR, Davies RJ. (2000). Is more NCPAP better?. Sleep.
1132 Stroh C, Groh C, Weiner R, et al. (2013). Are there gender-specific aspects of gastric banding? Data analysis from the quality assurance study of the surgical treatment of obesity in Germany. Obes Surg.
1133 Su CT, Chen KH, Chen LF, et al. (2012). Prediagnosis of obstructive sleep apnea via multiclass MTS. Comput Math Methods Med.
1134 Su MC, Chen YC, Huang KT, et al. (2013). Association of metabolic factors with high-sensitivity C-reactive protein in patients with sleep-disordered breathing. Eur Arch Otorhinolaryngol.
1135 Su S, Baroody FM, Kohrman M, et al. (2004). A comparison of polysomnography and a portable home sleep study in the diagnosis of obstructive sleep apnea syndrome. Otolaryngol Head Neck Surg.
1136 Su VY, Liu CJ, Wang HK, et al. (2014). Sleep apnea and risk of pneumonia: a nationwide population-based study. CMAJ.
1137 Subramanian S, Hesselbacher SE, Aguilar R, et al. (2011). The NAMES assessment: a novel combined-modality screening tool for obstructive sleep apnea. Sleep Breath.
1138 Suksakorn S, Rattanaumpawan P, Banhiran W, et al. (2014). Reliability and validity of a Thai version of the Berlin questionnaire in patients with sleep disordered breathing. J Med Assoc Thai.
1139 Sullivan CE, Issa FG. (1980). Pathophysiological mechanisms in obstructive sleep apnea. Sleep.
1140 Sullivan DR, Lai N, Phillips C, et al. (2011). Post-prandial lipidemia is reduced by treatment of obstructive sleep apnoea: A randomised, placebo controlled trial of continuous positive airway pressure. Atherosclerosis Supplements.
1141 Sumi K, Tsuboi T, Yamashita M, et al. (2014). How many times should overnight pulse-oximetry be undergone to screen obstructive sleep apnea syndrome?. Eur Respir J.
1142 Sun H, Shi J, Li M, et al. (2013). Impact of continuous positive airway pressure treatment on left ventricular ejection fraction in patients with obstructive sleep apnea: a meta-analysis of randomized controlled trials. PLoS One.
1143 Sun LM, Chiu HW, Chuang CY, et al. (2011). A prediction model based on an artificial intelligence system for moderate to severe obstructive sleep apnea. Sleep Breath.
1144 Sundaram S, Lim J, Lasserson Toby J. (2005). Surgery for obstructive sleep apnoea in adults. Cochrane Database of Systematic Reviews.
1145 Suzuki T, Kameyama K, Inoko Y, et al. (2010). Development of a sleep apnea event detection method using photoplethysmography. Conf Proc IEEE Eng Med Biol Soc.
1146 Svendsen M, Blomhoff R, Holme I, et al. (2007). The effect of an increased intake of vegetables and fruit on weight loss, blood pressure and antioxidant defense in subjects with sleep related breathing disorders. Eur J Clin Nutr.
1147 Szymanski FM, Filipiak KJ, Hrynkiewicz-Szymanska A, et al. (2013). Clinical characteristics of patients with acute coronary syndrome at high clinical suspicion for obstructive sleep apnea syndrome. Hellenic J Cardiol.
1148 Szyszko A, Franceschini C, Gonzalez-Zuelgaray J. (2009). Reliability of a Holter-based methodology for evaluation of sleep apnoea syndrome. Europace.
1149 Tada T, Kusano KF, Ogawa A, et al. (2007). The predictors of central and obstructive sleep apnoea in haemodialysis patients. Nephrol Dial Transplant.
1150 Tagluk ME, Sezgin N. (2010). Classification of sleep apnea through sub-band energy of abdominal effort signal using Wavelets + Neural Networks. J Med Syst.
1151 Takaesu Y, Inoue Y, Komada Y, et al. (2012). Effects of nasal continuous positive airway pressure on panic disorder comorbid with obstructive sleep apnea syndrome. Sleep Med.
1152 Takama N, Kurabayashi M. (2010). Effectiveness of a portable device and the need for treatment of mild-to-moderate obstructive sleep-disordered breathing in patients with cardiovascular disease. J Cardiol.
1153 Takeda T, Nishimura Y, Satouchi M, et al. (2006). Usefulness of the oximetry test for the diagnosis of sleep apnea syndrome in Japan. Am J Med Sci.
1154 Takegami M, Hayashino Y, Chin K, et al. (2009). Simple four-variable screening tool for identification of patients with sleep-disordered breathing. Sleep.
1155 Takegami M, Suzukamo Y, Wakita T, et al. (2009). Development of a Japanese version of the Epworth Sleepiness Scale (JESS) based on item response theory. Sleep Med.
1156 Tami TA, Duncan HJ, Pfleger M. (1998). Identification of obstructive sleep apnea in patients who snore. Laryngoscope.
1157 Tan A, Cheung YY, Yin J, et al. (2016). Predicting obstructive sleep apnea using STOP-Bang Questionnaire in the general population. Respiratory and Critical Care Medicine, Abstract Issue. American Thoracic Society.
1158 Tan X, Saarinen A, Mikkola TM, et al. (2013). Effects of exercise and diet interventions on obesity-related sleep disorders in men: study protocol for a randomized controlled trial. Trials.
1159 Tandeter H. (2009). Obstructive sleep apnea: a puzzle built in retrospect. Can Fam Physician.
1160 Tang RB, Dong JZ, Liu XP, et al. (2009). Obstructive sleep apnoea risk profile and the risk of recurrence of atrial fibrillation after catheter ablation. Europace.
1161 Tang SC, Lam B, Yao TJ, et al. (2010). Sleep apnea is a novel risk predictor of cardiovascular morbidity and death in patients receiving peritoneal dialysis. Kidney Int.
1162 Tangugsorn V, Krogstad O, Espeland L, et al. (2000). Obstructive sleep apnea (OSA): a cephalometric analysis of severe and non-severe OSA patients. Part II: A predictive discriminant function analysis. Int J Adult Orthodon Orthognath Surg.
1163 Tantrakul V, Guilleminault C. (2009). Chronic sleep complaints in premenopausal women and their association with sleep-disordered breathing. Lung.
1164 Tasker C, Crosby JH, Stradling JR. (2002). Evidence for persistence of upper airway narrowing during sleep, 12 years after adenotonsillectomy. Arch Dis Child.
1165 Tedeschi E, Carratu P, Damiani MF, et al. (2013). Home unattended portable monitoring and automatic CPAP titration in patients with high risk for moderate to severe obstructive sleep apnea. Respir Care.
1166 Teferra RA, Grant BJ, Mindel JW, et al. (2014). Cost minimization using an artificial neural network sleep apnea prediction tool for sleep studies. Ann Am Thorac Soc.
1167 Teixeira AOB, Abi-Ramia LBP, Almeida MAO. (2013). Treatment of obstructive sleep apnea with oral appliances. Prog Orthod.
1168 Telakivi T, Kajaste S, Partinen M, et al. (1993). Cognitive function in obstructive sleep apnea. Sleep.
1169 Telakivi T, Kajaste S, Partinen M, et al. (1988). Cognitive function in middle-aged snorers and controls: role of excessive daytime somnolence and sleep-related hypoxic events. Sleep.
1170 Tenhunen M, Elomaa E, Sistonen H, et al. (2013). Emfit movement sensor in evaluating nocturnal breathing. Respir Physiol Neurobiol.
1171 Teodorescu M, Barnet JH, Hagen EW, et al. (2015). Association between asthma and risk of developing obstructive sleep apnea. JAMA.
1172 Teramoto S, Yamaguchi Y, Yamamoto H, et al. (2008). Cardiovascular and metabolic effects of CPAP in obese obstructive sleep apnoea patients. The European respiratory journal.
1173 Terris DJ. (2001). Prospective, randomized trial of surgery for sleep-disordered breathing. Otolaryngology - Head and Neck Surgery.
1174 Teschler H, Berthon-Jones M, Wessendorf T, et al. (1996). Influence of moderate alcohol consumption on obstructive sleep apnoea with and without AutoSet nasal CPAP therapy. Eur Respir J.
1175 Thulesius HL, Thulesius HO, Jessen M. (2004). Pharyngometric correlations with obstructive sleep apnea syndrome. Acta Otolaryngol.
1176 Thurtell MJ, Bruce BB, Rye DB, et al. (2011). The Berlin questionnaire screens for obstructive sleep apnea in idiopathic intracranial hypertension. J Neuroophthalmol.
1177 Thurtell MJ, Trotti LM, Bixler EO, et al. (2013). Obstructive sleep apnea in idiopathic intracranial hypertension: comparison with matched population data. J Neurol.
1178 Ting H, Huang RJ, Lai CH, et al. (2014). Evaluation of candidate measures for home-based screening of sleep disordered breathing in Taiwanese bus drivers. Sensors (Basel).
1179 Ting H, Mai YT, Hsu HC, et al. (2014). Decision tree based diagnostic system for moderate to severe obstructive sleep apnea. J Med Syst.
1180 Tippu Z, Pengo M, Kosky C, et al. (2014). Comparison of the polysomnographic apnoea-hypopnea-index with the oxygen desaturation index in patients with obstructive sleep apnoea. Eur Respir J.
1181 Tishler PV, Larkin EK, Schluchter MD, et al. (2003). Incidence of sleep-disordered breathing in an urban adult population: the relative importance of risk factors in the development of sleep-disordered breathing. JAMA.
1182 Tkacova R, McNicholas WT, Javorsky M, et al. (2014). Nocturnal intermittent hypoxia predicts prevalent hypertension in the European Sleep Apnoea Database cohort study. Eur Respir J.
1183 To KW, Chan WC, Chan TO, et al. (2012). Comparison of empirical continuous positive airway pressure (CPAP) treatment versus initial portable sleep monitoring followed by CPAP treatment for patients with suspected obstructive sleep apnoea. Intern Med J.
1184 To KW, Chan WC, Chan TO, et al. (2009). Validation study of a portable monitoring device for identifying OSA in a symptomatic patient population. Respirology.
1185 Tonelli de Oliveira AC, Martinez D, Vasconcelos LF, et al. (2009). Diagnosis of obstructive sleep apnea syndrome and its outcomes with home portable monitoring. Chest.
1186 Toraldo DM, De Nuccio F, Nicolardi G. (2010). Fixed-pressure nCPAP in patients with obstructive sleep apnea (OSA) syndrome and chronic obstructive pulmonary disease (COPD): a 24-month follow-up study. Sleep Breath.
1187 Tregear S, Reston J, Schoelles K, et al. (2010). Continuous positive airway pressure reduces risk of motor vehicle crash among drivers with obstructive sleep apnea: systematic review and meta-analysis. Sleep.
1188 Tregear S, Reston J, Schoelles K, et al. (2010). Continuous positive airway pressure reduces risk of motor vehicle crash among drivers with obstructive sleep apnea: systematic review and meta-analysis. Sleep.
1189 Trikalinos TA, Ip S, Raman G, et al. (2007). Home Diagnosis of Obstructive Sleep Apnea-Hypopnea Syndrome.
1190 Troell R, Powell N, Riley R. (1998). Hypopharyngeal airway surgery for obstructive sleep apnea syndrome. Seminars in Respiratory Critical Care Medicine.
1191 Trombetta IC, Somers VK, Maki-Nunes C, et al. (2010). Consequences of comorbid sleep apnea in the metabolic syndrome--implications for cardiovascular risk. Sleep.
1192 Troussiere AC, Charley CM, Salleron J, et al. (2014). Treatment of sleep apnoea syndrome decreases cognitive decline in patients with Alzheimer's disease. J Neurol Neurosurg Psychiatry.
1193 Tsai WH, Remmers JE, Brant R, et al. (2003). A decision rule for diagnostic testing in obstructive sleep apnea. Am J Respir Crit Care Med.
1194 Tsara V, Serasli E, Amfilochiou A, et al. (2004). Greek version of the Epworth Sleepiness Scale. Sleep Breath.
1195 Tsukahara M, Sakao S, Jujo T, et al. (2014). The accuracy and uncertainty of a sheet-type portable monitor as a screening device to identify obstructive sleep apnea-hypopnea syndrome. Intern Med.
1196 Tun Y, Hida W, Okabe S, et al. (2003). Can nasal continuous positive airway pressure decrease clinic blood pressure in patients with obstructive sleep apnea?. Tohoku J Exp Med.
1197 Tuomilehto H, Seppa J, Uusitupa M, et al. (2014). The impact of weight reduction in the prevention of the progression of obstructive sleep apnea: an explanatory analysis of a 5-year observational follow-up trial. Sleep Med.
1198 Tuomilehto H, Uusitupa M, Seppa J. (2012). Sustained improvement in mild obstructive sleep apnoea by lifestyle intervention-post-interventional follow-up of a randomised, controlled trial (5-year follow-up upcoming). Journal of Sleep Research.
1199 Tuomilehto HPI. (2012). Initial improvements in apnoea-hypopnoea index after very low calorie diet maintained for 1 year with weight loss maintenance program. Evid Based Med.
1200 Turkington PM, Sircar M, Saralaya D, et al. (2004). Time course of changes in driving simulator performance with and without treatment in patients with sleep apnoea hypopnoea syndrome. Thorax.
1201 Turnbull F, Blood Pressure Lowering Treatment Trialists Collaboration. (2003). Effects of different blood-pressure-lowering regimens on major cardiovascular events: results of prospectively-designed overviews of randomised trials. Lancet.
1202 Ucok K, Aycicek A, Sezer M, et al. (2011). Resting metabolic rate and anthropometric measurements in male sleep apnea patients. Intern Med.
1203 Ueno K, Kasai T, Brewer G, et al. (2010). Evaluation of the apnea-hypopnea index determined by the S8 auto-CPAP, a continuous positive airway pressure device, in patients with obstructive sleep apnea-hypopnea syndrome. J Clin Sleep Med.
1204 Ugur KS, Ark N, Kurtaran H, et al. (2011). Comparison of scores of application methods of the Epworth Sleepiness Scale: self administered or nurse administered. ORL J Otorhinolaryngol Relat Spec.
1205 Ulasli SS, Gunay E, Koyuncu T, et al. (2014). Predictive value of Berlin Questionnaire and Epworth Sleepiness Scale for obstructive sleep apnea in a sleep clinic population. Clin Respir J.
1206 Ulfberg J, Carter N, Talback M, et al. (1996). Excessive daytime sleepiness at work and subjective work performance in the general population and among heavy snorers and patients with obstructive sleep apnea. Chest.
1207 Unal M, Ozturk L, Kanik A. (2002). The role of oxygen saturation measurement and body mass index in distinguishing between non-apnoeic snorers and patients with obstructive sleep apnoea syndrome. Clin Otolaryngol Allied Sci.
1208 Utriainen KT, Airaksinen JK, Polo O, et al. (2014). Sleep apnoea is associated with major cardiac events in peripheral arterial disease. Eur Respir J.
1209 Vaessen TJ, Overeem S, Sitskoorn MM. (2015). Cognitive complaints in obstructive sleep apnea. Sleep Med Rev.
1210 Vaidya AM, Petruzzelli GJ, Walker RP, et al. (1996). Identifying obstructive sleep apnea in patients presenting for laser-assisted uvulopalatoplasty. Laryngoscope.
1211 Vakulin A, Catcheside P, Baulk S, et al. (2011). Driving simulator performance deficits in OSA patients distinguished by auditory reaction time lapses and cortical evoked potentials but not OSA severity or sleepiness. Journal of Sleep Research.
1212 Valbuza JS, de Oliveira MM, Conti CF, et al. (2011). Oropharyngeal examination as a predictor of obstructive sleep apnea: pilot study of gag reflex and palatal reflex. Arq Neuropsiquiatr.
1213 Valenza MC, Baranchuk A, Valenza-Demet G, et al. (2014). Prevalence of risk factors for atrial fibrillation and stroke among 1210 patients with sleep disordered breathing. Int J Cardiol.
1214 van Knippenberg FC, Passchier J, Heysteck D, et al. (1995). The Rotterdam Daytime Sleepiness Scale: a new daytime sleepiness scale. Psychol Rep.
1215 Van Meerhaeghe A, Delpire P, Stenuit P, et al. (2004). Operating characteristics of the negative expiratory pressure technique in predicting obstructive sleep apnoea syndrome in snoring patients. Thorax.
1216 Van Surell C, Lemaigre D, Leroy M, et al. (1995). Evaluation of an ambulatory device, CID 102, in the diagnosis of obstructive sleep apnoea syndrome. Eur Respir J.
1217 Vana KD, Silva GE, Goldberg R. (2013). Predictive abilities of the STOP-Bang and Epworth Sleepiness Scale in identifying sleep clinic patients at high risk for obstructive sleep apnea. Res Nurs Health.
1218 Varghese B. (2011). Identification of risk for obstructive sleep apnea by Berlin Questionnaire. Research Journal of Pharmaceutical, Biological and Chemical Sciences.
1219 Vasquez M, Goodwin J, Drescher A, et al. (2007). Associations of dietary intake and physical activity with sleep disordered breathing. Sleep.
1220 Vaz AP, Drummond M, Mota PC, et al. (2011). Translation of Berlin Questionnaire to Portuguese language and its application in OSA identification in a sleep disordered breathing clinic. Rev Port Pneumol.
1221 Vazir A, Hastings PC, Papaioannou I, et al. (2008). Variation in severity and type of sleep-disordered breathing throughout 4 nights in patients with heart failure. Respir Med.
1222 Vazquez JC, Tsai WH, Flemons WW, et al. (2000). Automated analysis of digital oximetry in the diagnosis of obstructive sleep apnoea. Thorax.
1223 Verbraecken J. (2011). Clinical implications of residual sleep apnoea after chronic CPAP therapy. Breathe.
1224 Verbraecken J, Willemen M, De Cock W, et al. (2000). Influence of longterm CPAP therapy on CO(2) drive in patients with obstructive sleep apnea. Respir Physiol.
1225 Verse T, Hormann K. (2011). The surgical treatment of sleep-related upper airway obstruction. Dtsch Arztebl Int.
1226 Verse T, Pirsig W, Junge-Hulsing B, et al. (2000). Validation of the POLY-MESAM seven-channel ambulatory recording unit. Chest.
1227 Vgontzas AN, Tan TL, Bixler EO, et al. (1994). Sleep apnea and sleep disruption in obese patients. Arch Intern Med.
1228 Vicente E, Marin JM, Carrizo S, et al. (2006). Tongue-base suspension in conjunction with uvulopalatopharyngoplasty for treatment of severe obstructive sleep apnea: long-term follow-up results. Laryngoscope.
1229 Viner S, Szalai JP, Hoffstein V. (1991). Are history and physical examination a good screening test for sleep apnea?. Ann Intern Med.
1230 Vitarelli A, D'Orazio S, Caranci F, et al. (2013). Left ventricular torsion abnormalities in patients with obstructive sleep apnea syndrome: an early sign of subclinical dysfunction. Int J Cardiol.
1231 Vlachantoni IT, Dikaiakou E, Antonopoulos CN, et al. (2013). Effects of continuous positive airway pressure (CPAP) treatment for obstructive sleep apnea in arterial stiffness: a meta-analysis. Sleep Med Rev.
1232 Wachter R, Luthje L, Klemmstein D, et al. (2013). Impact of obstructive sleep apnoea on diastolic function. Eur Respir J.
1233 Walia HK, Li H, Rueschman M, et al. (2014). Association of severe obstructive sleep apnea and elevated blood pressure despite antihypertensive medication use. J Clin Sleep Med.
1234 Walia R, Achilefu A, Crawford S, et al. (2014). Are at-home sleep studies performed using portable monitors (PMs) as effective at diagnosing obstructive sleep apnea (OSA) in adults as sleep laboratory-based polysomnography (PSG)?. J Okla State Med Assoc.
1235 Walker RP, Garrity T, Gopalsami C. (1999). Early polysomnographic findings and long-term subjective results in sleep apnea patients treated with laser-assisted uvulopalatoplasty. Laryngoscope.
1236 Walker-Engstrom ML, Wilhelmsson B, Tegelberg A, et al. (2000). Quality of life assessment of treatment with dental appliance or UPPP in patients with mild to moderate obstructive sleep apnoea. A prospective randomized 1-year follow-up study. J Sleep Res.
1237 Wang CW, Hunter A, Gravill N, et al. (2010). Real time pose recognition of covered human for diagnosis of sleep apnoea. Comput Med Imaging Graph.
1238 Wang PC, Li HY, Shih TS, et al. (2006). Generic and specific quality-of-life measures in Taiwanese adults with sleep-disordered breathing. Otolaryngol Head Neck Surg.
1239 Ward K, Palmer L, Mukherjee S, et al. (2011). Validation of a portable monitoring device for investigation of obstructive sleep apnoea (OSA). Journal of Sleep Research.
1240 Ward NR, Cowie MR, Rosen SD, et al. (2012). Utility of overnight pulse oximetry and heart rate variability analysis to screen for sleep-disordered breathing in chronic heart failure. Thorax.
1241 Watkins MR, Talmage JB, Thiese MS, et al. (2009). Correlation between screening for obstructive sleep apnea using a portable device versus polysomnography testing in a commercial driving population. J Occup Environ Med.
1242 Waxman JA, Graupe D, Carley DW. (2010). Automated prediction of apnea and hypopnea, using a LAMSTAR artificial neural network. Am J Respir Crit Care Med.
1243 Weaver EM, Kapur V, Yueh B. (2004). Polysomnography vs self-reported measures in patients with sleep apnea. Arch Otolaryngol Head Neck Surg.
1244 Weaver EM, Woodson BT, Steward DL. (2005). Polysomnography indexes are discordant with quality of life, symptoms, and reaction times in sleep apnea patients. Otolaryngol Head Neck Surg.
1245 Weihu C, Jingying Y, Demin H, et al. (2011). Relationship of body position, upper airway morphology, and severity of obstructive sleep apnea/hypopnea syndrome among Chinese patients. Acta Otolaryngol.
1246 Weinreich G, Terjung S, Wang Y, et al. (2014). Validation of SleepMinder as screening device for obstructive sleep apnea. [German]. Somnologie.
1247 Weir ID, Ahmed KM, Korbuly S, et al. (2012). Detection of postoperative sleep-disordered breathing using a portable monitoring device. Sleep Breath.
1248 Weitzman ED, Kahn E, Pollak CP. (1980). Quantitative analysis of sleep and sleep apnea before and after tracheostomy in patients with the hypersomnia-sleep apnea syndrome. Sleep.
1249 Wellman A, Eckert DJ, Jordan AS, et al. (2011). A method for measuring and modeling the physiological traits causing obstructive sleep apnea. J Appl Physiol (1985).
1250 West P, George CF, Kryger MH. (1987). Dynamic in vivo response characteristics of three oximeters: Hewlett-Packard 47201A, Biox III, and Nellcor N-100. Sleep.
1251 West SD, Nicoll DJ, Wallace TM, et al. (2006). The effect of CPAP on insulin resistance and HBAIC in people with obstructive sleep apnoea and type 2 diabetes: A randomised controlled trial. Thorax.
1252 West SD, Nicoll DJ, Wallace TM, et al. (2006). Obstructive sleep apnoea in men with type 2 diabetes a double blind randomised controlled trial of the effects of CPAP on HbA1c and insulin resistance. Proc Am Thorac Soc.
1253 Westbrook PR, Levendowski DJ, Cvetinovic M, et al. (2005). Description and validation of the apnea risk evaluation system: a novel method to diagnose sleep apnea-hypopnea in the home. Chest.
1254 Wheaton AG, Perry GS, Chapman DP, et al. (2012). Sleep disordered breathing and depression among U.S. adults: National Health and Nutrition Examination Survey, 2005-2008. Sleep.
1255 White DP, Gibb TJ, Wall JM, et al. (1995). Assessment of accuracy and analysis time of a novel device to monitor sleep and breathing in the home. Sleep.
1256 Whitelaw WA, Brant RF, Flemons WW. (2005). Clinical usefulness of home oximetry compared with polysomnography for assessment of sleep apnea. Am J Respir Crit Care Med.
1257 Whittle AT, Finch SP, Mortimore IL, et al. (1997). Use of home sleep studies for diagnosis of the sleep apnoea/hypopnoea syndrome. Thorax.
1258 Whyte KF, Allen MB, Fitzpatrick MF, et al. (1992). Accuracy and significance of scoring hypopneas. Sleep.
1259 Williams AJ, Yu G, Santiago S, et al. (1991). Screening for sleep apnea using pulse oximetry and a clinical score. Chest.
1260 Wilson G, Terpening Z, Wong K, et al. (2014). Screening for sleep apnoea in mild cognitive impairment: The utility of the multivariable apnoea prediction index. Sleep Disorders.
1261 Wiltshire N, Kendrick AH, Catterall JR. (2001). Home oximetry studies for diagnosis of sleep apnea/hypopnea syndrome: limitation of memory storage capabilities. Chest.
1262 Winslow DH, Bowden CH, DiDonato KP, et al. (2012). A randomized, double-blind, placebo-controlled study of an oral, extended-release formulation of phentermine/topiramate for the treatment of obstructive sleep apnea in obese adults. Sleep.
1263 Won CH, Chun HJ, Chandra SM, et al. (2013). Severe obstructive sleep apnea increases mortality in patients with ischemic heart disease and myocardial injury. Sleep Breath.
1264 Wong KK, Jankelson D, Reid A, et al. (2008). Diagnostic test evaluation of a nasal flow monitor for obstructive sleep apnea detection in sleep apnea research. Behav Res Methods.
1265 Woodson BT, Han JK. (2005). Relationship of snoring and sleepiness as presenting symptoms in a sleep clinic population. Ann Otol Rhinol Laryngol.
1266 Worsnop C, Naughton M, Barter C, et al. (1994). Blood pressure and humoral effects of nasal continuous positive airway pressure (NCPAP) in hypertensives with obstructive sleep apnoea (OSA). Aust N Z J Med.
1267 Worsnop CJ, Miseki S, Rochford PD. (2005). Humidification of CPAP for obstructive sleep apnoea. Eur Respir J.
1268 Worsnop CJ, Miseski S, Rochford PD. (2010). Routine use of humidification with nasal continuous positive airway pressure. Intern Med J.
1269 Worsnop CJ, Pierce RJ, Naughton M. (1993). Systemic hypertension and obstructive sleep apnea. Sleep.
1270 Wu X, Lv S, Yu X, et al. (2015). Treatment of OSA reduces the risk of repeat revascularization after percutaneous coronary intervention. Chest.
1271 Xie B, Minn H. (2012). Real-time sleep apnea detection by classifier combination. IEEE Trans Inf Technol Biomed.
1272 Xu H, Yi H, Guan J, et al. (2014). Effect of continuous positive airway pressure on lipid profile in patients with obstructive sleep apnea syndrome: a meta-analysis of randomized controlled trials. Database of Abstracts of Reviews of Effects.
1273 Xu M, Yang Y, Zhang J. (2013). Levels of neuroglobin in serum and neurocognitive impairments in Chinese patients with obstructive sleep apnea. Sleep Breath.
1274 Yadollahi A, Azarbarzin A, Montazeri A, et al. (2012). Acoustical flow estimation in patients with obstructive sleep apnea during sleep. Conf Proc IEEE Eng Med Biol Soc.
1275 Yagi H, Nakata S, Tsuge H, et al. (2009). Morphological examination of upper airway in obstructive sleep apnea. Auris Nasus Larynx.
1276 Yagi H, Nakata S, Tsuge H, et al. (2009). Significance of a screening device (Apnomonitor 5) for sleep apnea syndrome. Auris Nasus Larynx.
1277 Yalamanchali S, Farajian V, Hamilton C, et al. (2013). Diagnosis of obstructive sleep apnea by peripheral arterial tonometry: meta-analysis. JAMA Otolaryngol Head Neck Surg.
1278 Yamamoto H, Akashiba T, Kosaka N, et al. (2000). Long-term effects nasal continuous positive airway pressure on daytime sleepiness, mood and traffic accidents in patients with obstructive sleep apnoea. Respir Med.
1279 Yamashiro Y, Kryger MH. (1995). Nocturnal oximetry: is it a screening tool for sleep disorders?. Sleep.
1280 Yang D, Liu Z, Yang H. (2012). The impact of effective continuous positive airway pressure on homeostasis model assessment insulin resistance in non-diabetic patients with moderate to severe obstructive sleep apnea. Diabetes Metab Res Rev.
1281 Yang D, Liu Z, Yang H, et al. (2013). Effects of continuous positive airway pressure on glycemic control and insulin resistance in patients with obstructive sleep apnea: a meta-analysis. Sleep and Breathing.
1282 Yang SQ, Han LL, Dong XL, et al. (2012). Mal-effects of obstructive sleep apnea on the heart. Sleep Breath.
1283 Ye H, Li TP, Feng Y, et al. (2009). Effect of CPAP treatment on life quality in patients with obstructive sleep apnea-hypopnea syndrome results of a meta-analysis. Chinese Journal of Evidence-Based Medicine.
1284 Ye L, Pien GW, Ratcliffe SJ, et al. (2014). The different clinical faces of obstructive sleep apnoea: a cluster analysis. Eur Respir J.
1285 Ye L, Pien GW, Ratcliffe SJ, et al. (2009). Gender differences in obstructive sleep apnea and treatment response to continuous positive airway pressure. J Clin Sleep Med.
1286 Yee BJ, Cheung J, Phipps P, et al. (2006). Treatment of obesity hypoventilation syndrome and serum leptin. Respiration.
1287 Yin M, Miyazaki S, Ishikawa K. (2006). Evaluation of type 3 portable monitoring in unattended home setting for suspected sleep apnea: factors that may affect its accuracy. Otolaryngol Head Neck Surg.
1288 Yin M, Miyazaki S, Itasaka Y, et al. (2005). A preliminary study on application of portable monitoring for diagnosis of obstructive sleep apnea. Auris Nasus Larynx.
1289 Yoshihisa A, Owada T, Hoshino Y, et al. (2010). Flow-mediated dilatation identifies impaired endothelial function in patients with sleep apnea syndrome. Fukushima J Med Sci.
1290 Yoshihisa A, Suzuki S, Yamaki T, et al. (2013). Impact of adaptive servo-ventilation on cardiovascular function and prognosis in heart failure patients with preserved left ventricular ejection fraction and sleep-disordered breathing. Eur J Heart Fail.
1291 Yoshihisa A, Suzuki S, Yamauchi H, et al. (2015). Beneficial Effects of Positive Airway Pressure Therapy for Sleep-Disordered Breathing in Heart Failure Patients with Preserved Left Ventricular Ejection Fraction. Clin Cardiol.
1292 Yosunkaya S, Okur HK, Can U, et al. (2015). Impact of continuous positive airway pressure treatment on leptin levels in patients with obstructive sleep apnea syndrome. Metab Syndr Relat Disord.
1293 Young T, Blustein J, Finn L, et al. (1997). Sleep-disordered breathing and motor vehicle accidents in a population-based sample of employed adults. Sleep.
1294 Yu BH, Ancoli-Israel S, Dimsdale JE. (1999). Effect of CPAP treatment on mood states in patients with sleep apnea. J Psychiatr Res.
1295 Yu R, Li W, Huo H, et al. (2011). Short daytime ApneaGraph for initial case selection of obstructive sleep apnea-hypopnea syndrome before surgery. Eur Arch Otorhinolaryngol.
1296 Yuan X, Fang J, Wang L, et al. (2015). Continuous positive airway pressure eliminates increased risk of death of obstructive sleep apnea in Chinese patients. Sleep.
1297 Yuan X, Fang J, Wang L, et al. (2015). Adequate continuous positive airway pressure therapy reduces mortality in Chinese patients with obstructive sleep apnea. Sleep and Breathing.
1298 Yuceege M, Firat H, Demir A, et al. (2013). Reliability of the Watch-PAT 200 in detecting sleep apnea in highway bus drivers. J Clin Sleep Med.
1299 Yuceege M, Firat H, Sever O, et al. (2015). The effect of adding gender item to Berlin Questionnaire in determining obstructive sleep apnea in sleep clinics. Ann Thorac Med.
1300 Zaffaroni A, Kent B, O'Hare E, et al. (2013). Assessment of sleep-disordered breathing using a non-contact bio-motion sensor. J Sleep Res.
1301 Zamarron C, Gude F, Barcala J, et al. (2003). Utility of oxygen saturation and heart rate spectral analysis obtained from pulse oximetric recordings in the diagnosis of sleep apnea syndrome. Chest.
1302 Zamarron C, Hornero R, del Campo F, et al. (2006). Heart rate regularity analysis obtained from pulse oximetric recordings in the diagnosis of obstructive sleep apnea. Sleep Breath.
1303 Zamarron C, Romero PV, Rodriguez JR, et al. (1999). Oximetry spectral analysis in the diagnosis of obstructive sleep apnoea. Clin Sci (Lond).
1304 Zeng J, Gu Y, Ke J, et al. (2014). Lin Chung Er Bi Yan Hou Tou Jing Wai Ke Za Zhi.
1305 Zhang J, Li Y, Cao X, et al. (2014). The combination of anatomy and physiology in predicting the outcomes of velopharyngeal surgery. Laryngoscope.
1306 Zhang P, Ouyang SY, Sun PZ, et al. (2013). Effects of noninvasive positive pressure ventilation on patients with arrhythmia complicated by sleep apnea syndrome. [Chinese]. Chinese Journal of Cardiology.
1307 Zhang X, Zhang T, Zhang X, et al. (2014). Obstructive sleep apnea syndrome: a risk factor for Stanford's type B aortic dissection. Ann Vasc Surg.
1308 Zhao Q, Liu Z, McEvoy D, et al. (2010). Effectiveness of continuous positive airway pressure on blood pressure in patients with obstructive sleep apnoea. Heart.
1309 Zhao Q, Liu ZH, Luo Q, et al. (2012). Effects of continuous positive airway pressure on blood pressure and daytime sleepiness in obstructive sleep apnea patients with coronary heart diseases under optimal medications. Sleep Breath.
1310 Ziegler MG, Mills PJ, Loredo JS, et al. (2001). Effect of continuous positive airway pressure and placebo treatment on sympathetic nervous activity in patients with obstructive sleep apnea. Chest.
1311 Zimmerman ME, Aloia MS. (2012). Sleep-disordered breathing and cognition in older adults. Curr Neurol Neurosci Rep.
1312 Zou D, Grote L, Peker Y, et al. (2006). Validation a portable monitoring device for sleep apnea diagnosis in a population based cohort using synchronized home polysomnography. Sleep.
1313 Zou J, Guan J, Yi H, et al. (2013). An effective model for screening obstructive sleep apnea: a large-scale diagnostic study. PLoS One.
1314 Zucconi M, Ferini-Strambi L, Castronovo V, et al. (1996). An unattended device for sleep-related breathing disorders: validation study in suspected obstructive sleep apnoea syndrome. Eur Respir J.
1315 Zucconi M, Ferini-Strambi L, Palazzi S, et al. (1992). Habitual snoring with and without obstructive sleep apnoea: the importance of cephalometric variables. Thorax.