# Appendix B Detailed Methods

## Appendix B1 Detailed Methods

### Original Search Strategies

PubMed intervention/treatment search, 9/30/2014

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Sleep Apnea Syndromes”[MeSH] OR “Sleep Apnea, Obstructive”[MeSH] OR “Obstructive Sleep Apneas”[tw] OR “Obstructive Sleep Apnea”[tw] OR “Obstructive Sleep Apnea Syndrome”[tw] OR “Obstructive Sleep Apnoeas”[tw] OR “Obstructive Sleep Apnoea”[tw] OR OSAHS[tw] OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing”[tw]) | 28401 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Positive-Pressure Respiration”[Mesh:NoExp] | 14880 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Continuous Positive Airway Pressure”[Mesh] | 3985 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Continuous Positive Airway Pressure”[tw] OR CPAP[tw]) | 9222 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Intermittent Positive-Pressure Ventilation”[MeSH] | 2004 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Intermittent Positive Pressure Ventilation”[tw] OR “IPPV”[tw] OR “Inspiratory Positive-Pressure Ventilation”[tw] OR “Inspiratory Positive Pressure Ventilation”[tw] OR “Biphasic Intermittent Positive Airway Pressure”[tw] OR BiPAP[tw]) | 3260 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Mandibular Prosthesis”[MeSH Terms] | 798 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“mandibular advancement device”[tw] OR “mandibular advancement devices”[tw]) | 180 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Mandibular Advancement/instrumentation”[Mesh] | 516 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“oral appliance”[tw] OR “oral appliances”[tw]) | 641 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“General Surgery”[MeSH] OR “general surgery”[tw]) | 39479 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“otolaryngology”[MeSH] OR “otolaryngology”[tw] OR “Otorhinolaryngology”[tw] OR “Laryngology”[tw]) | 17942 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“surgery, plastic”[MeSH] OR “Plastic Surgery”[tw]) | 29779 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Surgical Procedures, Operative”[MeSH] OR “Operative Surgical Procedure”[tw] OR “Operative Surgical Procedures”[tw] OR “Operative Procedures”[tw] OR “Operative Procedure”[tw]) | 2394551 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Bariatric Surgery”[Mesh] | 14577 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (UPPP[tw] OR uvulopalatopharyngoplasty[tw]) | 921 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (septoplasty[tw] AND “turbinate reduction”[tw]) | 39 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Pillar Procedure”[tw] OR “soft palate implants”[tw]) | 0 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Hyoid advancement”[tw] | 11 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Orthognathic Surgical Procedures”[Mesh] | 1136 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Osteotomy, Le Fort”[Mesh] | 1482 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Osteotomy, Sagittal Split Ramus”[Mesh] | 284 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“tonsillectomy”[MeSH] OR tonsillectomy[tw]) | 9651 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Exercise Therapy”[MeSH] OR exercise[MeSH] OR “exercise therapy”[tw] OR “exercise therapies”[tw]) | 142239 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#25 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“weight loss”[MeSH] OR “weight loss”[tw] OR “weight reduction”[tw]) | 72130 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)
#26 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Body Mass Index”[Mesh] OR “body mass index”[tw] OR BMI[tw]) | 164639 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=26)
#27 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Obesity”[Mesh] OR obesity[tw]) | 201780 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=27)
#28 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Diet, Reducing”[Mesh] | 9355 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=28)
#29 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27 or #28) | 2904782 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#30 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #1 and #29) | 15311 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=30)
#31 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]) | 579517 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=31)
#32 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #30 and #31) | 1051 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=32)
#33 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #30 and #31) Filters: Humans | 1007 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=33)
#34 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #30 and #31) Filters: Humans; Adult: 19+ years | 862 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=34)
#35 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #30 and #31) Filters: Publication date from 2010/01/01; Humans; Adult: 19+ years | 301 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=35)
#36 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #30 and #31) Filters: Publication date from 2010/01/01; Humans; English; Adult: 19+ years | 290 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=36)
#37 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #35 not #36) | 11 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=37)
#38 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Cohort Studies”[Mesh] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective^*^[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields])) | 1664863 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=38)
#39 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #30 and #38) | 4240 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=39)
#40 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #30 and #38) Filters: Humans | 4211 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=40)
#41 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #30 and #38) Filters: Humans; Adult: 19+ years | 3247 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=41)
#42 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #30 and #38) Filters: Publication date from 2010/01/01; Humans; Adult: 19+ years | 1256 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=42)
#43 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #30 and #38) Filters: Publication date from 2010/01/01; Humans; English; Adult: 19+ years | 1182 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=43)
#44 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #42 not #43) | 74 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=44)

PubMed screening search, 9/29/2014

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Sleep Apnea Syndromes”[MeSH] OR “Sleep Apnea, Obstructive”[MeSH] OR “Obstructive Sleep Apneas”[tw] OR “Obstructive Sleep Apnea”[tw] OR “Obstructive Sleep Apnea Syndrome”[tw] OR “Obstructive Sleep Apnoeas”[tw] OR “Obstructive Sleep Apnoea”[tw] OR OSAHS[tw] OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing”[tw]) | 28390 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Questionnaires”[Mesh] | 309519 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Epworth Sleepiness Scale”[All Fields] | 2137 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “STOP Questionnaire”[All Fields] | 21 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “STOP-Bang Questionnaire”[All Fields] | 41 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Berlin Questionnaire”[All Fields] | 250 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Wisconsin Sleep Questionnaire”[All Fields] | 3 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Decision Support Techniques”[Mesh] | 60053 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Clinical prediction tool” OR “Clinical prediction rule” OR “Clinical prediction score”) | 497 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Multivariable Apnea Prediction Index”[All Fields] | 9 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Multivariable Apnoea Prediction Index”[All Fields] | 0 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Snoring Scale”[All Fields] | 22 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “NAMES”[All Fields] | 14085 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Sleep Apnea Clinical Score”[All Fields] | 10 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Neck circumference”[All Fields] | 621 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed) | Search Mallampati[All Fields] | 511 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Craniofacial structure”[All Fields] | 121 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Nocturnal choking”[All Fields] | 21 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Nocturnal gasping”[All Fields] | 3 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#21 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Body Mass Index”[Mesh]) OR “Body Weight”[Mesh] OR “Obesity”[Mesh]) | 386293 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Snoring”[Mesh] OR snoring) | 5547 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed) | Search Sleepiness | 30048 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #21 or #22 or #23) | 782859 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#25 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #1 and #24) | 12584 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)
#26 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Mass Screening”[Mesh] OR screening[tiab]) | 378755 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=26)
#27 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Predictive Value of Tests”[Mesh] | 142093 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=27)
#28 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Diagnostic Tests, Routine”[Mesh] OR “Sensitivity and Specificity”[Mesh] OR “Predictive Value of Tests”[Mesh] OR “ROC Curve”[Mesh] OR “Diagnosis”[Mesh] OR “Reproducibility of Results”[Mesh] OR “False Negative Reactions”[Mesh] OR “False Positive Reactions”[Mesh] OR “predictive value”[tw] OR sensitivity[tw] OR specificity[tw] OR accuracy[tw] OR screen[tw] OR diagno^*^[tw] OR ROC[tw] OR reproducib^*^[tw] OR “false positive”[tw] OR “false negative”[tw] OR “likelihood ratio”[tw]) | 8792662 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=28)
#29 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #26 or #27 or #28) | 8900912 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#30 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #25 and #29) | 10585 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=30)
#31 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (Autobiography[Publication Type] OR Bibliography[Publication Type] OR Biography[Publication Type] OR Case Reports[Publication Type] OR Classical Article[Publication Type] OR comment[Publication Type] OR Congresses[Publication Type] OR Consensus Development Conference[Publication Type] OR Dictionary[Publication Type] OR Directory[Publication Type] OR Editorial[Publication Type] OR Electronic supplementary materials[Publication Type] OR Festschrift[Publication Type] OR In Vitro[Publication Type] OR Interactive Tutorial[Publication Type] OR Interview[Publication Type] OR Lectures[Publication Type] OR Legal Cases[Publication Type] OR Legislation[Publication Type] OR Letter[Publication Type] OR News[Publication Type] OR Newspaper article[Publication Type] OR Patient Education Handout[Publication Type] OR Personal Narratives[Publication Type] OR Periodical Index[Publication Type] OR Pictorial works[Publication Type] OR Popular works[Publication Type] OR Portraits[Publication Type] OR Scientific Integrity Review[Publication Type] OR Video Audio Media[Publication Type] OR Webcasts[Publication Type]) | 3692864 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=31)
#32 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #30 not #31) | 9359 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=32)
#33 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #30 not #31) Filters: Adult: 19+ years | 6029 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=33)
#34 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #30 not #31) Filters: Humans; Adult: 19+ years | 6029 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=34)
#35 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #30 not #31) Filters: Humans; English; Adult: 19+ years | 5279 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=35)
#36 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #34 NOT #35) | 750 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=36)

PubMed KQ6 search, 9/29/2014

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Sleep Apnea Syndromes”[MeSH] OR “Sleep Apnea, Obstructive”[MeSH] OR “Obstructive Sleep Apneas”[tw] OR “Obstructive Sleep Apnea”[tw] OR “Obstructive Sleep Apnea Syndrome”[tw] OR “Obstructive Sleep Apnoeas”[tw] OR “Obstructive Sleep Apnoea”[tw] OR OSAHS[tw] OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing”[tw]) | 28401 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Apnea hypopnea Index”[All Fields] OR “Apnea/hypopnea index”[All Fields] OR “Apnoea hypopnea index”[All Fields] OR “Apnoea hypopnoea index”[All Fields] OR “Apnoea/hypopnoea index”[All Fields]) | 4725 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #1 and #2) | 4573 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Patient Outcome Assessment”[Mesh] OR “Outcome Assessment (Health Care)”[Mesh] OR “Fatal Outcome”[Mesh]) | 749768 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search outcome^*^[tiab] | 961492 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Mortality”[Mesh] OR “mortality” [Subheading] OR mortality[tiab]) | 864162 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Quality of Life”[Mesh] OR “quality of life”[tiab]) | 195341 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Motor Vehicles”[Mesh] OR “motor vehicle”[tiab] OR “motor vehicles”[tiab]) | 24728 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Cardiovascular Diseases”[Mesh]) OR “Myocardial Infarction”[Mesh] OR cardiovascular^*^[tiab]) | 2008239 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Stroke”[Mesh]) OR “Cerebrovascular Disorders”[Mesh] OR stroke[tiab] OR cerebrovasc^*^[tiab]) | 361286 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “heart failure”[tiab] | 110169 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Headache”[Mesh] OR headache[tiab]) | 61110 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Mild Cognitive Impairment”[Mesh]) OR “Cognition Disorders”[Mesh] OR cognit^*^[tiab]) | 247674 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13) | 4056320 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #3 and #14) | 2370 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (Autobiography[Publication Type] OR Bibliography[Publication Type] OR Biography[Publication Type] OR Case Reports[Publication Type] OR Classical Article[Publication Type] OR comment[Publication Type] OR Congresses[Publication Type] OR Consensus Development Conference[Publication Type] OR Dictionary[Publication Type] OR Directory[Publication Type] OR Editorial[Publication Type] OR Electronic supplementary materials[Publication Type] OR Festschrift[Publication Type] OR In Vitro[Publication Type] OR Interactive Tutorial[Publication Type] OR Interview[Publication Type] OR Lectures[Publication Type] OR Legal Cases[Publication Type] OR Legislation[Publication Type] OR Letter[Publication Type] OR News[Publication Type] OR Newspaper article[Publication Type] OR Patient Education Handout[Publication Type] OR Personal Narratives[Publication Type] OR Periodical Index[Publication Type] OR Pictorial works[Publication Type] OR Popular works[Publication Type] OR Portraits[Publication Type] OR Scientific Integrity Review[Publication Type] OR Video Audio Media[Publication Type] OR Webcasts[Publication Type] OR Twin Studies[Publication Type]) | 3694043 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #15 not #16) | 2327 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #15 not #16) Filters: Adult: 19+ years | 1826 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #15 not #16) Filters: Humans; Adult: 19+ years | 1826 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #15 not #16) Filters: Publication date from 2010/01/01; Humans; Adult: 19+ years | 781 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #15 not #16) Filters: Publication date from 2010/01/01; Humans; English; Adult: 19+ years | 743 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ( #20 not #21) | 38 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)

PubMed Diagnosis Search, 9-29-14

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Sleep Apnea Syndromes”[MeSH] OR “Sleep Apnea, Obstructive”[MeSH] OR “Obstructive Sleep Apneas”[tw] OR “Obstructive Sleep Apnea”[tw] OR “Obstructive Sleep Apnea Syndrome”[tw] OR “Obstructive Sleep Apnoeas”[tw] OR “Obstructive Sleep Apnoea”[tw] OR OSAHS[tw] OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing”[tw])) | 28390 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Sleep Apnea Syndromes/diagnosis”[Majr] | 4408 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Sleep Apnea, Obstructive/diagnosis”[Majr] | 2256 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Monitoring, Ambulatory/instrumentation”[Majr] | 2980 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (Polysomnography[Mesh] OR Polysomnographies[tw]) | 14079 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (oximetry[MeSH] OR oximetry[tw] OR “Oximetries”[tw]) | 14957 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Diagnostic Tests, Routine”[Mesh] | 7019 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “sleep monitoring”[All Fields] | 245 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search PSG | 3498 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search polygraphy | 496 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search Actigraphy | 2620 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search Apnoescreen | 4 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((home AND monitor^*^)) | 13099 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search Monitoring system^*^ | 8700 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “portable respiratory monitoring” | 4 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search Portable monitor^*^ | 308 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“diagnosis”[MeSH] OR “diagnosis”[tw] OR “diagnoses”[tw] OR “Reproducibility of Results”[MeSH] OR “Reproducibility of Results”[tw] OR “Reproducibility of Findings”[tw] OR “Predictive Value of Tests”[Mesh] OR “Predictive Value”[tw] OR “ROC Curve”[Mesh] OR “ROC”[tw] OR “Validity of Results”[tw] OR reliab^*^[tw] OR valid^*^[tw] OR “False Negative Reactions”[MeSH] OR “false negative”[tw] OR “False Positive Reactions”[MeSH] OR “false positive”[tw] OR “accuracy”[tw] OR reproducib^*^[tw] OR “likelihood ratio”[tw] OR “accuracy”[tw] OR “sensitivity”[tw] OR “specificity”[tw]) | 8743832 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #1 AND ( #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17)) | 20457 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #1 AND ( #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17)) Filters: Humans | 19169 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #1 AND ( #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17)) Filters: Publication date from 2010/01/01; Humans | 5426 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (Autobiography[Publication Type] OR Bibliography[Publication Type] OR Biography[Publication Type] OR Case Reports[Publication Type] OR Classical Article[Publication Type] OR comment[Publication Type] OR Congresses[Publication Type] OR Consensus Development Conference[Publication Type] OR Dictionary[Publication Type] OR Directory[Publication Type] OR Editorial[Publication Type] OR Electronic supplementary materials[Publication Type] OR Festschrift[Publication Type] OR In Vitro[Publication Type] OR Interactive Tutorial[Publication Type] OR Interview[Publication Type] OR Lectures[Publication Type] OR Legal Cases[Publication Type] OR Legislation[Publication Type] OR Letter[Publication Type] OR News[Publication Type] OR Newspaper article[Publication Type] OR Patient Education Handout[Publication Type] OR Personal Narratives[Publication Type] OR Periodical Index[Publication Type] OR Pictorial works[Publication Type] OR Popular works[Publication Type] OR Portraits[Publication Type] OR Scientific Integrity Review[Publication Type] OR Video Audio Media[Publication Type] OR Webcasts[Publication Type]) | 3692864 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #20 NOT #21) | 4647 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #20 NOT #21) Filters: Adult: 19+ years | 3035 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #20 NOT #21) Filters: English; Adult: 19+ years | 2806 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#25 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #23 NOT #24) | 229 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)

Cochrane Interventions/Treatment search, 9-30-14

ID | Search | Hits
#1 | [mh “Sleep Apnea Syndromes”] or [mh “Sleep Apnea, Obstructive”] or [mh “Obstructive Sleep Apneas”] or [mh “Obstructive Sleep Apnea”] or [mh “Obstructive Sleep Apnea Syndrome”] or “Obstructive Sleep Apnoeas” or “Obstructive Sleep Apnoea” or OSAHS or (“sleep apnea” and hypopnea) or “sleep disordered breathing” | 1966
#2 | [mh ^“Positive-Pressure Respiration”] | 1249
#3 | [mh “Continuous Positive Airway Pressure”] | 650
#4 | “Continuous Positive Airway Pressure” or CPAP | 2344
#5 | [mh “Intermittent Positive-Pressure Ventilation”] | 194
#6 | “Intermittent Positive Pressure Ventilation” or “IPPV” or “Inspiratory Positive-Pressure Ventilation” or “Inspiratory Positive Pressure Ventilation” or “Biphasic Intermittent Positive Airway Pressure” or BiPAP | 592
#7 | [mh “Mandibular Prosthesis”] | 6
#8 | “mandibular advancement device” or “mandibular advancement devices” | 46
#9 | [mh “Mandibular Advancement”] | 125
#10 | [mh “General Surgery”] or “general surgery” | 2042
#11 | [mh otolaryngology] or otolaryngology or Otorhinolaryngology or Laryngology | 5993
#12 | [mh “Surgery, Plastic”] or “Plastic Surgery” | 1236
#13 | [mh “Surgical Procedures, Operative”] or “Operative Surgical Procedure” or “Operative Surgical Procedures” or “Operative Procedures” or “Operative Procedure” | 99826
#14 | [mh “Bariatric Surgery”] | 764
#15 | UPPP or uvulopalatopharyngoplasty | 103
#16 | (septoplasty and “turbinate reduction”) | 3
#17 | “Pillar Procedure” or “soft palate implants” | 1
#18 | “Hyoid advancement” | 0
#19 | [mh “Orthognathic Surgical Procedures”] | 61
#20 | [mh “Osteotomy, Le Fort”] | 63
#21 | [mh “Osteotomy, Sagittal Split Ramus”] | 14
#22 | [mh tonsillectomy] or tonsillectomy | 1716
#23 | [mh “Exercise Therapy”] or [mh exercise] or “exercise therapy” or “exercise therapies” | 19323
#24 | [mh “weight loss”] or “weight loss” or “weight reduction” | 8842
#25 | [mh “Body Mass Index”] or “body mass index” or BMI | 17317
#26 | [mh Obesity] or obesity | 13520
#27 | [mh “Diet, Reducing”] | 1581
#28 | #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27 | 149515
#29 | #1 and #28 | 1362

Cochrane Screening search, 9-30-14

ID | Search | Hits
#1 | [mh “Sleep Apnea Syndromes”] or [mh “Sleep Apnea, Obstructive”] or [mh “Obstructive Sleep Apneas”] or [mh “Obstructive Sleep Apnea”] or [mh “Obstructive Sleep Apnea Syndrome”] or “Obstructive Sleep Apnoeas” or “Obstructive Sleep Apnoea” or OSAHS or (“sleep apnea” and hypopnea) or “sleep disordered breathing” | 1966
#2 | [mh Questionnaires] | 17241
#3 | “Epworth Sleepiness Scale” | 420
#4 | “STOP Questionnaire” | 2
#5 | “STOP-Bang Questionnaire” | 2
#6 | “Berlin Questionnaire” | 13
#7 | “Wisconsin Sleep Questionnaire” | 0
#8 | [mh “Decision Support Techniques”] | 3166
#9 | “Clinical prediction tool” or “Clinical prediction rule” or “Clinical prediction score” | 73
#10 | “Multivariable Apnea Prediction Index” | 0
#11 | “Multivariable Apnoea Prediction Index” | 0
#12 | “Snoring Scale” | 4
#13 | “NAMES” | 1745
#14 | “Sleep Apnea Clinical Score” | 2
#15 | “Neck circumference” | 40
#16 | Mallampati | 111
#17 | “Craniofacial structure” | 2
#18 | “Nocturnal choking” | 1
#19 | “Nocturnal gasping” | 1
#20 | [mh “Body Mass Index”] or [mh “Body Weight”] or [mh Obesity] | 19124
#21 | [mh Snoring] or snoring | 419
#22 | Sleepiness | 1768
#23 | #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #21 or #22 | 23969
#24 | #1 and #23 | 664
#25 | [mh “Mass Screening”] or screening | 28803
#26 | [mh “Predictive Value of Tests”] | 6169
#27 | [mh “Diagnostic Tests, Routine”] or [mh “Sensitivity and Specificity”] or [mh “Predictive Value of Tests”] or [mh “ROC Curve”] or [mh Diagnosis] or [mh “Reproducibility of Results”] or [mh “False Negative Reactions”] or [mh “False Positive Reactions”] or “predictive value” or sensitivity or specificity or accuracy or screen^*^ or diagno^*^ or ROC or reproducib^*^ or “false positive” or “false negative” or “likelihood ratio” | 331387
#28 | #25 or #26 or #27 | 331467
#29 | #24 and #28 in Cochrane Reviews (Reviews and Protocols), Other Reviews, Trials and Technology Assessments | 529

Cochrane KQ6 search, 10-01-14

ID | Search | Hits
#1 | [mh “Sleep Apnea Syndromes”] or [mh “Sleep Apnea, Obstructive”] or [mh “Obstructive Sleep Apneas”] or [mh “Obstructive Sleep Apnea”] or [mh “Obstructive Sleep Apnea Syndrome”] or “Obstructive Sleep Apnoeas” or “Obstructive Sleep Apnoea” or OSAHS or (“sleep apnea” and hypopnea) or “sleep disordered breathing” | 1986
#2 | “Apnea hypopnea Index” or “Apnea/hypopnea index” or “Apnoea hypopnea index” or “Apnoea hypopnoea index” or “Apnoea/hypopnoea index” | 654
#3 | #1 and #2 | 607
#4 | [mh “Patient Outcome Assessment”] or [mh “Outcome Assessment (Health Care)”] or [mh “Fatal Outcome”] | 99822
#5 | outcome^*^ | 208437
#6 | [mh Mortality] or mortality | 50240
#7 | [mh “Quality of Life”] or “quality of life” | 37654
#8 | [mh “Motor Vehicles”] or “motor vehicle” or “motor vehicles” | 620
#9 | [mh “Cardiovascular Diseases”] or [mh “Myocardial Infarction”] or cardiovascular^*^ | 97515
#10 | [mh Stroke] or [mh “Cerebrovascular Disorders”] or stroke or cerebrovasc^*^ | 41189
#11 | “heart failure” | 12771
#12 | [mh Headache] or headache | 14079
#13 | [mh “Mild Cognitive Impairment”] or [mh “Cognition Disorders”] or cognit^*^ | 31052
#14 | #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 | 340683
#15 | #3 and #14 Publication Year from 2010 to 2014, in Cochrane Reviews (Reviews and Protocols), Other Reviews, Trials and Technology Assessments | 177

Cochrane Diagnosis search, 10-01-14

ID | Search | Hits
#1 | [mh “Sleep Apnea Syndromes”] or [mh “Sleep Apnea, Obstructive”] or [mh “Obstructive Sleep Apneas”] or [mh “Obstructive Sleep Apnea”] or [mh “Obstructive Sleep Apnea Syndrome”] or “Obstructive Sleep Apnoeas” or “Obstructive Sleep Apnoea” or OSAHS or (“sleep apnea” and hypopnea) or “sleep disordered breathing” | 1986
#2 | [mh ^“Monitoring, Ambulatory”/IS] | 125
#3 | [mh Polysomnography] or Polysomnographies | 1330
#4 | [mh oximetry] or oximetry or Oximetries | 1696
#5 | [mh “Diagnostic Tests, Routine”] | 311
#6 | “sleep monitoring” | 27
#7 | PSG | 384
#8 | polygraphy | 42
#9 | Actigraphy | 387
#10 | Apnoescreen | 1
#11 | home and monitor^*^ | 3144
#12 | Monitoring system^*^ | 11395
#13 | “portable respiratory monitoring” | 3
#14 | Portable monitor^*^ | 375
#15 | [mh diagnosis] or diagnosis or diagnoses or [mh “Reproducibility of Results”] or “Reproducibility of Results” or “Reproducibility of Findings” or [mh “Predictive Value of Tests”] or “Predictive Value” or [mh “ROC Curve”] or ROC or “Validity of Results” or reliab^*^ or valid^*^ or [mh “False Negative Reactions”] or “false negative” or [mh “False Positive Reactions”] or “false positive” or accuracy or reproducib^*^ or “likelihood ratio” or “accuracy” or “sensitivity” or “specificity” | 334889
#16 | #1 and ( #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15) | 1391
#17 | #16 Publication Year from 2010 to 2014, in Cochrane Reviews (Reviews and Protocols), Other Reviews, Trials and Technology Assessments | 479

EMBASE Intervention Search, 10-6-14

No. | Query | Results
#43 | #41 NOT #37 | 5
#42 | #40 NOT #36 | 137
#41 | #39 NOT #40 | 6
#40 | #33 AND #38 AND [english]/lim | 272
#39 | #33 AND #38 | 278
#38 | ‘cohort analysis’/exp OR ‘epidemiological study’ OR (cohort AND (study OR studies)) OR ‘prospective study’/exp OR (prospective^*^ AND cohort) | 624,021
#37 | #35 NOT #36 | 6
#36 | #35 AND [english]/lim | 562
#35 | #33 AND #34 | 568
#34 | ‘randomized controlled trial’/exp OR ‘single blind procedure’/exp OR ‘double blind procedure’/exp OR ‘random allocation’/exp OR ‘controlled trial’/exp OR ‘control trial’ OR (‘control’:ab,ti OR ‘controlled’:ab,ti AND ‘trial’:ab,ti) | 4,685,658
#33 | #4 AND #29 AND [humans]/lim AND [2010-2014]/py AND ([adult]/lim OR [middle aged]/lim OR [aged]/lim OR [very elderly]/lim) | 1,448
#32 | #4 AND #29 AND [humans]/lim AND [2010-2014]/py | 4,392
#30 | #4 AND #29 | 9,611
#29 | #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #15 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #28 | 176,391
#28 | ‘weight reduction’/exp | 103,035
#25 | ‘tonsillectomy’/exp | 11,569
#24 | ‘sagittal split ramal osteotomy’/exp | 165
#23 | ‘maxilla osteotomy’/exp | 2,083
#22 | ‘orthognathic surgery’/exp | 1,621
#21 | ‘hyoid advancement’ | 20
#20 | ‘pillar procedure’ OR ‘soft palate implants’ | 8
#19 | ‘nose septum reconstruction’/exp AND ‘turbinate reduction’ | 38
#18 | ‘uvulopalatopharyngoplasty’/exp | 1,194
#17 | ‘bariatric surgery’/exp | 19,692
#15 | ‘otorhinolaryngology’/exp | 19,509
#13 | ‘general surgery’/exp | 8,891
#12 | ‘mandible reconstruction’/exp | 3,870
#11 | ‘mandibular advancement device’ OR ‘mandibular advancement devices’ | 254
#10 | ‘mandible prosthesis’/exp | 656
#9 | ‘intermittent positive pressure ventilation’ OR ‘ippv’ OR ‘inspiratory positive-pressure ventilation’ OR ‘inspiratory positive pressure ventilation’ OR ‘biphasic intermittent positive airway pressure’ OR bipap | 4,895
#8 | ‘intermittent positive pressure ventilation’/exp | 2,792
#7 | ‘positive end expiratory pressure’/exp/mj | 11,754
#6 | ‘cpap device’/exp | 151
#5 | ‘positive end expiratory pressure’/exp/mj | 11,754
#4 | #1 OR #2 OR #3 | 43,859
#3 | ‘sleep apnea’ AND hypopnea | 7,727
#2 | ‘obstructive sleep apnoeas’ OR ‘obstructive sleep apnoea’ | 4,530
#1 | ‘sleep disordered breathing’/exp | 43,459

EMBASE screening search, 10-07-14

No. | Query | Results
#21 | #19 NOT #20 | 32
#20 | #16 NOT #17 AND ([adult]/lim OR [middle aged]/lim OR [aged]/lim OR [very elderly]/lim) AND [humans]/lim AND [english]/lim | 318
#19 | #16 NOT #17 AND ([adult]/lim OR [middle aged]/lim OR [aged]/lim OR [very elderly]/lim) AND [humans]/lim | 350
#18 | #16 NOT #17 | 596
#17 | #8 AND #15 AND ([conference abstract]/lim OR [conference paper]/lim OR [conference review]/lim OR [editorial]/lim OR [letter]/lim OR [note]/lim) | 706
#16 | #8 AND #15 | 1,302
#15 | #9 OR #10 OR #11 OR #12 OR #13 OR #14 | 5,021,470
#14 | ‘diagnosis’/exp | 4,846,516
#13 | ‘receiver operating characteristic’/exp | 48,005
#12 | ‘sensitivity and specificity’/exp | 201,366
#11 | ‘diagnostic test’/exp | 721,811
#10 | ‘predictive value’/exp | 58,047
#9 | ‘mass screening’/exp | 159,522
#8 | #4 AND #7 | 3,876
#7 | #5 OR #6 | 412,992
#6 | ‘clinical prediction tool’ OR ‘clinical prediction rule’ OR ‘clinical prediction score’ | 740
#5 | ‘questionnaire’/exp | 412,296
#4 | #1 OR #2 OR #3 | 44,485
#3 | ‘sleep apnea’ AND hypopnea | 7,733
#2 | ‘obstructive sleep apnoeas’ OR ‘obstructive sleep apnoea’ | 4,530
#1 | ‘sleep disordered breathing’/exp OR ‘sleep disordered breathing’ | 44,124

### Gray Literature Searches, June 18-24, 2015

#### ClinicalTrials.gov Expert Searches (484 in EndNote):

SCREENING AND DIAGNOSIS (on 6/12 yield was N=303. On 6/18 increased to 304)

INFLECT EXACT ( “Adult” OR “Senior” ) [AGE-GROUP] AND (Ambulatory monitoring OR Polysomnograph^*^ OR oximetr^*^ OR diagnos^*^ OR sleep monitoring OR PSG OR polygraphy OR Actigraphy OR Apnoescreen OR home monitor^*^ OR Monitoring system^*^ OR portable respiratory monitoring OR Portable monitor^*^ OR screen^*^ OR diagno^*^ OR sensitivity OR specificity OR accuracy OR reliab^*^ OR valid^*^ OR reproducib^*^ OR “false positive” OR “false negative” ) AND (“Sleep Apnea, Obstructive”) [DISEASE] (N=304)

TREATMENT AND HARMS (180 of 296 imported to the screening/diag search results; 116 were duplicates with the Screening and Diag. Search – imported to Duplicates Library)

INFLECT EXACT “Interventional” [STUDY-TYPES] AND INFLECT EXACT ( “Adult” OR “Senior” ) [AGE-GROUP] AND NOT “single group assignment” AND “Sleep Apnea, Obstructive” [DISEASE] AND ( Positive-Pressure Respiration OR Continuous Positive Airway Pressure OR CPAP OR Intermittent Positive Pressure Ventilation OR IPPV OR Inspiratory Positive-Pressure Ventilation OR Inspiratory Positive Pressure Ventilation OR Biphasic Intermittent Positive Airway Pressure OR BiPAP OR Mandibular Prosthesis OR mandibular advancement device OR mandibular advancement devices OR Mandibular Advancement OR surgery OR surgical OR UPPP or uvulopalatopharyngoplasty OR septoplasty OR Pillar Procedure OR Hyoid advancement OR Osteotomy OR tonsillectomy OR exercise OR weight loss OR weight reduction OR diet ) [TREATMENT] (N=296)

#### WHO ICTRP Advanced searches translated from the above, 6-18-15 through 6-24-15

Total from ICTRP in EndNote =422

Recruitment status: ALL

Condition box:

Obstructive sleep apnea

SCREENING AND DIAGNOSIS (N=85; all imported but I see a lot of CT.gov results)

Title box:

Ambulatory monitoring OR Polysomnograph^*^ OR oximetr^*^ OR diagnos^*^ OR sleep monitoring OR PSG OR polygraphy OR Actigraphy OR Apnoescreen OR home monitor^*^ OR Monitoring system^*^ OR portable respiratory monitoring OR Portable monitor^*^ OR screen^*^ OR diagno^*^ OR sensitivity OR specificity OR accuracy OR reliab^*^ OR valid^*^ OR reproducib^*^ OR “false positive” OR “false negative”

TREATMENT AND HARMS (N=229-289)

Must run 2 iterations to be able to search all of the terms that go into the Intervention box. When String 1 (321) and String 2 (68) were imported to previous results, 337 total were imported

Condition box:

Obstructive sleep apnea

Intervention box:

String 1:

Positive-Pressure Respiration OR Continuous Positive Airway Pressure OR CPAP OR Mandibular Prosthesis OR mandibular advancement device OR mandibular advancement devices OR Mandibular Advancement OR surgery

(N=321, 302 imported)

String 2:

surgical OR UPPP or uvulopalatopharyngoplasty OR septoplasty OR Pillar Procedure OR Hyoid advancement OR Osteotomy OR tonsillectomy OR exercise OR weight loss OR weight reduction OR diet

(N= 68, 35 imported)

### Update Search Strategies

PubMed searches 10/26/15

PubMed Intervention/Treatment Search

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Sleep Apnea Syndromes”[MeSH] OR “Sleep Apnea, Obstructive”[MeSH] OR “Obstructive Sleep Apneas”[tw] OR “Obstructive Sleep Apnea”[tw] OR “Obstructive Sleep Apnea Syndrome”[tw] OR “Obstructive Sleep Apnoeas”[tw] OR “Obstructive Sleep Apnoea”[tw] OR OSAHS[tw] OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing”[tw] | 31091 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Positive-Pressure Respiration”[Mesh:NoExp] | 15320 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Continuous Positive Airway Pressure”[Mesh] | 4528 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Continuous Positive Airway Pressure”[tw] OR CPAP[tw]) | 10108 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Intermittent Positive-Pressure Ventilation”[MeSH] | 2041 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Intermittent Positive Pressure Ventilation”[tw] OR “IPPV”[tw] OR “Inspiratory Positive-Pressure Ventilation”[tw] OR “Inspiratory Positive Pressure Ventilation”[tw] OR “Biphasic Intermittent Positive Airway Pressure”[tw] OR BiPAP[tw]) | 3351 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Mandibular Prosthesis”[MeSH Terms] | 809 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“mandibular advancement device”[tw] OR “mandibular advancement devices”[tw]) | 224 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Mandibular Advancement/instrumentation”[Mesh] | 563 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“oral appliance”[tw] OR “oral appliances”[tw]) | 701 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“General Surgery”[MeSH] OR “general surgery”[tw]) | 40999 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“otolaryngology”[MeSH] OR “otolaryngology”[tw] OR “Otorhinolaryngology”[tw] OR “Laryngology”[tw]) | 18827 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“surgery, plastic”[MeSH] OR “Plastic Surgery”[tw]) | 30637 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Surgical Procedures, Operative”[MeSH] OR “Operative Surgical Procedure”[tw] OR “Operative Surgical Procedures”[tw] OR “Operative Procedures”[tw] OR “Operative Procedure”[tw]) | 2507349 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Bariatric Surgery”[Mesh] | 16383 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (UPPP[tw] OR uvulopalatopharyngoplasty[tw]) | 969 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (septoplasty[tw] AND “turbinate reduction”[tw]) | 44 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Pillar Procedure”[tw] OR “soft palate implants”[tw]) | 0 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Hyoid advancement”[tw] | 11 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Orthognathic Surgical Procedures”[Mesh] | 1554 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Osteotomy, Le Fort”[Mesh] | 1646 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Osteotomy, Sagittal Split Ramus”[Mesh] | 405 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“tonsillectomy”[MeSH] OR tonsillectomy[tw]) | 10083 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Exercise Therapy”[MeSH] OR exercise[MeSH] OR “exercise therapy”[tw] OR “exercise therapies”[tw]) | 153553 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#25 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“weight loss”[MeSH] OR “weight loss”[tw] OR “weight reduction”[tw]) | 78219 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)
#26 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Body Mass Index”[Mesh] OR “body mass index”[tw] OR BMI[tw]) | 184751 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=26)
#27 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Obesity”[Mesh] OR obesity[tw]) | 222785 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=27)
#28 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Diet, Reducing”[Mesh] | 9720 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=28)
#29 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27 or #28) | 3061634 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#30 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #29) | 16809 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=30)
#31 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]) | 616366 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=31)
#32 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#30 and #31) | 1163 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=32)
#33 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#30 and #31) Filters: Humans | 1111 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=33)
#34 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#30 and #31) Filters: Humans; Adult: 19+ years | 948 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=34)
#35 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#30 and #31) Filters: Publication date from 2014/03/30 to 2015/10/26; Humans; Adult: 19+ years | 74 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=35)
#36 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Cohort Studies”[Mesh] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective^*^[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields])) | 1799790 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=36)
#37 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#30 and #36) | 4805 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=37)
#38 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#30 and #36) Filters: Humans | 4770 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=38)
#39 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#30 and #36) Filters: Humans; Adult: 19+ years | 3683 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=39)
#40 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#30 and #36) Filters: Publication date from 2014/03/30 to 2015/10/26; Humans; Adult: 19+ years | 375 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=40)

PubMed Screening Search, 10-26-15

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Sleep Apnea Syndromes”[MeSH] OR “Sleep Apnea, Obstructive”[MeSH] OR “Obstructive Sleep Apneas”[tw] OR “Obstructive Sleep Apnea”[tw] OR “Obstructive Sleep Apnea Syndrome”[tw] OR “Obstructive Sleep Apnoeas”[tw] OR “Obstructive Sleep Apnoea”[tw] OR OSAHS[tw] OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing”[tw])) | 31091 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Questionnaires”[Mesh] | 336040 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Epworth Sleepiness Scale”[All Fields] | 2465 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “STOP Questionnaire”[All Fields] | 24 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “STOP-Bang Questionnaire”[All Fields] | 65 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Berlin Questionnaire”[All Fields] | 295 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Wisconsin Sleep Questionnaire”[All Fields] | 5 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Decision Support Techniques”[Mesh] | 63509 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Clinical prediction tool” OR “Clinical prediction rule” OR “Clinical prediction score”) | 575 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Multivariable Apnea Prediction Index”[All Fields] | 9 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Multivariable Apnoea Prediction Index”[All Fields] | 0 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Snoring Scale”[All Fields] | 24 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “NAMES”[All Fields] | 15214 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Sleep Apnea Clinical Score”[All Fields] | 12 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Neck circumference”[All Fields] | 726 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed) | Search Mallampati[All Fields] | 577 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Craniofacial structure”[All Fields] | 128 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Nocturnal choking”[All Fields] | 22 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Nocturnal gasping”[All Fields] | 3 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Body Mass Index”[Mesh]) OR “Body Weight”[Mesh] OR “Obesity”[Mesh]) | 410281 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Snoring”[Mesh] OR snoring) | 5921 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed) | Search Sleepiness | 31499 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22) | 837425 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #23) | 13656 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#25 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Mass Screening”[Mesh] OR screening[tiab]) | 410872 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)
#26 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Predictive Value of Tests”[Mesh] | 153814 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=26)
#27 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Diagnostic Tests, Routine”[Mesh] OR “Sensitivity and Specificity”[Mesh] OR “Predictive Value of Tests”[Mesh] OR “ROC Curve”[Mesh] OR “Diagnosis”[Mesh] OR “Reproducibility of Results”[Mesh] OR “False Negative Reactions”[Mesh] OR “False Positive Reactions”[Mesh] OR “predictive value”[tw] OR sensitivity[tw] OR specificity[tw] OR accuracy[tw] OR screen[tw] OR diagno^*^[tw] OR ROC[tw] OR reproducib^*^[tw] OR “false positive”[tw] OR “false negative”[tw] OR “likelihood ratio”[tw]) | 9240601 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=27)
#28 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#25 or #26 or #27) | 9360197 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=28)
#29 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#24 and #28) | 11490 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#30 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (Autobiography[Publication Type] OR Bibliography[Publication Type] OR Biography[Publication Type] OR Case Reports[Publication Type] OR Classical Article[Publication Type] OR comment[Publication Type] OR Congresses[Publication Type] OR Consensus Development Conference[Publication Type] OR Dictionary[Publication Type] OR Directory[Publication Type] OR Editorial[Publication Type] OR Electronic supplementary materials[Publication Type] OR Festschrift[Publication Type] OR In Vitro[Publication Type] OR Interactive Tutorial[Publication Type] OR Interview[Publication Type] OR Lectures[Publication Type] OR Legal Cases[Publication Type] OR Legislation[Publication Type] OR Letter[Publication Type] OR News[Publication Type] OR Newspaper article[Publication Type] OR Patient Education Handout[Publication Type] OR Personal Narratives[Publication Type] OR Periodical Index[Publication Type] OR Pictorial works[Publication Type] OR Popular works[Publication Type] OR Portraits[Publication Type] OR Scientific Integrity Review[Publication Type] OR Video Audio Media[Publication Type] OR Webcasts[Publication Type]) | 3475802 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=30)
#31 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#29 NOT #30) | 10194 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=31)
#32 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#29 NOT #30) Filters: Adult: 19+ years | 6552 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=32)
#33 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#29 NOT #30) Filters: Humans; Adult: 19+ years | 6552 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=33)
#34 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#29 NOT #30) Filters: Publication date from 2014/03/29 to 2015/10/26; Humans; Adult: 19+ years | 407 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=34)
#35 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#29 NOT #30) Filters: Publication date from 2014/03/29 to 2015/10/26; Humans; English; Adult: 19+ years | 389 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=35)
#36 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#34 NOT #35) Non-English | 18 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=36)

PubMed KQ6 (AHI) search update, 10-26-15

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Sleep Apnea Syndromes”[MeSH] OR “Sleep Apnea, Obstructive”[MeSH] OR “Obstructive Sleep Apneas”[tw] OR “Obstructive Sleep Apnea”[tw] OR “Obstructive Sleep Apnea Syndrome”[tw] OR “Obstructive Sleep Apnoeas”[tw] OR “Obstructive Sleep Apnoea”[tw] OR OSAHS[tw] OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing”[tw])) | 31091 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Apnea hypopnea Index”[All Fields] OR “Apnea/hypopnea index”[All Fields] OR “Apnoea hypopnea index”[All Fields] OR “Apnoea hypopnoea index”[All Fields] OR “Apnoea/hypopnoea index”[All Fields]) | 5420 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #2) | 5228 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Patient Outcome Assessment”[Mesh] OR “Outcome Assessment (Health Care)”[Mesh] OR “Fatal Outcome”[Mesh]) | 815297 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search outcome^*^[tiab] | 1078898 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Mortality”[Mesh] OR “mortality” [Subheading] OR mortality[tiab])) | 929218 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Quality of Life”[Mesh] OR “quality of life”[tiab]) | 216756 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Motor Vehicles”[Mesh] OR “motor vehicle”[tiab] OR “motor vehicles”[tiab]) | 26220 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Cardiovascular Diseases”[Mesh]) OR “Myocardial Infarction”[Mesh] OR cardiovascular^*^[tiab]) | 2105237 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Stroke”[Mesh]) OR “Cerebrovascular Disorders”[Mesh] OR stroke[tiab] OR cerebrovasc^*^[tiab])) | 385822 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “heart failure”[tiab] | 123422 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Headache”[Mesh] OR headache[tiab])) | 65056 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Mild Cognitive Impairment”[Mesh]) OR “Cognition Disorders”[Mesh] OR cognit^*^[tiab]) | 278023 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13) | 4353340 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 and #14) | 2740 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (Autobiography[Publication Type] OR Bibliography[Publication Type] OR Biography[Publication Type] OR Case Reports[Publication Type] OR Classical Article[Publication Type] OR comment[Publication Type] OR Congresses[Publication Type] OR Consensus Development Conference[Publication Type] OR Dictionary[Publication Type] OR Directory[Publication Type] OR Editorial[Publication Type] OR Electronic supplementary materials[Publication Type] OR Festschrift[Publication Type] OR In Vitro[Publication Type] OR Interactive Tutorial[Publication Type] OR Interview[Publication Type] OR Lectures[Publication Type] OR Legal Cases[Publication Type] OR Legislation[Publication Type] OR Letter[Publication Type] OR News[Publication Type] OR Newspaper article[Publication Type] OR Patient Education Handout[Publication Type] OR Personal Narratives[Publication Type] OR Periodical Index[Publication Type] OR Pictorial works[Publication Type] OR Popular works[Publication Type] OR Portraits[Publication Type] OR Scientific Integrity Review[Publication Type] OR Video Audio Media[Publication Type] OR Webcasts[Publication Type] OR Twin Studies[Publication Type]) | 3475802 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#15 NOT #16) | 2690 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#15 NOT #16) Filters: Adult: 19+ years | 2052 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#15 NOT #16) Filters: Humans; Adult: 19+ years | 2052 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#15 NOT #16) Filters: Publication date from 2014/03/30 to 2015/10/26; Humans; Adult: 19+ years | 201 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)

PubMed Diagnosis search update, 10-26-15

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Sleep Apnea Syndromes”[MeSH] OR “Sleep Apnea, Obstructive”[MeSH] OR “Obstructive Sleep Apneas”[tw] OR “Obstructive Sleep Apnea”[tw] OR “Obstructive Sleep Apnea Syndrome”[tw] OR “Obstructive Sleep Apnoeas”[tw] OR “Obstructive Sleep Apnoea”[tw] OR OSAHS[tw] OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing”[tw])) | 31091 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Sleep Apnea Syndromes/diagnosis”[Majr] | 4804 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Sleep Apnea, Obstructive/diagnosis”[Majr] | 2550 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Monitoring, Ambulatory/instrumentation”[Majr] | 3293 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (Polysomnography[Mesh] OR Polysomnographies[tw]) | 15308 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (oximetry[MeSH] OR oximetry[tw] OR “Oximetries”[tw]) | 15759 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Diagnostic Tests, Routine”[Mesh] | 7624 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “sleep monitoring”[All Fields] | 286 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search PSG | 3975 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search polygraphy | 547 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search Actigraphy | 3170 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search Apnoescreen | 4 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (home AND monitor^*^) | 14258 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed) | Search Monitoring system^*^ | 9502 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “portable respiratory monitoring” | 4 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed) | Search Portable monitor^*^ | 344 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“diagnosis”[MeSH] OR “diagnosis”[tw] OR “diagnoses”[tw] OR “Reproducibility of Results”[MeSH] OR “Reproducibility of Results”[tw] OR “Reproducibility of Findings”[tw] OR “Predictive Value of Tests”[Mesh] OR “Predictive Value”[tw] OR “ROC Curve”[Mesh] OR “ROC”[tw] OR “Validity of Results”[tw] OR reliab^*^[tw] OR valid^*^[tw] OR “False Negative Reactions”[MeSH] OR “false negative”[tw] OR “False Positive Reactions”[MeSH] OR “false positive”[tw] OR “accuracy”[tw] OR reproducib^*^[tw] OR “likelihood ratio”[tw] OR “accuracy”[tw] OR “sensitivity”[tw] OR “specificity”[tw]) | 9196706 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 AND (#4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17)) | 22367 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 AND (#4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17)) Filters: Humans | 20874 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 AND (#4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17)) Filters: Publication date from 2014/03/29 to 2015/10/26; Humans | 1383 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (Autobiography[Publication Type] OR Bibliography[Publication Type] OR Biography[Publication Type] OR Case Reports[Publication Type] OR Classical Article[Publication Type] OR comment[Publication Type] OR Congresses[Publication Type] OR Consensus Development Conference[Publication Type] OR Dictionary[Publication Type] OR Directory[Publication Type] OR Editorial[Publication Type] OR Electronic supplementary materials[Publication Type] OR Festschrift[Publication Type] OR In Vitro[Publication Type] OR Interactive Tutorial[Publication Type] OR Interview[Publication Type] OR Lectures[Publication Type] OR Legal Cases[Publication Type] OR Legislation[Publication Type] OR Letter[Publication Type] OR News[Publication Type] OR Newspaper article[Publication Type] OR Patient Education Handout[Publication Type] OR Personal Narratives[Publication Type] OR Periodical Index[Publication Type] OR Pictorial works[Publication Type] OR Popular works[Publication Type] OR Portraits[Publication Type] OR Scientific Integrity Review[Publication Type] OR Video Audio Media[Publication Type] OR Webcasts[Publication Type]) | 3475802 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#20 NOT #21) | 1192 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#20 NOT #21) Filters: Adult: 19+ years | 769 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)

Cochrane Library Interventions/Tx search update, 10-26-15

ID | Search | Hits
#1 | [mh “Sleep Apnea Syndromes”] or [mh “Sleep Apnea, Obstructive”] or [mh “Obstructive Sleep Apneas”] or [mh “Obstructive Sleep Apnea”] or [mh “Obstructive Sleep Apnea Syndrome”] or “Obstructive Sleep Apnoeas” or “Obstructive Sleep Apnoea” or OSAHS or (“sleep apnea” and hypopnea) or “sleep disordered breathing” | 2386
#2 | [mh ^“Positive-Pressure Respiration”] | 1266
#3 | [mh “Continuous Positive Airway Pressure”] | 696
#4 | “Continuous Positive Airway Pressure” or CPAP | 2810
#5 | [mh “Intermittent Positive-Pressure Ventilation”] | 195
#6 | “Intermittent Positive Pressure Ventilation” or “IPPV” or “Inspiratory Positive-Pressure Ventilation” or “Inspiratory Positive Pressure Ventilation” or “Biphasic Intermittent Positive Airway Pressure” or BiPAP | 662
#7 | [mh “Mandibular Prosthesis”] | 6
#8 | “mandibular advancement device” or “mandibular advancement devices” | 56
#9 | [mh “Mandibular Advancement”] | 130
#10 | [mh “General Surgery”] or “general surgery” | 2312
#11 | [mh otolaryngology] or otolaryngology or Otorhinolaryngology or Laryngology | 6541
#12 | [mh “Surgery, Plastic”] or “Plastic Surgery” | 1400
#13 | [mh “Surgical Procedures, Operative”] or “Operative Surgical Procedure” or “Operative Surgical Procedures” or “Operative Procedures” or “Operative Procedure” | 102778
#14 | [mh “Bariatric Surgery”] | 823
#15 | UPPP or uvulopalatopharyngoplasty | 115
#16 | (septoplasty and “turbinate reduction”) | 3
#17 | “Pillar Procedure” or “soft palate implants” | 1
#18 | “Hyoid advancement” | 0
#19 | [mh “Orthognathic Surgical Procedures”] | 67
#20 | [mh “Osteotomy, Le Fort”] | 67
#21 | [mh “Osteotomy, Sagittal Split Ramus”] | 18
#22 | [mh tonsillectomy] or tonsillectomy | 1890
#23 | [mh “Exercise Therapy”] or [mh exercise] or “exercise therapy” or “exercise therapies” | 20172
#24 | [mh “weight loss”] or “weight loss” or “weight reduction” | 11104
#25 | [mh “Body Mass Index”] or “body mass index” or BMI | 22489
#26 | [mh Obesity] or obesity | 16993
#27 | [mh “Diet, Reducing”] | 1627
#28 | #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27 | 161973
#29 | #1 and #28 | 1642
#30 | #29 Publication Year from 2014 to 2015, in in Cochrane Reviews, Other Reviews, Trials and Technology Assessments | 253

Cochrane Library Screening update, 10-26-15

ID | Search | Hits
#1 | [mh “Sleep Apnea Syndromes”] or [mh “Sleep Apnea, Obstructive”] or [mh “Obstructive Sleep Apneas”] or [mh “Obstructive Sleep Apnea”] or [mh “Obstructive Sleep Apnea Syndrome”] or “Obstructive Sleep Apnoeas” or “Obstructive Sleep Apnoea” or OSAHS or (“sleep apnea” and hypopnea) or “sleep disordered breathing” | 2386
#2 | [mh Questionnaires] | 17769
#3 | “Epworth Sleepiness Scale” | 573
#4 | “STOP Questionnaire” | 2
#5 | “STOP-Bang Questionnaire” | 2
#6 | “Berlin Questionnaire” | 18
#7 | “Wisconsin Sleep Questionnaire” | 1
#8 | [mh “Decision Support Techniques”] | 3255
#9 | “Clinical prediction tool” or “Clinical prediction rule” or “Clinical prediction score” | 81
#10 | “Multivariable Apnea Prediction Index” | 0
#11 | “Multivariable Apnoea Prediction Index” | 0
#12 | “Snoring Scale” | 4
#13 | “NAMES” | 1844
#14 | “Sleep Apnea Clinical Score” | 2
#15 | “Neck circumference” | 68
#16 | Mallampati | 128
#17 | “Craniofacial structure” | 3
#18 | “Nocturnal choking” | 1
#19 | “Nocturnal gasping” | 1
#20 | [mh “Body Mass Index”] or [mh “Body Weight”] or [mh Obesity] | 19723
#21 | [mh Snoring] or snoring | 458
#22 | Sleepiness | 2207
#23 | #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #21 or #22 | 25182
#24 | #1 and #23 | 801
#25 | [mh “Mass Screening”] or screening | 24181
#26 | [mh “Predictive Value of Tests”] | 6376
#27 | [mh “Diagnostic Tests, Routine”] or [mh “Sensitivity and Specificity”] or [mh “Predictive Value of Tests”] or [mh “ROC Curve”] or [mh Diagnosis] or [mh “Reproducibility of Results”] or [mh “False Negative Reactions”] or [mh “False Positive Reactions”] or “predictive value” or sensitivity or specificity or accuracy or screen^*^ or diagno^*^ or ROC or reproducib^*^ or “false positive” or “false negative” or “likelihood ratio” | 355349
#28 | #25 or #26 or #27 | 355433
#29 | #24 and #28 Publication Year from 2014 to 2015, in Cochrane Reviews, Other Reviews, Trials and Technology Assessments | 75

Cochrane Library KQ6 (AHI) search update, 10-26-15

ID | Search | Hits
#1 | [mh “Sleep Apnea Syndromes”] or [mh “Sleep Apnea, Obstructive”] or [mh “Obstructive Sleep Apneas”] or [mh “Obstructive Sleep Apnea”] or [mh “Obstructive Sleep Apnea Syndrome”] or “Obstructive Sleep Apnoeas” or “Obstructive Sleep Apnoea” or OSAHS or (“sleep apnea” and hypopnea) or “sleep disordered breathing” | 2386
#2 | “Apnea hypopnea Index” or “Apnea/hypopnea index” or “Apnoea hypopnea index” or “Apnoea hypopnoea index” or “Apnoea/hypopnoea index” | 797
#3 | #1 and #2 | 742
#4 | [mh “Patient Outcome Assessment”] or [mh “Outcome Assessment (Health Care)”] or [mh “Fatal Outcome”] | 102609
#5 | outcome^*^ | 240219
#6 | [mh Mortality] or mortality | 56244
#7 | [mh “Quality of Life”] or “quality of life” | 44998
#8 | [mh “Motor Vehicles”] or “motor vehicle” or “motor vehicles” | 679
#9 | [mh “Cardiovascular Diseases”] or [mh “Myocardial Infarction”] or cardiovascular^*^ | 106030
#10 | [mh Stroke] or [mh “Cerebrovascular Disorders”] or stroke or cerebrovasc^*^ | 45504
#11 | “heart failure” | 15167
#12 | [mh Headache] or headache | 18758
#13 | [mh “Mild Cognitive Impairment”] or [mh “Cognition Disorders”] or cognit^*^ | 36402
#14 | #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 | 388817
#15 | #3 and #14 Publication Year from 2014 to 2015, in Cochrane Reviews, Other Reviews, Trials and Technology Assessments | 67

Cochrane Library Diagnosis search update, 10-26-15

ID | Search | Hits
#1 | [mh “Sleep Apnea Syndromes”] or [mh “Sleep Apnea, Obstructive”] or [mh “Obstructive Sleep Apneas”] or [mh “Obstructive Sleep Apnea”] or [mh “Obstructive Sleep Apnea Syndrome”] or “Obstructive Sleep Apnoeas” or “Obstructive Sleep Apnoea” or OSAHS or (“sleep apnea” and hypopnea) or “sleep disordered breathing” | 2386
#2 | [mh ^“Monitoring, Ambulatory”/IS] | 128
#3 | [mh Polysomnography] or Polysomnographies | 1371
#4 | [mh oximetry] or oximetry or Oximetries | 1927
#5 | [mh “Diagnostic Tests, Routine”] | 331
#6 | “sleep monitoring” | 42
#7 | PSG | 566
#8 | polygraphy | 50
#9 | Actigraphy | 572
#10 | Apnoescreen | 1
#11 | home and monitor^*^ | 3574
#12 | Monitoring system^*^ | 9320
#13 | “portable respiratory monitoring” | 3
#14 | Portable monitor^*^ | 443
#15 | [mh diagnosis] or diagnosis or diagnoses or [mh “Reproducibility of Results”] or “Reproducibility of Results” or “Reproducibility of Findings” or [mh “Predictive Value of Tests”] or “Predictive Value” or [mh “ROC Curve”] or ROC or “Validity of Results” or reliab^*^ or valid^*^ or [mh “False Negative Reactions”] or “false negative” or [mh “False Positive Reactions”] or “false positive” or accuracy or reproducib^*^ or “likelihood ratio” or “accuracy” or “sensitivity” or “specificity” | 350315
#16 | #1 and (#2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15) | 1529
#17 | #16 Publication Year from 2014 to 2015, in Cochrane Reviews, Other Reviews, Trials and Technology Assessments | 165

EMBASE searches 10-26-15 (Intervention & Harms) and 10-27-15 (Screening)

Intervention search

Benefits – 217, 169 imported

Harms – 151, 75 imported

No. | Query | Results
#32 | #28 AND #31 | 151
#31 | ‘cohort analysis’/exp OR ‘epidemiological study’ OR (cohort AND (study OR studies)) OR ‘prospective study’/exp OR (prospective^*^ AND cohort) | 736,749
#30 | #28 AND #29 | 217
#29 | ‘randomized controlled trial’/exp OR ‘single blind procedure’/exp OR ‘double blind procedure’/exp OR ‘random allocation’/exp OR ‘controlled trial’/exp OR ‘control trial’ OR (‘control’:ab,ti OR ‘controlled’:ab,ti AND ‘trial’:ab,ti) | 5,048,338
#28 | #27 AND ([adult]/lim OR [middle aged]/lim OR [aged]/lim OR [very elderly]/lim) | 656
#27 | #26 AND [humans]/lim AND [6-4-2014]/sd NOT [26-10-2015]/sd | 2,405
#26 | #4 AND #25 | 11,198
#25 | #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 | 200,411
#24 | ‘weight reduction’/exp | 117,483
#23 | ‘tonsillectomy’/exp | 12,449
#22 | ‘sagittal split ramal osteotomy’/exp | 236
#21 | ‘maxilla osteotomy’/exp | 2,282
#20 | ‘orthognathic surgery’/exp | 2,019
#19 | ‘hyoid advancement’ | 20
#18 | ‘pillar procedure’ OR ‘soft palate implants’ | 8
#17 | ‘nose septum reconstruction’/exp AND ‘turbinate reduction’ | 41
#16 | ‘uvulopalatopharyngoplasty’/exp | 1,276
#15 | ‘bariatric surgery’/exp | 23,670
#14 | ‘otorhinolaryngology’/exp | 22,128
#13 | ‘general surgery’/exp | 10,791
#12 | ‘mandible reconstruction’/exp | 4,303
#11 | ‘mandibular advancement device’ OR ‘mandibular advancement devices’ | 315
#10 | ‘mandible prosthesis’/exp | 676
#9 | ‘intermittent positive pressure ventilation’ OR ‘ippv’ OR ‘inspiratory positive-pressure ventilation’ OR ‘inspiratory positive pressure ventilation’ OR ‘biphasic intermittent positive airway pressure’ OR bipap | 5,180
#8 | ‘intermittent positive pressure ventilation’/exp | 2,895
#7 | ‘positive end expiratory pressure’/exp/mj | 12,783
#6 | ‘cpap device’/exp | 289
#5 | ‘positive end expiratory pressure’/exp/mj | 12,783
#4 | #1 OR #2 OR #3 | 50,880
#3 | ‘sleep apnea’ AND hypopnea | 9,473
#2 | ‘obstructive sleep apnoeas’ OR ‘obstructive sleep apnoea’ | 5,288
#1 | ‘sleep disordered breathing’/exp | 50,425

EMBASE Screening search, 10-27-15

37 results, 28 imported

No. | Query | Results
#21 | #16 NOT #17 AND ([adult]/lim OR [middle aged]/lim OR [aged]/lim OR [very elderly]/lim) AND [humans]/lim AND [english]/lim AND [7-10-2014]/sd NOT [27-10-2015]/sd | 37
#20 | #16 NOT #17 AND ([adult]/lim OR [middle aged]/lim OR [aged]/lim OR [very elderly]/lim) AND [humans]/lim AND [english]/lim | 355
#19 | #16 NOT #17 AND ([adult]/lim OR [middle aged]/lim OR [aged]/lim OR [very elderly]/lim) AND [humans]/lim | 389
#18 | #16 NOT #17 | 675
#17 | #8 AND #15 AND ([conference abstract]/lim OR [conference paper]/lim OR [conference review]/lim OR [editorial]/lim OR [letter]/lim OR [note]/lim) | 930
#16 | #8 AND #15 | 1,605
#15 | #9 OR #10 OR #11 OR #12 OR #13 OR #14 | 5,416,056
#14 | ‘diagnosis’/exp | 5,218,583
#13 | ‘receiver operating characteristic’/exp | 59,873
#12 | ‘sensitivity and specificity’/exp | 228,199
#11 | ‘diagnostic test’/exp | 760,098
#10 | ‘predictive value’/exp | 78,645
#9 | ‘mass screening’/exp | 174,071
#8 | #4 AND #7 | 4,672
#7 | #5 OR #6 | 463,378
#6 | ‘clinical prediction tool’ OR ‘clinical prediction rule’ OR ‘clinical prediction score’ | 866
#5 | ‘questionnaire’/exp | 462,559
#4 | #1 OR #2 OR #3 | 51,523
#3 | ‘sleep apnea’ AND hypopnea | 9,473
#2 | ‘obstructive sleep apnoeas’ OR ‘obstructive sleep apnoea’ | 5,288
#1 | ‘sleep disordered breathing’/exp OR ‘sleep disordered breathing’ | 51,108

### CT.gov and ICTRP searches for OSA Oct 2015

All searches done Oct. 28, 2015

Total number in EndNote = 120

Duplicates library = 22

#### ClinicalTrials.gov Expert searches

##### Screening/Diagnosis combined search

67 results, all imported

INFLECT EXACT ( “Adult” OR “Senior” ) [AGE-GROUP] AND ( Ambulatory monitoring OR Polysomnograph^*^ OR oximetr^*^ OR diagnos^*^ OR sleep monitoring OR PSG OR polygraphy OR Actigraphy OR Apnoescreen OR home monitor^*^ OR Monitoring system^*^ OR portable respiratory monitoring OR Portable monitor^*^ OR screen^*^ OR diagno^*^ OR sensitivity OR specificity OR accuracy OR reliab^*^ OR valid^*^ OR reproducib^*^ OR “false positive” OR “false negative” ) AND “Sleep Apnea, Obstructive” ∣ updated from 06/18/2015 to 10/28/2015

##### Treatment and Harms combined search

62 results, 40 imported and 22 went to Duplicates Library

INFLECT EXACT “Interventional” [STUDY-TYPES] AND INFLECT EXACT ( “Adult” OR “Senior” ) [AGE-GROUP] AND NOT “single group assignment” ∣ “Sleep Apnea, Obstructive” ∣ Positive-Pressure Respiration OR Continuous Positive Airway Pressure OR CPAP OR Intermittent Positive Pressure Ventilation OR IPPV OR Inspiratory Positive-Pressure Ventilation OR Inspiratory Positive Pressure Ventilation OR Biphasic Intermittent Positive Airway Pressure OR BiPAP OR Mandibular Prosthesis OR mandibular advancement device OR mandibular advancement devices OR Mandibular Advancement OR surgery OR surgical OR UPPP or uvulopalatopharyngoplasty OR septoplasty OR Pillar Procedure OR Hyoid advancement OR Osteotomy OR tonsillectomy OR exercise OR weight loss OR weight reduction OR diet ∣ updated from 06/18/2015 to 10/28/2015

#### WHO ICTRP Advanced Searches

Limited to ALL trials and dates 6-18-15 – 10-28-15

SCREENING AND DIAGNOSIS (N=0)

Condition box:

Obstructive sleep apnea

Title box:

Ambulatory monitoring OR Polysomnograph^*^ OR oximetr^*^ OR diagnos^*^ OR sleep monitoring OR PSG OR polygraphy OR Actigraphy OR Apnoescreen OR home monitor^*^ OR Monitoring system^*^ OR portable respiratory monitoring OR Portable monitor^*^ OR screen^*^ OR diagno^*^ OR sensitivity OR specificity OR accuracy OR reliab^*^ OR valid^*^ OR reproducib^*^ OR “false positive” OR “false negative”

##### Treatment and Harms search: (13 total, all imported)

Terms do not all fit in the intervention box so they were broken into two searches

Condition box:

Obstructive sleep apnea

Intervention box:

String 1:

Positive-Pressure Respiration OR Continuous Positive Airway Pressure OR CPAP OR Mandibular Prosthesis OR mandibular advancement device OR mandibular advancement devices OR Mandibular Advancement OR surgery

(N=11, all imported)

String 2:

surgical OR UPPP or uvulopalatopharyngoplasty OR septoplasty OR Pillar Procedure OR Hyoid advancement OR Osteotomy OR tonsillectomy OR exercise OR weight loss OR weight reduction OR diet

(N= 2, all imported)

## Appendix B2 Eligibility Criteria

| Include | Exclude
Populations | Adults ages 18 years or older KQs 1, 2: Asymptomatic adults and persons with unrecognized symptoms of OSA KQs 3, 7: Asymptomatic adults, persons with unrecognized symptoms of OSA, and referral populations KQs 4–6, 8: Persons with a confirmed diagnosis of OSA; population may include asymptomatic and/or symptomatic adults OSA severity will be defined as mild if the AHI (or RDI) is ≥5 to <15, moderate if the AHI (or RDI) is ≥15 to ≤30, and severe if the AHI (or RDI) is ≥30 | Children and adolescents, pregnant women, studies of adults with acute stroke or other acute conditions that can trigger onset of OSA Studies focused on screening, diagnosis, or treatment of OSA among persons with a rare condition (e.g., acromegaly) KQs 4–6, 8: Studies of persons with suspected but unconfirmed OSA
Setting | Studies conducted in countries categorized as “Very High” on the Human Development Index, as defined by the United Nations Development Programme KQs 4, 5, 8: For nonsurgical interventions, studies must evaluate use at home rather than in a laboratory or facility (although the testing and outcome assessments may occur in sleep laboratories or other settings) | KQs 4, 5, 8: For nonsurgical treatments, interventions studied only in laboratories (e.g., studies of CPAP conducted in sleep laboratories)
Screening | Screening with the Epworth Sleepiness Scale, STOP Questionnaire, Berlin Questionnaire, Wisconsin Sleep Questionnaire, or STOP-BANG Questionnaire Risk stratification or clinical prediction tools that include multiple factors (e.g., the Multivariable Apnea Prediction Index); may include findings from physical examination (e.g., neck circumference, Mallampati classification) KQ 2b: Combined screening approaches, which may use a questionnaire or clinical prediction tool followed by home-based testing for persons who score above a defined threshold on the questionnaire or clinical prediction tool | Studies assessing single patient characteristics or risk factors
Diagnostic testing | Polysomnography conducted in a sleep laboratory, reviewed and interpreted by a qualified physician (the reference standard) Portable monitors used for home-based testing (including Type II, III, and IV monitors) Home-based testing followed by polysomnography
Treatment/management interventions | CPAP, mandibular advancement devices, surgery, and weight loss programs Variations of fixed oral CPAP are eligible, including auto-titrating CPAP, nasal CPAP, bilevel CPAP, and humidification with CPAP | Atrial overdrive pacing, medications, palatal implants, oropharyngeal exercises, tongue-retaining devices, positional alarms, nasal dilator strips, acupuncture, auricular plaster, and all other interventions not listed as included Medications to treat sleepiness, sleep quality, or bruxism (rather than used to treat OSA), such as armodafinil, bromocriptine, donepezil, eszopiclone, and modafinil Nasal steroids for treatment of allergic rhinitis or similar treatments that might secondarily improve OSA by treating another condition Studies focusing on potential worsening of OSA caused by treatment for another condition (e.g., use of testosterone for hypogonadism, use of medications that may cause weight gain)
Comparisons | KQ 1: Screened vs. nonscreened groups KQ 2: Overnight polysomnography conducted in a sleep laboratory; studies may also determine or compare persons at increased, average, or decreased risk or persons at higher and lower risk for OSA KQ 3: Studies on accuracy of screening must include a comparison with polysomnography; studies on reliability of screening must include measures of reproducibility (e.g., test-retest, comparison between different laboratories or readers) KQs 4, 5, 8: CPAP vs. control or sham CPAP; mandibular advancement devices vs. no treatment or inactive mandibular advancement devices; surgery vs. sham, conservative treatment, or no treatment; and weight loss interventions vs. control KQ 6: Persons with a higher or lower AHI KQ 7: Screened vs. nonscreened groups or groups undergoing screening and/or diagnostic testing vs. groups not undergoing screening and/or diagnostic testing | No comparison; nonconcordant historical controls; comparative studies of various interventions (e.g., comparing CPAP with mandibular advancement devices or comparing different types of CPAP) KQs 2, 3: Studies with verification bias in which only a subgroup had polysomnography as the comparator
Outcomes | KQs 1, 5, 6: Mortality, quality of life (both disease-specific measures, such as the Functional Outcomes of Sleep Questionnaire, and general measures, such as the 36-Item Short-Form Health Survey), motor vehicle crashes, cardiovascular events (including ischemic events and rhythm disturbances, such as atrial fibrillation), cerebrovascular events, incidence of heart failure, headaches, cognitive impairment KQ 2: Sensitivity, specificity, discrimination, calibration KQ 3: Sensitivity and specificity; measures of reproducibility (e.g., test-retest, comparison between different laboratories or readers) KQ 4: Change in AHI, blood pressure, and daytime somnolence or sleepiness (e.g., as measured by the Epworth Sleepiness Scale or other validated measures) KQ 7: False-positive results leading to unnecessary treatment, anxiety, condition-specific distress, or stigma KQ 8: Rash, irritation, need for additional sleep medications (e.g., to tolerate CPAP), claustrophobia, oral or nasal dryness, epistaxis, pain, excess salivation, tooth damage or loosening, complications of surgery (e.g., perioperative death, hemorrhage, nerve palsy, additional emergency surgery, cardiovascular events, respiratory failure, rehospitalization, speech or voice changes, difficulty swallowing, airway stenosis)
Study designs | KQ 1: RCTs comparing screened vs. nonscreened groups KQ 2: Prospective cohort studies and cross-sectional studies that develop or evaluate screening questionnaires or clinical prediction tools Previously published systematic reviews (only for the purposes of identifying existing studies) Clinical prediction tools and screening questionnaires must be externally validated KQ 3: Good-quality, recent (within 5 years) systematic reviews comparing diagnostic tests with formal, attended polysomnography conducted in a sleep laboratory Primary studies published after the search cutoff of the most recent systematic review will be included (i.e., bridge searches will be performed to determine whether there is new evidence since the review and whether it is consistent with the review) KQs 4, 5: RCTs; previously published systematic reviews (only for the purposes of identifying existing studies) KQ 6: Good-quality, recent (within 5 years) systematic reviews; bridge searches will be performed to determine whether there is new evidence since the review and whether it is consistent with the review Prospective cohort studies that follow participants for at least 1 year and are published after the search cutoff of the most recent systematic review will be included Treatment studies included in KQ 4 or 5 that report both change in AHI and change in a health outcome KQ 7: Studies eligible for KQ 1, 2, or 3 that report harms of screening or diagnostic tests KQ 8: RCTs for all interventions; prospective cohort studies with at least 100 participants that report harms of surgical interventions | All other designs KQs 2, 3: Questionnaires, tools, and tests not validated in a group of participants separate from the sample used to develop the test
Language | English | Languages other than English

AHI = apnea-hypopnea index; CPAP = continuous positive airway pressure; KQ = Key Question; OSA = obstructive sleep apnea; RCT = randomized, controlled trial; RDI = respiratory disturbance index.

## Appendix B3 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized Controlled Trials

Criteria
- Initial assembly of comparable groups: Randomized controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: Equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

Definition of Ratings Based on Above Criteria

Good: | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
Poor: | Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

Sources: U.S. Preventive Services Task Force, Procedure Manual, Appendix VII http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual---appendix-vii

Harris et al., 2001^285^

### Studies of Screening Tests

Criteria
- Screening test relevant, available for primary care, adequately described.
- Study uses a credible reference standard, performed regardless of test results.
- Reference standard interpreted independently of screening test.
- Handles indeterminate results in a reasonable manner.
- Spectrum of patients included in study.
- Sample size: Although this is one of the criteria listed in the current procedures manual, we did not consider sample size when assessing study quality, as sample size affects precision of the estimate.
- Administration of reliable screening test.

In addition to the criteria listed in the USPSTF procedures manual, we also considered the criteria described in our Appendix D (which details quality assessments of individual studies).

Definition of Ratings Based on Above Criteria

Good: | Relevant and adequately described study populations for the outcome of interest (i.e., Sensitivity, Specificity), screening test well described in terms of test procedures followed and threshold used for a “positive” or “negative” test, credible reference standard used for outcome of interest (i.e., Sensitivity or Specificity), generally interprets reference standard independently of screening test, outcomes clearly reported and valid, handles indeterminate results in a reasonable manner.
Fair: | Mostly includes a relevant and adequately described study population for the outcome of interest (i.e., Sensitivity, Specificity), screening test described although may include some ambiguity about test procedures followed or threshold for a “positive” or “negative” test, credible reference standard mostly used for outcome of interest (i.e., Sensitivity or specificity), interpretation of reference standard may or may not be independent of screening test, outcomes mostly clearly reported although may have some ambiguity regarding how indeterminate results were handled.
Poor: | Has fatal flaw such as study population not appropriate for outcome of interest (i.e., Sensitivity, Specificity), screening test improperly administered or not at all described, use of noncredible reference standard, reference and screening test not independently assessed, outcomes not clearly or accurately reported with no information about how indeterminate tests were handled.

Criteria Adapted from: U.S. Preventive Services Task Force, Procedure Manual Appendix VII http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual---appendix-vii

Harris et al., 2001.^285^

## Appendix B4 Outcome Measures and Instruments

Abbreviated Name | Complete Name | Description | Range/Meaning of Possible Scores | Improvement Indicated by
BQ | Berlin Questionnaire | Questionnaire consists of 3 categories (10 questions total) related to the risk of having sleep apnea. | Patients can be classified into High Risk or Low Risk | NA (screening instrument)
ESS | Epworth Sleepiness Scale | 8-question measure of general level of daytime sleepiness or average sleep propensity in daily life | 0 to 24 | Decrease
EQ-5D | European Quality of Life Index | Assesses 5 dimensions of health status: mobility, self-care, usual activities, pain/discomfort and anxiety/depression; yields a single index value for health status | -0.1 to 1.0 | Increase
FOSQ and FOSQ-10 | Functional Outcomes of Sleep Questionnaire | Assesses the impact of disorders of excessive sleepiness on multiple activities of everyday living and the extent to which these abilities are improved by effective treatment (30- and 10-item versions) | 5 to 20 (both versions)^a^ | Increase
MCS | Mental Health Component Score of the SF-36 | Summary measure that aggregates 4 mental/emotional health domains | 0 to 100 (mean) | Increase
MVAP Score | Multivariable Apnea Prediction Score | Screening tool for sleep apnea based on the reporting of the frequency of various symptoms plus age, body mass index and gender | 0 to 1; risk increases as score increases | NA (screening instrument)
NHP | Nottingham health profile | 38-item instrument that measures subjective health status across the following domains: sleep, mobility, energy, pain, emotional reactions, social isolation | 0 to 100 | Decrease
PCS | Physical Health Component Score of the SF-36 | Summary measure that aggregates 4 physical health domains | 0 to 100 (mean) | Increase
SAQLI | Calgary Sleep Apnea Quality of Life Index | 35-item tool to assess OSA-related quality of life across 4 domains: daily functioning, social interactions, emotional functioning, symptoms. An optional 5^th^ domain assesses treatment-related symptoms | 1 to 7 | Increase
SF-36 | Medical Outcome Short Form (36) Health Survey (SF-36) | 36-item scale of patient health status. Administration time less than 15 minutes | 0 to 100 (mean) | Increase

a Most published studies determine the total score by calculating the mean of the 5 subscale scores (each subscale score ranges from 1 to 4) and multiplying by 5, giving a total score range of 5 to 20. However, some published studies report the mean of the subscale scores without multiplying by 5 (resulting in a total score range of 1 to 4) and others report the sum of all the individual responses (resulting in a total score range of 0 to 120).

Berlin Questionnaire

Epworth Sleepiness Scale

### Multivariable Apnea Prediction (MVAP) Index

“During the last month, have you had, or have been told about the following symptom”

(0) Never;

(1) Rarely, Less Than Once a Week;

(2) 1-2 Times Per Week;

(3) 3-4 Times Per Week;

(4) 5-7 Time Per Week

(.) Don't Know

Symptoms:

- Loud snoring
- Breathing cessation
- Snorting or gasping

Index 1 is the average of the 3 symptom scores.

The estimated probability that a patient will have an RDI ≥10 is:

Probability = ex/(l + ex)

where

x = -8.160 + 1.299-Index I + 0.163-BMI - 0.028-Index I-BMI + 0.032-Age + 1.278-Male,and Male = 1 if male and 0 if female.