# Appendix A Additional Background and Summary of Guidelines From Other Groups

## Prevalence

Reported estimates of the prevalence vary, likely because of variation in the definitions of obstructive sleep apnea (OSA) used (i.e., different apnea-hypopnea index [AHI] cutoffs), sampling biases, year of publication, or combinations of these factors.^31^ A recent systematic review estimated a prevalence range of 2 to 14 percent among four community-based studies^8^ after correcting for oversampling. Pooled estimates from the systematic review indicated a prevalence of 6 percent (95% confidence interval [CI], 3.7 to 8.3) for an AHI threshold of 15 and a prevalence of 14 percent (95% CI, 8.3 to 20) for an AHI threshold of 5. Sample sizes of the four included studies ranged from 360 to 1,741. Two of the four studies were conducted in the United States;^15,32^ the others were conducted in India and Norway. For the largest U.S.-based study (N=1,741),^32^ the estimated prevalence was 3.8 percent (95% CI, 2.9 to 9.8) using an AHI threshold of 15. The prevalence was higher among the subsample with obesity (almost 10%), was higher for men than women (6.6% vs. 1.8%), and increased with age (0.7% for ages 20 to 44, 5.6% for ages 45 to 64, and 8% for ages 65 to 100). For the other U.S.-based study (N=602, Wisconsin Sleep Cohort Study^15^ data published in 1993), the estimated prevalence was 6.5 percent (95% CI, 4.5 to 8.5) using an AHI threshold of 15 and 17 percent (95% CI, 14 to 21) using an AHI threshold of 5. The prevalence was higher for men than women (9.1% vs. 4.0% using an AHI threshold of 15 and 24% vs. 9% using an AHI threshold of 5). From the same study, the estimated prevalence for an OSA syndrome (AHI of at least 5 plus excessive daytime sleepiness) was 4 percent for men (95% CI, 2 to 6) and 2 percent for women (95% CI, 0.3 to 3.7).

We searched for estimates of how many people with mild, moderate, or severe OSA would be detected by screening, and we were only able to find some of the information. Specifically, estimates for those with mild OSA (AHI of at least 5 but <15) and those with moderate/severe (combining the two categories, with AHI of at least 15) are available. The systematic review described in the previous paragraph^8^ indicated that 8 percent of the population would have mild OSA and that 6 percent would have moderate or severe OSA. The two U.S.-based studies that were included found about 10 percent^15^ with mild OSA and 3.8^32^ to 6.5^15^ percent with moderate or severe OSA when using data from the 1990s; long-term followup from one of them estimated a 16 percent prevalence for mild OSA and 10 percent for moderate or severe OSA.^33^

Longitudinal epidemiological studies and modeling studies estimate that the prevalence of OSA is increasing, perhaps due to rising rates of obesity.^33,34^ Recent publications use data from the Wisconsin Sleep Cohort Study and statistical modeling to estimate current OSA prevalence. This approach found that the prevalence of OSA has increased over the last two decades.^33^ Data published in 2009 (N=1,500) and 2013 (N=1,520) reported a prevalence around 20 to 30 percent for men and 10 to 15 percent for women ages 30 to 70 years when using an AHI threshold of 5.^33,34^ When more stringent definitions are used, either combining an AHI of at least 5 with report of at least one symptom of disturbed sleep or using an AHI threshold of 15, the estimated prevalence was approximately 15 percent in men and 5 percent in women.^33,34^

Multiple cohort studies have found that OSA is approximately 2 to 3 times more common in men than women, although the gap narrows at the age of menopause in women.^15-17,35^ The prevalence of OSA appears to increase with age through the sixth to seventh decade and then plateaus.^14,16,17^ In both males and females, multiple epidemiological studies have found that the prevalence of OSA progressively increases as body mass index (BMI) increases. Using data from the Wisconsin Sleep Cohort Study, a prospective study of nearly 700 adults with 4-year longitudinal followup, the authors reported that a 10 percent increase in weight was associated with a six-fold increase in risk of incident OSA.^7^ In another study that used age- and BMI-specific OSA prevalence data from the Wisconsin Sleep Cohort Study combined with BMI population distributions from the U.S. National Health and Nutrition Examination Survey database, the estimated prevalence of OSA increased from 1990 to 2010 in every age group and BMI category studied, in some cases by as much as 50 percent.^33^ It is unclear whether the prevalence of OSA differs by race or ethnicity; most population-based studies in the United States have been conducted in select populations and have not sought to describe this relationship.^31,277^

## Burden

Patients with untreated, severe OSA have an increased risk of all-cause mortality. A 2011 comparative effectiveness review for the Agency for Healthcare Research and Quality (AHRQ) found high strength of evidence from four studies indicating that an AHI greater than 30 is an independent predictor of all-cause mortality.^1^ The review found two studies with some evidence of an association between AHI and incident diabetes but concluded that the association may be confounded by obesity, which may result in both OSA and diabetes.^1^ The authors concluded that evidence was insufficient for the association between AHI and other clinical outcomes.^1^

OSA has been associated with a wide range of other adverse health outcomes in various publications. However, there is some controversy in the literature regarding the extent to which OSA directly contributes to various adverse outcomes—above and beyond the contributions of age, BMI, and other potential confounders. One systematic review from the 1990s (including 54 epidemiological studies) examined the association between sleep apnea and health-related outcomes and concluded that most studies were poorly designed and found only weak or contradictory evidence for an association with cardiac arrhythmias, ischemic heart disease, cardiac failure, systemic or pulmonary hypertension, and stroke.^278^ In a systematic review of case-control and matched cohort studies, drivers with OSA had an increased risk of motor vehicle accidents (relative risk, 2.43; 95% CI, 1.21 to 4.89).^279^ However, the authors noted that most included studies were rated as low quality because of retrospective design, lack of adjustment for important confounders, and self-reported outcome or lack of independent outcome assessment and that there was significant statistical heterogeneity in results.^279^ Two recent systematic reviews of cohort studies found that people with OSA have increased risk of stroke, but the relationship between OSA and risk of ischemic heart disease is uncertain.^280,281^

Appendix A Table 1 Summary of Guidelines From Other Groups

Group, Year | Screening or Treatment? | Recommendations
American College of Physicians (ACP), 2013^76^ | Treatment | All overweight and obese patients diagnosed with OSA should be encouraged to lose weight. (strong recommendation; low-quality evidence) CPAP treatment as initial therapy for patients diagnosed with OSA. (strong recommendation; moderate-quality evidence) Mandibular advancement devices as an alternative therapy to CPAP treatment for patients diagnosed with OSA who prefer mandibular advancement devices or for those with adverse effects associated with CPAP treatment. (weak recommendation; low-quality evidence)
American Academy of Sleep Medicine (AASM), 2009^282^ | Screening | Routine health maintenance evaluations should include questions about OSA (e.g., history of snoring and daytime sleepiness), as well as an evaluation for the presence of obesity, retrognathia, and hypertension. Positive findings should trigger a comprehensive sleep evaluation. The diagnostic strategy includes a sleep-oriented history and physical examination, objective testing, and education of the patient. The presence or absence and severity of OSA must be determined before initiating treatment to identify those patients at risk of developing the complications of sleep apnea, guide selection of appropriate treatment, and provide a baseline to establish the effectiveness of subsequent treatment.
American Academy of Sleep Medicine (AASM), 2009^282^ | Treatment | Once the diagnosis is established, the patient should be included in deciding an appropriate treatment strategy that may include CPAP devices, oral appliances, behavioral treatments, surgery, and adjunctive treatments. OSA should be approached as a chronic disease requiring long-term, multidisciplinary management.
Institute for Clinical Systems Improvement (ICSI), 2008^283^ | Screening | Appropriately sensitive overnight oximetry (when combined with history and physical) can be a useful tool in screening patients with a high pretest probability of OSA and excluding patients with a low pretest probability of OSA. (Conclusion Grade II) Unattended sleep studies can be valuable tools in the diagnosis of OSA, providing an accurate and reliable AHI in patients with a high pretest probability, but they carry the following limitations: absence of trained technician means no one can enlist patient cooperation, they cannot make continuous patient observations, they cannot intervene for the medically unstable patient, and they cannot provide therapeutic intervention (i.e., CPAP, oxygen, supine positioning, resuscitation). (Conclusion Grade III)
National Institute for Health and Clinical Excellence (NICE), 2008^284^ | Screening | Moderate to severe obstructive sleep apnea hypopnea syndrome (OSAHS) can be diagnosed from patient history and a sleep study using oximetry or other monitoring devices carried out in the person's home. In some cases, further studies that monitor additional physiological variables in a sleep laboratory or at home may be required, especially when alternative diagnoses are being considered.
National Institute for Health and Clinical Excellence (NICE), 2008^284^ | Treatment | CPAP is recommended as a treatment option for adults with moderate or severe symptomatic OSAHS. CPAP is only recommended as a treatment option for adults with mild OSAHS if:; - they have symptoms that affect their quality of life and ability to go about their daily activities, and; - lifestyle advice and any other relevant treatment options have been unsuccessful or are considered inappropriate.; The diagnosis and treatment of OSAHS, and the monitoring of the response, should be carried out by a specialist service with appropriately trained medical and support staff.

Abbreviations: AASM=American Academy of Sleep Medicine; ACP=American College of Physicians; AHI=apnea-hypopnea index; CPAP=continuous positive airway pressure; ICSI=Institute for Clinical Systems Improvement; NICE=National Institute for Health and Clinical Excellence; OSA=obstructive sleep apnea; OSAHS=obstructive sleep apnea-hypopnea syndrome.