# References

1 National Institutes of Health, Eunice Kennedy Shriver National Institute of Child Health and Human Development. (2012). Neural Tube Defects (NTDs): Condition Information.
2 Centers for Disease Control and Prevention (CDC). (2010). CDC Grand Rounds: additional opportunities to prevent neural tube defects with folic acid fortification. MMWR Morb Mortal Wkly Rep.
3 National Institute of Neurological Disorders and Stroke. (2014). NINDS Anencephaly Information Page.
4 National Institute of Neurological Disorders and Stroke. (2012). Cephalic disorders fact sheet.
5 Rasmussen SA, Olney RS, Holmes LB, et al. (2003). Guidelines for case classification for the National Birth Defects Prevention Study. Birth Defects Res A Clin Mol Teratol.
6 Rasmussen SR, Frais JL. (2006). Genetics of syndromic neural tube defects. Wyszynski DF, editor. Neural Tube Defects: From Origin to Treatment.
7 Williams J, Mai CT, Mulinare J, et al. (2015). Updated estimates of neural tube defects prevented by mandatory folic acid fortification - United States, 1995-2011. MMWR Morb Mortal Wkly Rep.
8 (2003). American College of Obstetricians and Gynecologists. Neural tube defects. ACOG Practice Bulletin No. 44. Obstet Gynecol.
9 Agopian AJ, Tinker SC, Lupo PJ, et al. (2013). Proportion of neural tube defects attributable to known risk factors. Birth Defects Res A Clin Mol Teratol.
10 Elwood JM, Little J, Elwood JH. (1992). Epidemiology and control of neural tube defects.
11 Ahrens K, Yazdy MM, Mitchell AA, et al. (2011). Folic acid intake and spina bifida in the era of dietary folic acid fortification. Epidemiology.
12 van der Put NM, Eskes TK, Blom HJ. (1997). Is the common 677C-->T mutation in the methylenetetrahydrofolate reductase gene a risk factor for neural tube defects? A meta-analysis. QJM.
13 Tsang BL, Devine OJ, Cordero AM, et al. (2015). Assessing the association between the methylenetetrahydrofolate reductase (MTHFR) 677C>T polymorphism and blood folate concentrations: a systematic review and meta-analysis of trials and observational studies. Am J Clin Nutr.
14 Botto LD, Yang Q. (2000). 5,10-Methylenetetrahydrofolate reductase gene variants and congenital anomalies: a HuGE review. Am J Epidemiol.
15 van der Put NM, Steegers-Theunissen RP, Frosst P, et al. (1995). Mutated methylenetetrahydrofolate reductase as a risk factor for spina bifida. Lancet.
16 Shin M, Besser LM, Siffel C, et al. (2010). Prevalence of spina bifida among children and adolescents in 10 regions in the United States. Pediatrics.
17 Goldman P, Peppercorn MA. (1975). Drug therapy: sulfasalazine. N Engl J Med.
18 Williams LJ, Rasmussen SA, Flores A, et al. (2005). Decline in the prevalence of spina bifida and anencephaly by race/ethnicity: 1995-2002. Pediatrics.
19 Aneji CN, Northrup H, Au KS. (2012). Deep sequencing study of the MTHFR gene to identify variants associated with myelomeningocele. Birth Defects Res A Clin Mol Teratol.
20 Centers for Disease Control and Prevention (CDC). (2009). Racial/ethnic differences in the birth prevalence of spina bifida - United States, 1995-2005. MMWR Morb Mortal Wkly Rep.
21 Mitchell LE. (2005). Epidemiology of neural tube defects. Am J Med Genet C Semin Med Genet.
22 Suarez L, Hendricks KA, Cooper SP, et al. (2000). Neural tube defects among Mexican Americans living on the US-Mexico border: effects of folic acid and dietary folate. Am J Epidemiol.
23 Suarez L, Felkner M, Brender JD, et al. (2012). Neural tube defects on the Texas-Mexico border: what we've learned in the 20 years since the Brownsville cluster. Birth Defects Res A Clin Mol Teratol.
24 Hamner HC, Mulinare J, Cogswell ME, et al. (2009). Predicted contribution of folic acid fortification of corn masa flour to the usual folic acid intake for the US population: National Health and Nutrition Examination Survey 2001-2004. Am J Clin Nutr.
25 da Silva VR, Hausman DB, Kauwell GP, et al. (2013). Obesity affects short-term folate pharmacokinetics in women of childbearing age. Int J Obes (Lond).
26 McMahon DM, Liu J, Zhang H, et al. (2013). Maternal obesity, folate intake, and neural tube defects in offspring. Birth Defects Res A Clin Mol Teratol.
27 Flegal KM, Carroll MD, Kit BK, et al. (2012). Prevalence of obesity and trends in the distribution of body mass index among US adults, 1999-2010. JAMA.
28 Correa A, Gilboa SM, Botto LD, et al. (2012). Lack of periconceptional vitamins or supplements that contain folic acid and diabetes mellitus-associated birth defects. Am J Obstet Gynecol.
29 Dheen ST, Tay SS, Boran J, et al. (2009). Recent studies on neural tube defects in embryos of diabetic pregnancy: an overview. Curr Med Chem.
30 Yerby MS. (2003). Management issues for women with epilepsy: neural tube defects and folic acid supplementation. Neurology.
31 Shaer CM, Chescheir N, Schulkin J. (2007). Myelomeningocele: a review of the epidemiology, genetics, risk factors for conception, prenatal diagnosis, and prognosis for affected individuals. Obstet Gynecol Surv.
32 Chen CP. (2008). Syndromes, disorders and maternal risk factors associated with neural tube defects (VII). Taiwan J Obstet Gynecol.
33 Milunsky A, Ulcickas M, Rothman KJ, et al. (1992). Maternal heat exposure and neural tube defects. JAMA.
34 Parker SE, Mai CT, Canfield MA, et al. (2010). Updated National Birth Prevalence estimates for selected birth defects in the United States, 2004-2006. Birth Defects Res A Clin Mol Teratol.
35 (1998). Institute of Medicine (US) Standing Committee on the Scientific Evaluation of Dietary Reference Intakes and its Panel on Folate, Other B Vitamins, and Choline Dietary Reference Intakes for Thiamin, Riboflavin, Niacin, Vitamin B6, Folate, Vitamin B12, Pantothenic Acid, Biotin, and Choline.
36 Wolff T, Witkop CT, Miller T, et al. (2009). Folic Acid Supplementation for the Prevention of Neural Tube Defects: An Update of the Evidence for the U.S. Preventive Services Task Force.
37 Food and Drug Administration (FDA). (1996). Food standards: amendment of standards of identity for enriched grain products to require addition of folic acid. Final Rule. Fed Regist.
38 Honein MA, Paulozzi LJ, Mathews TJ, et al. (2001). Impact of folic acid fortification of the US food supply on the occurrence of neural tube defects. JAMA.
39 National Birth Defects Prevention Network. (2004). Neural tube defect ascertainment project 2010.
40 World Health Organization. (2015). Guideline: optimal serum and red blood cell folate concentrations in women of reproductive age for prevention of neural tube defects.
41 Shane B. (2011). Folate status assessment history: implications for measurement of biomarkers in NHANES. Am J Clin Nutr.
42 Crider KS, Devine O, Hao L, et al. (2014). Population red blood cell folate concentrations for prevention of neural tube defects: bayesian model. BMJ.
43 U.S. Department of Health and Human Services. (1996). Food standards: amendment of standards of identity for enriched grain products to require addition of folic acid. Fed Regist.
44 Yang Q, Cogswell ME, Hamner HC, et al. (2010). Folic acid source, usual intake, and folate and vitamin B-12 status in US adults: National Health and Nutrition Examination Survey (NHANES) 2003-2006. Am J Clin Nutr.
45 Tinker SC, Hamner HC, Qi YP, et al. (2015). U.S. women of childbearing age who are at possible increased risk of a neural tube defect-affected pregnancy due to suboptimal red blood cell folate concentrations, National Health and Nutrition Examination Survey 2007 to 2012. Birth Defects Res A Clin Mol Teratol.
46 Siega-Riz AM, Bodnar LM, Savitz DA. (2002). What are pregnant women eating? Nutrient and food group differences by race. Am J Obstet Gynecol.
47 Gahche J, Bailey R, Burt V, et al. (2011). Dietary supplement use among U.S. adults has increased since NHANES III (1988-1994). NCHS Data Brief.
48 Robbins CL, Zapata LB, Farr SL, et al. (2014). Core state preconception health indicators - pregnancy risk assessment monitoring system and behavioral risk factor surveillance system, 2009. MMWR Surveill Summ.
49 McDowell MA, Lacher DA, Pfeiffer CM, et al. (2008). Blood folate levels: the latest NHANES results. NCHS Data Brief.
50 Crider KS, Bailey LB, Berry RJ. (2011). Folic acid food fortification-its history, effect, concerns, and future directions. Nutrients.
51 Marchetta CM, Devine OJ, Crider KS, et al. (2015). Assessing the association between natural food folate intake and blood folate concentrations: a systematic review and Bayesian meta-analysis of trials and observational studies. Nutrients.
52 Daly LE, Kirke PN, Molloy A, et al. (1995). Folate levels and neural tube defects. Implications for prevention. JAMA.
53 Berry RJ, Li Z, Erickson JD, et al. (1999). Prevention of neural-tube defects with folic acid in China. China-U.S. Collaborative Project for Neural Tube Defect Prevention. N Engl J Med.
54 Hao L, Yang QH, Li Z, et al. (2008). Folate status and homocysteine response to folic acid doses and withdrawal among young Chinese women in a large-scale randomized double-blind trial. Am J Clin Nutr.
55 Crider KS, Zhu JH, Hao L, et al. (2011). MTHFR 677C->T genotype is associated with folate and homocysteine concentrations in a large, population-based, double-blind trial of folic acid supplementation. Am J Clin Nutr.
56 Chuang CH, Hillemeier MM, Dyer AM, et al. (2011). The relationship between pregnancy intention and preconception health behaviors. Prev Med.
57 Dott M, Rasmussen SA, Hogue CJ, et al. (2010). Association between pregnancy intention and reproductive-health related behaviors before and after pregnancy recognition, National Birth Defects Prevention Study, 1997-2002. Matern Child Health J.
58 Goldberg BB, Alvarado S, Chavez C, et al. (2006). Prevalence of periconceptional folic acid use and perceived barriers to the postgestation continuance of supplemental folic acid: survey results from a Teratogen Information Service. Birth Defects Res A Clin Mol Teratol.
59 Rosenberg KD, Gelow JM, Sandoval AP. (2003). Pregnancy intendedness and the use of periconceptional folic acid. Pediatrics.
60 Finer LB, Zolna MR. (2011). Unintended pregnancy in the United States: incidence and disparities, 2006. Contraception.
61 Robbins CL, Zapata LB, Farr SL, et al. (2014). Core state preconception health indicators - pregnancy risk assessment monitoring system and behavioral risk factor surveillance system, 2009. MMWR Surveill Summ.
62 Centers for Disease Control and Prevention. (2013). Preconception Care and Health Care.
63 Lynch MM, Squiers LB, Lewis MA, et al. (2014). Understanding women's preconception health goals: audience segmentation strategies for a preconception health campaign. Soc Mar Q.
64 Squiers L, Mitchell EW, Levis DM, et al. (2013). Consumers' perceptions of preconception health. Am J Health Promot.
65 Lewis MA, Mitchell EW, Levis DM, et al. (2013). Couples' notions about preconception health: implications for framing social marketing plans. Am J Health Promot.
66 Rofail D, Colligs A, Abetz L, et al. (2012). Factors contributing to the success of folic acid public health campaigns. J Public Health (Oxf).
67 March of Dimes. (2008). Improving Preconception Health: Women's Knowledge and Use of Folic Acid.
68 American College of Obstetricians and Gynecologists. (2005). The importance of preconception care in the continuum of women's health care.
69 Callegari LS, Ma EW, Schwarz EB. (2015). Preconception care and reproductive planning in primary care. Med Clin North Am.
70 American Congress of Obstetricians and Gynecologists. (2003). ACOG practice bulletin. Clinical management guidelines for obstetrician-gynecologists. Number 44, July 2003. (Replaces Committee Opinion Number 252, March 2001). Obstet Gynecol.
71 American Academy of Pediatrics, Committee on Genetics. (1999). Folic acid for the prevention of neural tube defects. Pediatrics.
72 Centers for Disease Control and Prevention. (1993). From the Centers for Disease Control and Prevention. Recommendations for use of folic acid to reduce number of spina bifida cases and other neural tube defects. JAMA.
73 American Academy of Family Physicians. (2009). Summary of Recommendations for Clinical and Preventive Services. Neural Tube Defects, Prevention, Folic Acid Supplementation, Women.
74 National Institute for Health and Care Excellence. (2008). NICE public health guidance: PH11 Maternal and child nutrition.
75 Quality Standards Subcommittee of the American Academy of Neurology. (1998). Practice parameter: management issues for women with epilepsy (summary statement). Report of the Quality Standards Subcommittee of the American Academy of Neurology. Epilepsia.
76 Sterne JAC, Hernán MA, Reeves BC, et al. ROBINS-I: a tool for assessing risk of bias in non-randomized studies of interventions. BMJ (Online).
77 Higgins JP, Altman DG, Gotzsche PC, et al. (2011). The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ.
78 Whiting P, Savovic J, Higgins JP, et al. (2016). ROBIS: A new tool to assess risk of bias in systematic reviews was developed. J Clin Epidemiol.
79 Harris RP, Helfand M, Woolf SH, et al. (2001). Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med.
80 West SL, Gartlehner G, Mansfield AJ, et al. (2010). Comparative Effectiveness Review Methods: Clinical Heterogeneity.
81 Czeizel AE, Dobo M, Vargha P. (2004). Hungarian cohort-controlled trial of periconceptional multivitamin supplementation shows a reduction in certain congenital abnormalities. Birth Defects Res A Clin Mol Teratol.
82 Shaw GM, Schaffer D, Velie EM, et al. (1995). Periconceptional vitamin use, dietary folate, and the occurrence of neural tube defects. Epidemiology.
83 Vollset SE, Gjessing HK, Tandberg A, et al. (2005). Folate supplementation and twin pregnancies. Epidemiology.
84 Goh YI, Bollano E, Einarson TR, et al. (2006). Prenatal multivitamin supplementation and rates of congenital anomalies: a meta-analysis. J Obstet Gynaecol Can.
85 Thompson SJ, Torres ME, Stevenson RE, et al. (2003). Periconceptional multivitamin folic acid use, dietary folate, total folate and risk of neural tube defects in South Carolina. Ann Epidemiol.
86 Wolff T, Witkop CT, Miller T, et al. (2009). Folic acid supplementation for the prevention of neural tube defects: an update of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med.
87 Mosley BS, Cleves MA, Siega-Riz AM, et al. (2009). Neural tube defects and maternal folate intake among pregnancies conceived after folic acid fortification in the United States. Am J Epidemiol.
88 Czeizel AE, Dudas I. (1992). Prevention of the first occurrence of neural-tube defects by periconceptional vitamin supplementation. N Engl J Med.
89 Czeizel AE. (1993). Prevention of congenital abnormalities by periconceptional multivitamin supplementation. BMJ.
90 Czeizel AE, Dudas I, Metneki J. (1994). Pregnancy outcomes in a randomised controlled trial of periconceptional multivitamin supplementation. Final report. Arch Gynecol Obstet.
91 Czeizel AE, Metneki J, Dudas I. (1994). The higher rate of multiple births after periconceptional multivitamin supplementation: an analysis of causes. Acta Genet Med Gemellol (Roma).
92 Czeizel AE. (1993). Controlled studies of multivitamin supplementation on pregnancy outcomes. Ann N Y Acad Sci.
93 Czeizel AE. (1998). Periconceptional folic acid containing multivitamin supplementation. Eur J Obstet Gynecol Reprod Biol.
94 Czeizel AE. (1996). Reduction of urinary tract and cardiovascular defects by periconceptional multivitamin supplementation. Am J Med Genet.
95 Hernandez-Diaz S, Werler MM, Walker AM, et al. (2001). Neural tube defects in relation to use of folic acid antagonists during pregnancy. Am J Epidemiol.
96 Mills JL, Rhoads GG, Simpson JL, et al. (1989). The absence of a relation between the periconceptional use of vitamins and neural-tube defects. National Institute of Child Health and Human Development Neural Tube Defects Study Group. N Engl J Med.
97 Milunsky A, Jick H, Jick SS, et al. (1989). Multivitamin/folic acid supplementation in early pregnancy reduces the prevalence of neural tube defects. JAMA.
98 Moore LL, Bradlee ML, Singer MR, et al. (2003). Folate intake and the risk of neural tube defects: an estimation of dose-response. Epidemiology.
99 Werler MM, Shapiro S, Mitchell AA. (1993). Periconceptional folic acid exposure and risk of occurrent neural tube defects. JAMA.
100 Bekkers MB, Elstgeest LE, Scholtens S, et al. (2012). Maternal use of folic acid supplements during pregnancy, and childhood respiratory health and atopy. Eur Respir J.
101 Crider KS, Cordero AM, Qi YP, et al. (2013). Prenatal folic acid and risk of asthma in children: a systematic review and meta-analysis. Am J Clin Nutr.
102 Haberg SE, London SJ, Stigum H, et al. (2009). Folic acid supplements in pregnancy and early childhood respiratory health. Arch Dis Child.
103 Kiefte-de Jong JC, Timmermans S, Jaddoe VW, et al. (2012). High circulating folate and vitamin B-12 concentrations in women during pregnancy are associated with increased prevalence of atopic dermatitis in their offspring. J Nutr.
104 Magdelijns FJ, Mommers M, Penders J, et al. (2011). Folic acid use in pregnancy and the development of atopy, asthma, and lung function in childhood. Pediatrics.
105 Martinussen MP, Risnes KR, Jacobsen GW, et al. (2012). Folic acid supplementation in early pregnancy and asthma in children aged 6 years. Am J Obstet Gynecol.
106 Whitrow MJ, Moore VM, Rumbold AR, et al. (2009). Effect of supplemental folic acid in pregnancy on childhood asthma: a prospective birth cohort study. Am J Epidemiol.
107 Granell R, Heron J, Lewis S, et al. (2008). The association between mother and child MTHFR C677T polymorphisms, dietary folate intake and childhood atopy in a population-based, longitudinal birth cohort. Clin Exp Allergy.
108 Yang L, Jiang L, Bi M, et al. (2015). High dose of maternal folic acid supplementation is associated to infant asthma. Food Chem Toxicol.
109 Wang T, Zhang HP, Zhang X, et al. (2015). Is folate status a risk factor for asthma or other allergic diseases?. Allergy Asthma Immunol Res.
110 Dunstan JA, West C, McCarthy S, et al. (2012). The relationship between maternal folate status in pregnancy, cord blood folate levels, and allergic outcomes in early childhood. Allergy.
111 Tinker SC, Cogswell ME, Devine O, et al. (2010). Folic acid intake among U.S. women aged 15-44 years, National Health and Nutrition Examination Survey, 2003-2006. Am J Prev Med.
112 Dietary Guidelines Advisory Committee. (2015). Scientific Report of the 2015 Dietary Guidelines Advisory Committee: Advisory Report to the Secretary of Health and Human Services.
113 Khodr ZG, Lupo PJ, Agopian AJ, et al. (2014). Preconceptional folic acid-containing supplement use in the national birth defects prevention study. Birth Defects Res A Clin Mol Teratol.
114 Centers for Disease Control and Prevention. (2012). Preconception health indicators among women--Texas, 2002-2010. MMWR Morb Mortal Wkly Rep.
115 Kim H, Cain R, Viner-Brown S, et al. (2011). Multivitamin use prior to pregnancy in Rhode Island. Med Health R I.
116 March of Dimes. (2008). Improving preconception health: women's knowledge and use of folic acid.
117 March of Dimes. (2009). Improving preconception health: knowledge and use of vitamins and folic acid among Spanish-language-dominant Hispanic women.
118 Bentley TG, Willett WC, Weinstein MC, et al. (2006). Population-level changes in folate intake by age, gender, and race/ethnicity after folic acid fortification. Am J Public Health.
119 Centers for Disease Control and Prevention (CDC). (2008). Use of supplements containing folic acid among women of childbearing age--United States, 2007. MMWR Morb Mortal Wkly Rep.
120 Centers for Disease Control and Prevention. (2007). Trends in folic acid supplement intake among women of reproductive age--California, 2002-2006. MMWR Morb Mortal Wkly Rep.
121 Correa A, Stolley A, Liu Y. (2000). Prenatal tea consumption and risks of anencephaly and spina bifida. Ann Epidemiol.
122 Parker SE, Yazdy MM, Tinker SC, et al. (2013). The impact of folic acid intake on the association among diabetes mellitus, obesity, and spina bifida. Am J Obstet Gynecol.
123 Kaplan JS, Iqbal S, England BG, et al. (1999). Is pregnancy in diabetic women associated with folate deficiency?. Diabetes Care.
124 Kim H, Lee YA, Hwang JY, et al. (2011). Relationship between body-mass index and serum folate concentrations in pregnant women: Mothers and Children's Environmental Health (MOCEH). FASEB J.
125 Jentink J, Bakker MK, De Jong-van Den Berg LTW. (2009). Effect of correct folic acid use on spina bifida in pregnancies exposed to valproic acid or carbamazepine in the Netherlands. Pharmacoepidemiol Drug Saf.
126 Jentink J, Bakker MK, Nijenhuis CM, et al. (2010). Does folic acid use decrease the risk for spina bifida after in utero exposure to valproic acid?. Pharmacoepidemiol Drug Saf.
127 Van Allen MI, Boyle E, Thiessen P, et al. (2006). The impact of prenatal diagnosis on neural tube defect (NTD) pregnancy versus birth incidence in British Columbia. J Appl Genet.
128 Kirke PN, Daly LE, Elwood JH. (1992). A randomised trial of low dose folic acid to prevent neural tube defects. The Irish Vitamin Study Group. Arch Dis Child.
129 Central Technical Co-Ordinating Unit. (2000). Multicentric study of efficacy of periconceptional folic acid containing vitamin supplementation in prevention of open neural tube defects from India. Indian J Med Res.
130 MRC Vitamin Study Research Group. (1991). Prevention of neural tube defects: results of the Medical Research Council Vitamin Study. Lancet.
131 De-Regil LM, Fernandez-Gaxiola AC, Dowswell T, et al. (2010). Effects and safety of periconceptional folate supplementation for preventing birth defects. Cochrane Database Syst Rev.
132 Lassi Zohra S, Salam Rehana A, Haider Batool A, et al. (2013). Folic acid supplementation during pregnancy for maternal health and pregnancy outcomes. Cochrane Database of Syst Rev.
133 Finer LB, Zolna MR. (2014). Shifts in intended and unintended pregnancies in the United States, 2001-2008. Am J Public Health.
134 Panel on Micronutrients, Subcommittees on Upper Reference Levels of Nutrients and of Interpretation and Use of Dietary Reference Intakes, and the Standing Committee on the Scientific Evaluation of Dietary Reference Intakes. (2001). Dietary Reference Intakes for Vitamin A, Vitamin K, Arsenic, Boron, Chromium, Copper, Iodine, Iron, Manganese, Molybdenum, Nickel, Silicon, Vanadium, and Zinc.
135 O'Keefe CA, Bailey LB, Thomas EA, et al. (1995). Controlled dietary folate affects folate status in nonpregnant women. J Nutr.
136 Herbert V. (1962). Experimental nutritional folate deficiency in man. Trans Assoc Am Physicians.
137 Eichner ER, Pierce HI, Hillman RS. (1971). Folate balance in dietary-induced megaloblastic anemia. N Engl J Med.
138 Hoffbrand AV, Newcombe BF, Mollin DL. (1966). Method of assay of red cell folate activity and the value of the assay as a test for folate deficiency. J Clin Pathol.
139 Varadi S, Abbott D, Elwis A. (1966). Correlation of peripheral white cell and bone marrow changes with folate levels in pregnancy and their clinical significance. J Clin Pathol.
140 Yoon PW, Rasmussen SA, Lynberg MC, et al. (2001). The National Birth Defects Prevention Study. Public Health Rep.
141 Bailey RL, Dodd KW, Gahche JJ, et al. (2010). Total folate and folic acid intake from foods and dietary supplements in the United States: 2003-2006. Am J Clin Nutr.
142 U.S. Department of Agriculture. (2015). Scientific Report of the 2015 Dietary Guidelines Advisory Committee. Appendix E-2: Supplementary Documentation to the 2015 DGAC Report.
143 Brown SB, Reeves KW, Bertone-Johnson ER. (2014). Maternal folate exposure in pregnancy and childhood asthma and allergy: a systematic review. Nutr Rev.
144 Abe M. (2014). Folic acid supplementation during pregnancy affects food allergy risk in offspring depending on parental allergies. Allergy.
145 Abe M. (2013). The effect of maternal folic acid intake during pregnancy on incidence of child food allergy. Allergy.
146 Abe M. (2015). The effect of folic acid supplementation before conception on the onset of food allergies in infants. Allergy.
147 Berry RJ, Kihlberg R, Devine O. (2005). Impact of misclassification of in vitro fertilisation in studies of folic acid and twinning: modelling using population based Swedish vital records. BMJ.
148 Botto LD, Erickson JD, Mulinare J, et al. (2002). Maternal fever, multivitamin use, and selected birth defects: evidence of interaction?. Epidemiology.
149 Bower C, Stanley FJ. (1989). Dietary folate as a risk factor for neural-tube defects: evidence from a case-control study in Western Australia. Med J Aust.
150 Bower C, Stanley FJ. (1992). Periconceptional vitamin supplementation and neural tube defects; evidence from a case-control study in Western Australia and a review of recent publications. J Epidemiol Community Health.
151 Brescianini S, Cotichini R, Nistico L, et al. (2012). Folic acid supplementation before conception and chance of a twin pregnancy: Preliminary results from an italian case-control study. Twin Res Hum Genet.
152 Carmichael SL, Yang W, Shaw GM. (2010). Periconceptional nutrient intakes and risks of neural tube defects in California. Birth Defects Res A Clin Mol Teratol.
153 Chandler AL, Hobbs CA, Mosley BS, et al. (2012). Neural tube defects and maternal intake of micronutrients related to one-carbon metabolism or antioxidant activity. Birth Defects Res A Clin Mol Teratol.
154 Charles D, Ness AR, Campbell D, et al. (2004). Taking folate in pregnancy and risk of maternal breast cancer. BMJ.
155 Charles DH, Ness AR, Campbell D, et al. (2005). Folic acid supplements in pregnancy and birth outcome: re-analysis of a large randomised controlled trial and update of Cochrane review. Paediatr Perinat Epidemiol.
156 Taylor CM, Atkinson C, Penfold C, et al. (2015). Folic acid in pregnancy and mortality from cancer and cardiovascular disease: further follow-up of the Aberdeen folic acid supplementation trial. J Epidemiol Community Health.
157 Czeizel AE, Vargha P. (2004). Periconceptional folic acid/multivitamin supplementation and twin pregnancy. Am J Obstet Gynecol.
158 Czeizel AE, Toth M, Rockenbauer M. (1996). Population-based case control study of folic acid supplementation during pregnancy. Teratology.
159 De Marco P, Merello E, Calevo MG, et al. (2011). Maternal periconceptional factors affect the risk of spina bifida-affected pregnancies: an Italian case-control study. Childs Nerv Syst.
160 Desoto MC, Hitlan RT. (2012). Synthetic folic acid supplementation during pregnancy may increase the risk of developing autism. J Pediatr Biochem.
161 Ericson A, Kallen B, Aberg A. (2001). Use of multivitamins and folic acid in early pregnancy and multiple births in Sweden. Twin Res.
162 Gildestad T, Nordtveit TI, Nilsen RM, et al. (2013). Maternal folic acid and multivitamin supplementation and risk of neural tube defects: a population-based registry study. Eur J Epidemiol.
163 Haberg SE. (2009). Folic acid supplements in pregnancy and respiratory health in early childhood. J Allergy Clin Immunol.
164 Kallen B. (2004). Use of folic acid supplementation and risk for dizygotic twinning. Early Hum Dev.
165 Kallen B. (2007). Congenital malformations in infants whose mothers reported the use of folic acid in early pregnancy in Sweden. A prospective population study. Congenit Anom (Kyoto).
166 Kondo A, Morota N, Date H, et al. (2015). Awareness of folic acid use increases its consumption, and reduces the risk of spina bifida. Br J Nutr.
167 Medveczky E, Puho E. (2004). Parental employment status and neural-tube defects and folic acid/multivitamin supplementation in Hungary. Eur J Obstet Gynecol Reprod Biol.
168 Mulinare J, Cordero JF, Erickson JD, et al. (1988). Periconceptional use of multivitamins and the occurrence of neural tube defects. JAMA.
169 Ohya Y, Yonemoto J, Ogata T, et al. (2011). Influence of environmental chemicals and drugs taken before and during pregnancy on onset of childhood asthma and eczema. Allergy.
170 Shaw GM, Nelson V, Carmichael SL, et al. (2002). Maternal periconceptional vitamins: interactions with selected factors and congenital anomalies?. Epidemiology.
171 Veeranki SP, Gebretsadik T, Dorris SL, et al. (2014). Association of folic acid supplementation during pregnancy and infant bronchiolitis. Am J Epidemiol.
172 Veeranki SP, Gebretsadik T, Mitchel EF, et al. (2014). Timing of prenatal folic acid supplementation and risk of allergic rhinitis in early childhood. Am J Respir Crit Care Med.
173 Di Renzo GC, Spano F, Giardina I, et al. (2015). Iron deficiency anemia in pregnancy. Womens Health (Lond Engl).
174 Locksmith GJ, Duff P. (1998). Preventing neural tube defects: the importance of periconceptional folic acid supplements. Obstet Gynecol.
175 Kallen BA, Olausson PO. (2002). Use of folic acid and delivery outcome: a prospective registry study. Reprod Toxicol.
176 Lumley J, Watson L, Watson M, et al. (2001). Periconceptional supplementation with folate and/or multivitamins for preventing neural tube defects. Cochrane Database Syst Rev.
177 Shaw GM, Rozen R, Finnell RH, et al. (1998). Maternal vitamin use, genetic variation of infant methylenetetrahydrofolate reductase, and risk for spina bifida. Am J Epidemiol.
178 Shaw GM, Todoroff K, Carmichael SL, et al. (2001). Lowered weight gain during pregnancy and risk of neural tube defects among offspring. Int J Epidemiol.
179 Shaw GM, Velie EM, Schaffer D. (1996). Risk of neural tube defect-affected pregnancies among obese women. JAMA.