# Acknowledgments

The authors acknowledge the following individuals for their contributions to this project: Iris Mabry-Hernandez, MD, and Tracy Wolff, MD, MPH, of AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; expert reviewers (Nancy Chescheir, MD, University of North Carolina at Chapel Hill; Anna Maria Siega-Riz, PhD, University of North Carolina at Chapel Hill; Kimberly D. Gregory, MD, MPH, Cedars-Sinai; Joe Leigh Simpson, MD, March of Dimes Foundation; and Lt. Col. Catherine Witkop, MD, MPH, Uniformed Services University); federal partner reviewers from the National Institute of Environmental Health Sciences, Eunice Kennedy Shriver National Institute of Child Health and Human Development, National Center on Birth Defects and Developmental Disabilities, and U.S. Department of Veterans Affairs; Evelyn Whitlock, MD, MPH, formerly of the Kaiser Permanente Research Affiliates EPC; and RTI–UNC EPC staff (Christiane Voisin, MSLS, librarian; Sharon Barrell, MA, editor; and Loraine Monroe, publications specialist).