# 3 Results

## Literature Search

We identified 5,786 unique records and assessed 757 full-text articles for eligibility (Figure 2). We excluded 691 studies for various reasons detailed in Appendix C and included 66 published articles (54 studies) of good or fair quality in our main analyses (Appendix D). All five studies^81-85^ that were included in the previous review^36,86^ were considered for the current review (Appendix E). Of these five studies, three^81-83^ were included in our main analyses, one^85^ was excluded due to wrong intervention, and one^84^ was excluded for high risk of bias. Of the 49 included studies, 20 studies^9,11,22,36,81,82,86-99^ addressed KQ 1a, three studies^11,82,87^ addressed KQ 1b, eight studies^11,22,82,87,96-99^ addressed KQ 1c, 20 articles^36,83,86,88-94,100-109^ addressed KQ 2a, and six studies^100-102,107,109,110^ addressed KQ 2b. Although we intended to limit studies of harms to folic acid supplementation only, the available evidence was mixed, so we elected to include studies of multivitamins as well. Details of the quality assessment of included studies and studies excluded based on poor quality are provided in Appendix D. Appendix F provides additional details on study characteristics.

Figure 2 Preferred Reporting of Systematic Review and Meta-Analysis (PRISMA) Tree

Figure 2 is a flow chart that summarizes the search and selection of articles: There were 5,879 references identified by searching PubMed (3,255), the Cochrane Library (666), and EMBASE (1,958). In addition, 3,271 references were identified by ClinicalTrials.gov (3,022), HSRProj (5), WHO ICTRP (116), NIH Reporter (127), hand searches (0), and suggestions from public comments (1). After removal of duplicate citations (3,364), the titles and abstracts of 5,786 references were screened for potential inclusion. Of these, 757 were deemed appropriate for full-text review to determine eligibility. After full-text review, 691 were excluded: 270 for wrong publication type/not original research, 28 for wrong population, 15 for wrong comparator, 124 for wrong outcome, 2 for wrong timing, 36 for wrong geographical setting, 44 for wrong study design, 98 for wrong intervention, 1 for wrong sample size, 68 for wrong language/non-English, and 5 that were irretrievable. 66 articles representing 54 studies are included in this report's qualitative synthesis. 34 articles representing 30 studies were excluded for high or unclear risk of bias. 32 articles representing 24 studies were included in the quantitative analyses.

## Results

### KQ 1a Effect of Folic Acid Supplementation on NTDs in Women of Childbearing Age

#### Overview

We found a total of 20 publications on the benefits of folic acid supplementation. Seven publications present results of the only eligible RCT.^88-94^ The trial, conducted in Hungary, is an RCT that was initiated in 1984 and terminated in 1992, with information collected through 1993. Three publications relate to two cohort studies; one was a Hungarian cohort study of women recruited between 1993 and 1996,^81^ and the second was a cohort drawn from women who underwent alpha-fetoprotein screening or amniocentesis between 1984 and 1987.^97,98^ All other studies were case-control studies and compared NTD cases with nonmalformed infants^9,11,22,82,87, 96^ or infants with non-NTD malformations.^95,99^ Additionally, we drew on information from two publications in the previous update.^36,86^

We present information from the RCT first, followed by the cohort studies and the case-control studies. Although the RCT and the cohort studies potentially offer greater control for potential sources of bias, they predate mandatory food fortification. The case-control studies span a period ranging from 1976 through 2008, including several relying exclusively on data collected after food fortification. Because these eight publications of case-control data draw from related, or in some cases, subsets of the same data, we present them by the broadest data source first (national or multistate followed by two-state or single-state studies) and recency of data collection within each section. Table 3 provides supporting descriptions of each study. Tables 4 and 5 provide results. Because of the heterogeneity across studies and the differences in food fortification over time, we did not pool the results.

Table 3 Study Characteristics of Studies on the Effect of Folic Acid Supplementation on Neural Tube Defects

Author Study Name Design Risk of Bias | Population | Intervention | Timing Setting
Czeizel et al, 1992^88^ Czeizel et al, 1993^89^ Czeizel et al, 1994^90^ Czeizel et al, 1994^91^ Czeizel et al, 1993^92^ Czeizel et al, 1996^94^ Czeizel et al, 1998^93^ Hungarian RCT RCT Medium (fair quality) | Women planning a pregnancy without any delayed conception or infertility and not currently pregnant | G1: Vitamin supplement (0.8 folic acid and 12 vitamins, 4 minerals, 3 trace elements)^93^ (n=2,793) G2: Trace-element supplement (copper, manganese, zinc, low dose of vitamin C)^94^ (n=2,660) | 28 days before conception and at least until the date of the second missed menstrual period.^91^ HPS began 3 months before a pregnancy is planned and continues for the first 3 months after conception. HPS provided information and counseling, examinations, and interventions during all trimesters by qualified nurses.
Czeizel et al, 2004^81^ Hungarian Cohort Cohort Medium (fair quality) | Women planning a pregnancy without any delayed conception or infertility and not currently pregnant | G1: Women supplemented with multivitamin (n=3,056) G2: Nonsupplemented women (n=3,056) | Before conception and at least until first missed menstrual period. Supplemented cohort was recruited from the HPS. HPS provides information and counseling, examinations, and interventions during all trimesters by qualified nurses. Unsupplemented cohort was recruited during their first visit at an antenatal care clinic.
Milunsky et al, 1989^97^ Moore et al, 2003^98^ Cohort Medium (fair quality) | Women undergoing MSAFP screen or an amniocentesis | G1: Use of multivitamins containing folic acid G2: No use of multivitamins containing folic acid (or use less than 1 a week) Total: (n=22,715, multivitamin use information available) | 3 months prior to pregnancy through 1st 3 months of pregnancy. Women were identified and recruited when they had a MSAFP screen or an amniocentesis at 16 weeks of pregnancy between October 1984 and June 1987. Women were receiving prenatal care and routine MSAFP screening in the practices of over 100 participating obstetricians.
Agopian et al, 2013^9^ National Birth Defects Prevention Study Case-control Medium (fair quality) | Mothers with and without pregnancies affected by birth defects | G1: Spina bifida or anencephaly live births, fetal deaths, and elective pregnancy terminations (n=1,239) G2: Live-born controls without major birth defects (n=8,494) | Folic acid supplementation before pregnancy through 1st month of pregnancy. Population-based surveillance systems in 10 states. Data collected from medical records, birth certificate data, or hospital birth logs.
Mosley et al, 2009^87^ National Birth Defects Prevention Study Case-control Medium (fair quality) | Mothers with and without pregnancies affected by birth defects | G1: Spina bifida or anencephaly live births, fetal deaths, and elective pregnancy terminations (n=565) G2: Live-born controls without major birth defects (n=3,691) | Folic acid supplementation before pregnancy through 1st month of pregnancy. Population-based surveillance systems in 10 states. Data collected from medical records, birth certificate data, or hospital birth logs.
Ahrens et al, 2011^11^ Slone Birth Defects Study Case-control Medium (fair quality) | Mothers with and without pregnancies affected by birth defects | G1: Malformed live-born infants, therapeutic abortions after 12 weeks' gestation, and fetal deaths after 20 weeks' gestation (n=205) G2: Live-born nonmalformed infants (n=6,357) | Folic acid supplementation 2 months before the last menstrual period and 1 month after last menstrual period. Cases identified from discharge records of participating hospitals serving the areas surrounding Boston, MA; Philadelphia, PA; San Diego, CA; and Toronto, Canada and through birth defect registries in Massachusetts and New York State. Nonmalformed controls selected each month from study hospitals' discharge lists or from statewide birth records.
Hernandez-Diaz et al, 2001^95^ Slone Birth Defects Study Case-control Medium (fair quality) | Mothers of malformed children | G1: Cases with NTDs (spina bifida, anencephaly, and encephalocele, or other NTDs) (n=1,242 ) G2: Infants with malformations not related to vitamin supplementation (n=6,660 ) | Any time during the 2 months after the last menstrual period. Participants of the Slone Epidemiology Unit Birth Defects Study. Study interviewed mothers of malformed children born in the greater metropolitan areas of Boston, MA; Philadelphia, PA; Toronto, Canada; and between 1983 and 1985, part of the state of Iowa. Subjects identified through review of admissions and discharges at major referral hospitals and clinics and through regular contact with newborn nurseries in community hospitals. A random sample of nonmalformed infants was identified at the birth hospitals as potential controls (only after 1993).
Werler et al, 1993^99^ Case-control Slone Birth Defects Study Medium (fair quality) | Mothers with NTD-affected pregnancies and mothers with pregnancies affected by other major malformations | G1: Live-born, stillborn infants, and therapeutic abortions with anencephaly, spina bifida, or encephalocele (n=436) G2: Live-born, stillborn infants, and therapeutic abortions with other major malformations (n=2,615) | Periconceptional period (interval from 28 days before the LMP through the 28 days after the LMP) (the first lunar month). Study subjects recruited from tertiary and birth hospitals in greater metropolitan Boston, MA; Philadelphia, PA; and Toronto, Ontario. Primary physicians of potential subjects were asked for permission to contact mothers.
Suarez et al, 2000^22^ Texas Department of Health's Neural Tube Defect Project Medium (fair quality) | Mothers with and without NTD-affected pregnancies | G1: Infants or fetuses who had anencephaly (including craniorachischisis and iniencephaly), spina bifida, or encephalocele identified at birth or prenatally (n=148) G2: Normal live births (n=158) | 3 months before conception to 3 months after conception. Texas Department of Health's Neural Tube Defect Project, occurrence of NTDs in 14 Texas counties along the U.S.-Mexico border identified at birth or prenatally between January 1995 and February 1999. Surveillance included hospitals, birthing centers, genetics clinics, ultrasound centers, licensed abortion centers, and approximately 150 midwives in the region.
Shaw et al, 1995^82^ California Birth Defects Monitoring Program Case-control Medium (fair quality) | Mothers with and without singleton pregnancies affected by reportable birth defects | G1: Singleton live-born infants and electively terminated fetuses with an NTD (anencephaly, spina bifida cystic, craniorhachischisis, and iniencephaly) (n=538) G2: Singleton live births without a reportable birth defect (n=539) | 3 months before pregnancy and/or first 3 months after conception. CBDMP, birth years between June 1, 1989 and May 31, 1991. Cases were women who had live-born and stillborn infants with NTDs and those who had NTD-affected pregnancies that were terminated after prenatal diagnosis (February 1, 1989–January 31, 1991). Controls were an equal number of singleton live births randomly selected in proportion to hospital's contributions to total population of infants born alive in CA.
Mills et al, 1989^96^ National Institute of Child Health and Human Development Neural Tube Defects Study (data from California and Illinois) Case-control Medium (fair quality) | Mothers with and without pregnancies affected by birth defects | G1: Cases, mothers of an infant or fetus with an NTD (n= 571) G2: Controls, mothers of normal infants (n=573) G3: Controls, mothers of an abnormal or stillborn infant or fetus (n=546) | Vitamin use 30 days before the first day of LMP and ending approximately 45 days thereafter. Study based in CA and IL. Cases included mothers of an infant or fetus with an NTD diagnosis prenatally or postnatally between June 15, 1985, and April 30, 1987, in IL or between August 1, 1985, and April 30, 1987, in CA.

Abbreviations: CBDMP=California Birth Defects Monitoring Program; G=group; HPS=Hungarian Preconceptional Service; LMP=last menstrual period; MSAFP=maternal serum alpha-fetoprotein; n=number; NTD=neural tube defect; RCT=randomized, controlled trial.

Table 4 Results of Prospective Studies on the Effect of Folic Acid Supplementation on Neural Tube Defects

First Author, Year Design Risk of Bias | Interventions | Timing of Measurement of Exposure | Outcome | Comparison | Period of Exposure | Odds Ratio (95% CI) | N | Adjustments
Czeizel et al, 1992^88^ Czeizel et al, 1993^89^ Czeizel et al, 1994^90^ Czeizel et al, 1994^91^ Czeizel et al, 1993^92^ Czeizel et al, 1996^94^ Czeizel et al, 1998^93^ RCT Medium (fair quality) | Vitamin supplement (0.8 folic acid and 12 vitamins, 4 minerals, 3 trace elements) Trace element supplement (copper, manganese, zinc, low dose of vitamin C) | Prospective, confirmed by (1) asking women; (2) checking women's record of supplement use, recorded daily with basal body temperatures; and (3) checking boxes of supplements for unused tablets | Live births, termination in the second trimester following prenatal diagnosis, and stillbirths with NTD | Live births, terminations in the second trimester following prenatal diagnosis, and stillbirths without NTD | 1984–1992 | (Peto) 0.131 (0.026–0.648) | Cases in exposed arm: 0 Cases in control arm: 6 N in exposed arm: 2,471 N in control arm: 2,391 | None
Czeizel et al, 2004^81^ Cohort Medium (fair quality) | Vitamin supplement (0.8 folic acid and 12 vitamins, 4 minerals, 3 trace elements) No supplement | Prospective, confirmed by (1) asking women; (2) checking women's record of supplement use, recorded daily with basal body temperatures; and (3) checking boxes of supplements for unused tablets | Live births, terminations in the second or third trimester following prenatal diagnosis, and stillbirths (late fetal death after 28th week of gestation and/or weighing >1,000 g) with NTD | Live births, terminations in the second or third trimester following prenatal diagnosis, and stillbirths (late fetal death after 28th week of gestation and/or weighing >1,000 g) without NTD | 1993–1996 | 0.11 (0.01–0.91) | Cases in exposed arm:1 Cases in control arm: 9 N in exposed arm: 3,056 N in control arm: 3,056 | Birth order (first or second and more), chronic maternal disorder, and history of previous unsuccessful pregnancies including fetal death or congenital abnormalities in fetuses or newborn infants
Milunsky et al, 1989^97^ Moore et al, 2003^98^ Cohort Medium (fair quality) | Multivitamins containing folic acid weeks 1-6 No multivitamins or multivitamins not containing folic acid weeks 7 and onward | Interviewed at the time that the laboratory received the alpha-fetoprotein or amniocentesis test (15–20 weeks of pregnancy) | NTD, defined as spina bifida, anencephaly, or encephalocele alone or in combination with other defects from pregnancy outcome data ascertained through questionnaires to delivering physician or mothers (for nonresponsive physician) | No NTD | 1984–1987 | 0.27 (0.11–0.63) | Cases in exposed arm: 10 Cases in control arm: 11 N in exposed arm: 10,713 N in control arm: 3,157 | None
Milunsky et al, 1989^97^ Moore et al, 2003^98^ Cohort Medium (fair quality) | Multivitamins containing folic acid weeks 7 and beyond No multivitamins or multivitamins not containing folic acid weeks 7 and onward | Interviewed at the time that the laboratory received the alpha-fetoprotein or amniocentesis test (15–20 weeks of pregnancy) | NTD, defined as spina bifida, anencephaly, or encephalocele alone or in combination with other defects from pregnancy outcome data ascertained through questionnaires to delivering physician or mothers (for nonresponsive physician) | No NTD | 1984–1987 | 0.92 (0.45–1.87) | Cases in exposed arm: 25 Cases in control arm: 11 N in exposed arm: 7,795 N in control arm: 3,157 | None

Abbreviations: CI=confidence interval; N=number; NTD=neural tube defect.

Table 5 Results of Retrospective Studies on the Effect of Folic Acid Supplementation on Neural Tube Defects

Author Design Risk of Bias | Intervention Comparison | Timing of Measurement of Exposure | Outcome | Comparison | Period of Exposure | Odds Ratio (95% CI) | N | Adjustments
Agopian et al, 2013^9^ Case-control Medium (fair quality) | Any folic acid supplement (folic acid, multivitamin, or prenatal supplement) during the month before pregnancy and the first month of pregnancy No supplements during the month before pregnancy and the first month of pregnancy | Interviews are targeted for completion within 6 months of the EDD but must be completed no earlier than 6 weeks and no later than 24 months after the EDD. | Spina bifida or anencephaly live births, fetal deaths, and elective pregnancy terminations | Live-born controls without major birth defects | 1997–2007 | 0.93 (0.82–1.06) | Cases: 1,239 N exposed: 617 N not exposed: 619 Controls: 8,494 N exposed: 4,293 N not exposed: 4,167 | Body mass index ≥30.0, low dietary folate intake, anticonvulsant medication use, female infant sex, family history of NTDs in a first- or second-degree relative, maternal Hispanic ethnicity
Mosley et al, 2009^87^ Case-control Medium (fair quality) | Consistent use (taking supplements at least half the number of days, ≥60 days, from 3 months before pregnancy to the first month of pregnancy) No supplements during the month before pregnancy and the first month of pregnancy | Interviews are targeted for completion within 6 months of the EDD but must be completed no earlier than 6 weeks and no later than 24 months after the EDD. | Anencephaly live births, fetal deaths, and elective pregnancy terminations | Live-born controls without major birth defects | 1998–2003 | 1.2 (0.8–1.9) | Cases: 180 N exposed: 38 N not exposed: 81 Controls: 3,691 N exposed: 965 N not exposed: 1,778 | Maternal race and education
Mosley et al, 2009^87^ Case-control Medium (fair quality) | Consistent use (taking supplements at least half the number of days, ≥60 days, from 3 months before pregnancy to the first month of pregnancy) No supplements during the month before pregnancy and the first month of pregnancy | Interviews are targeted for completion within 6 months of the EDD but must be completed no earlier than 6 weeks and no later than 24 months of the EDD. | Spina bifida live births, fetal deaths, and elective pregnancy terminations | Live-born controls without major birth defects | 1998–2003 | 1.4 (1.0–1.8) | Cases: 385 N exposed: 97 N not exposed: 188 Controls: 3,691 N exposed: 965 N not exposed: 1,778 | Maternal race, BMI, and pregnancy
Mosley et al, 2009^87^ Case-control Medium (fair quality) | Initiating supplement use in the first month of pregnancy No supplement use during the month before pregnancy and the first month of pregnancy | Interviews are targeted for completion within 6 months of the EDD but must be completed no earlier than 6 weeks and no later than 24 months of the EDD. | Anencephaly live births, fetal deaths, and elective pregnancy terminations | Live-born controls without major birth defects | 1998–2003 | 1.7 (1.2–2.4) | Cases: 180 N exposed: 61 N not exposed: 81 Controls: 3,691 N exposed: 948 N not exposed: 1,778 | Maternal race and education
Mosley et al, 2009^87^ Case-control Medium (fair quality) | Initiating supplement use in the first month of pregnancy No supplementation during the month before pregnancy and the first month of pregnancy | Interviews are targeted for completion within 6 months of the EDD but must be completed no earlier than 6 weeks and no later than 24 months of the EDD. | Spina bifida live births, fetal deaths, and elective pregnancy terminations | Live-born controls without major birth defects | 1998–2003 | 1.1 (0.9–1.5) | Cases: 385 N exposed: 100 N not exposed: 188 Controls: 3,691 N exposed: 948 N not exposed: 1,778 | Maternal race, BMI, and pregnancy
Ahrens et al, 2011^11^ Case-control Medium (fair quality) | Consistent users of prenatal vitamins, multivitamins, and folic acid supplements (≥4 days per week at least 2 of 3 periconceptional months) No folic acid supplement use (<1 day per month, or use only during LM-2) | Interviews conducted within 6 months of delivery | Malformed live-born infants, therapeutic abortions after 12 weeks' gestation, and fetal deaths after 20 weeks' gestation | Live-born nonmalformed infants | 1998–2008 | 1.11 (0.74–1.65) | Cases: 205 N exposed: 83 N not exposed: 59 Controls: 6,357 N exposed: 2,573 N not exposed: 1,438 | Race, BMI, pregnancy intent, and study center
Ahrens et al, 2011^11^ Case-control Medium (fair quality) | Early pregnancy initiators of prenatal vitamins, multivitamins, and folic acid supplements (≥4 days per week beginning in first or second postconceptional months) No folic acid supplement use (<1 day per month, or use only in LM-2) | Interviews conducted within 6 months of delivery | Malformed live-born infants, therapeutic abortions after 12 weeks' gestation, and fetal deaths after 20 weeks' gestation | Live-born nonmalformed infants | 1998–2008 | 0.79 (0.54–1.16) | Cases: 205 N in exposed: 60 N not exposed: 59 Controls: 6,357 N exposed: 2,293 N not exposed: 1,438 | Race, BMI, pregnancy intent, and study center
Ahrens et al, 2011^11^ Case-control Medium (fair quality) | Inconsistent users of prenatal vitamins, multivitamins, and folic acid supplements (use patterns not defined as consistent), early pregnancy or nonuse No folic acid supplement use (<1 day per month, or use only during LM-2) | Interviews conducted within 6 months of delivery | Malformed live-born infants, therapeutic abortions after 12 weeks' gestation, and fetal deaths after 20 weeks' gestation | Live-born nonmalformed infants | 1998–2008 | 2.20 (0.64–7.62) | Cases: 205 N in exposed: 3 N not exposed: 59 Controls: 6,357 N exposed: 53 N not exposed: 1,438 | Race, BMI, pregnancy intent, and study center
Hernandez-Diaz et al, 2001^95^ Case-control Medium (fair quality) | Folic acid during the 2 months after LMP No folic acid use | Interviews conducted within 6 months of delivery | Live-born and stillborn infants and therapeutic abortions with NTD (anencephaly, spina bifida, encephalocele, or other NTD); stillbirths and therapeutic abortions included from 1988 onward | Malformations other than NTDs | 1976–1998 | 0.7 (0.5–0.8) | Cases: 1,242 N exposed: 140 N not exposed: 715 Controls: 6,660 N exposed: 939 N not exposed: 3,695 | Interview year, region, maternal age, education, weight before pregnancy, and urinary tract infections or other infections early in pregnancy
Werler et al, 1993^99^ Case-control Medium (fair quality) | Daily use in the periconceptional period (28 days before LMP through 28 days after LMP) No folic acid use | Interviews conducted within 6 months of delivery | Live-born and stillborn infants and therapeutic abortions with NTD (anencephaly, spina bifida, or encephalocele) | Other major malformations | 1988–1991 | 0.6 (0.4–0.8) | Cases: 436 N exposed: 34 N not exposed: 250 Controls: 2,615 N exposed: 339 N not exposed: 1,253 | Maternal age, maternal education, annual family income, birth status
Suarez et al, 2000^22^ Case-control Medium (fair quality) | Daily use in every month in the preconception period (≤3 months before conception) No folic acid use | Interviews were conducted approximately 1 month postpartum | Infants or fetuses who had anencephaly, spina bifida, or encephalocele identified at birth or prenatally | Control, normal live births | 1995–1999 | 0.77 (0.17–3.59) | Cases: 148 N exposed: 3 N not exposed: 66 Controls: 158 N exposed: 4 N not exposed: 68 | None
Suarez et al, 2000^22^ Case-control Medium (fair quality) | Daily use in every month in the preconception period (≤3 months before conception) No folic acid use | Interviews were conducted approximately 1 month postpartum | Infants or fetuses who had anencephaly, spina bifida, or encephalocele identified at birth or prenatally | Control, normal live births | 1995–1999 | 1.12 (0.22–5.78) | Cases: 148 N exposed: 3 N not exposed: 66 Controls: 158 N exposed: 4 N not exposed: 68 | Maternal age, education, obesity, and previous stillbirth or miscarriage
Suarez et al, 2000^22^ Case-control Medium (fair quality) | Any use in every month in the preconception period (≤3 months before conception) No folic acid use | Interviews were conducted approximately 1 month postpartum | Infants or fetuses who had anencephaly, spina bifida, or encephalocele identified at birth or prenatally | Control, normal live births | 1995–1999 | 1.65 (0.51–5.30) | Cases: 148 N exposed: 8 N not exposed: 66 Controls: 158 N exposed: 5 N not exposed: 68 | None
Suarez et al, 2000^22^ Case-control Medium (fair quality) | Post conception period (≤3 months after conception) No folic acid use | Interviews were conducted approximately 1 month postpartum | Infants or fetuses who had anencephaly, spina bifida, or encephalocele identified at birth or prenatally | Control, normal live births | 1995–1999 | 0.90 (0.57–1.42) | Cases: 148 N exposed: 74 N not exposed: 66 Controls: 158 N exposed: 85 N not exposed: 68 | None
Shaw et al, 1995^82^ Case-control Medium (fair quality) | Vitamin supplements containing folic acid in the 3 months before conception No folic acid use | Interviews conducted an average of 5 months after delivery | Cases: Singleton live-born infants and electively terminated fetuses with an NTD (anencephaly, spina bifida cystic, craniorhachischisis, and iniencephaly) | Singleton live births without a reportable birth defect | 1989–1991 | 0.65 (0.45–0.94) | Cases: 538 N exposed: 88 N not exposed: 207 Controls: 539 N exposed: 98 N not exposed: 149 | None
Shaw et al, 1995^82^ Case-control Medium (fair quality) | Vitamin supplements containing folic acid in the 3 months after conception (assuming women who started in period before conception continued) No folic acid use | Interviews conducted an average of 5 months after delivery | Cases: Singleton live-born infants and electively terminated fetuses with an NTD (anencephaly, spina bifida cystic, craniorachischisis, and iniencephaly) | Singleton live births without a reportable birth defect | 1989–1991 | 0.60 (0.46–0.79) | Cases: 538 N exposed: 322 N not exposed: 207 Controls: 539 N exposed: 384 N not exposed: 149 | None
Mills et al, 1989^96^ Case-control Medium (fair quality) | Vitamin supplements containing folic acid (exposure defined as taking supplements containing the RDA of at least 4 vitamins or a higher dose ≥6 days per week) None | Interviews were conducted no more than 3 months after delivery | NTDs including anencephaly, meningocele, myelomengocele, encephalocele, rachischisis, iniencephaly, and lipomeningocele | Controls, mothers of normal infants | 1985–1987 | 1.00 (0.73–1.40) | Cases: 565 N exposed: 86 N not exposed: 464 Controls: 567 N exposed: 84 N not exposed: 456 | None

Abbreviations: BMI=body mass index; CI=confidence interval; EDD=expected date of delivery; LM-2=2 months before last menstrual period; LMP=last menstrual period; N=number; NTD=neural tube defect.

#### Study Characteristics of the Included RCT

One RCT, described in seven publications,^88-94^ randomized women to a vitamin supplement containing folic acid (0.8 mg folic acid and 12 vitamins, four minerals, and three trace elements) or a trace-element supplement (copper, manganese, zinc, and a low dose of vitamin C). Women started the supplement at least 28 days before conception and continued at least until the date of the second missed menstrual period.^91^ The trial, as part of the Hungarian Optimal Family Planning Programme, excluded women with delayed conception and infertility or with ongoing pregnancies. For the first 4 years, the program also excluded women older than age 35 years or with a prior wanted pregnancy.^90^ The trial involved repeated contact with women at regular intervals. Women were asked to visit the clinic immediately after the first missed menstrual period. The staff administered a sensitive serum pregnancy test, followed within 2 weeks by an ultrasound.^93^ As a result, the authors note that they had “nearly total ascertainment of unsuccessful pregnancy outcomes, including fetal deaths and malformations.”^93^ The trial included only “informative” cases in the analysis; that is, live births, terminations in the second trimester, and stillbirths (late fetal deaths). It did not account for loss to followup, which constituted 0.9 percent of each arm (26 cases of 2,819 confirmed pregnancies in the multivitamin arm and 23 cases of 2,863 confirmed pregnancies in the trace-element supplement arm), or loss due to first-trimester losses, chemical pregnancy, ectopic pregnancy, or miscarriage (395 cases [14%] in the multivitamin arm and 504 cases [17.6%] in the trace-element supplement arm).

The trialists ascertained compliance with the supplement by 1) asking women; 2) checking women's record of supplement use, recorded daily with basal body temperatures; and 3) checking boxes of supplements for unused tablets.^90^ Women who became pregnant before starting the supplement or during the first month were considered unsupplemented and were referred to prenatal care immediately. Women who became pregnant after a period of supplementation were referred at 12 weeks to prenatal care.

#### Results of the Included RCT

The trial reported no cases of NTDs in the experimental arm and 6 cases in the control arm. Based on a denominator of “informative” cases only (live births, stillbirths, and second-trimester terminations only; counting each of twin and triplet births separately), the p-value for the Fisher exact test was 0.014. We calculated the Peto odds ratio (OR) as 0.131 (95% CI, 0.0263 to 0.648; p=0.013).

#### Study Characteristics of Included Cohort Studies

At the conclusion of the RCT described above, no additional RCT was considered ethically possible. The authors continued their investigation using the same intervention (multivitamin supplement containing 0.8 mg of folic acid) in women drawn from the Hungarian Periconceptional Service (1993 to 1996), with supplementation provided before conception.^81^ The comparison group comprised unsupplemented pregnant women at their first visit in the regional antenatal care clinic between the 8th and 12th week of gestation; women who were determined (on a one-page, personally administered questionnaire) to have taken multivitamins or folic acid supplements during the periconceptional period were excluded. Unexposed women were matched to exposed women for age, socioeconomic status, employment status, and residence during the first year of pregnancy. Informative offspring included malformed fetuses, antenatally diagnosed and terminated in the second or third trimester; stillborn fetuses (late fetal death after the 28th week of gestation and/or weighing >1,000 g); and live-born infants. Informative offspring were ascertained in three ways: 1) by antenatal diagnoses of terminated fetuses, supported by a description of pathology; 2) through records at birth; and 3) by examination by a blinded pediatrician at 1 year of age or from pediatricians' records. NTDs included anencephaly and spina bifida. The study had a potential risk of selection bias because women in the supplemented cohort had a higher rate of comorbid conditions and unsuccessful pregnancies. The latter, in particular, likely prompted them to seek entry into the Hungarian Periconceptional Service. Supplemented women, however, were likely to have planned their pregnancies, had healthier behaviors in the periconceptional period, and received better prenatal care than unsupplemented women.

We also identified an eligible cohort study based on 23,491 women undergoing alpha-fetoprotein screening or amniocentesis between 15 and 20 weeks of gestation (1984 to 1987).^97,98^ Most of these women lived in Boston (33%), elsewhere in Massachusetts (48%), elsewhere in New England (5%), and outside New England (14%). Most of the samples were analyzed at the Boston University School of Medicine facilities. Nurses contacted women at the time that their tests were received by the laboratory; 93 percent did not know the results of their tests at the time of the interview. Nurses then asked women to recall their use of multivitamins in the first 3 months before pregnancy and the first 3 months of pregnancy. Exposure was defined as the use of at least one multivitamin containing folic acid per week between weeks 1 and 6 following conception. The maximum period of recall was 8 months (3 months prepregnancy and 5 months of pregnancy).

#### Results of Included Cohort Studies

The Hungarian cohort study reported 1 case of an NTD in 3,056 supplemented women and 9 cases in 3,056 unsupplemented women.^81^ The selection bias arising from higher rates of unsuccessful pregnancies in the supplemented cohort likely biased the results toward the null, while the selection bias from intentional pregnancies likely biased the results toward an effect of the intervention on NTDs. The authors adjusted the OR for birth order, chronic maternal disorder, and history of previous unsuccessful pregnancies. The study reported an adjusted OR (aOR) of 0.11 (95% CI, 0.011 to 0.91; p-value not reported).

The New England study reported 10 cases of NTDs among 10,713 women who took multivitamins containing folic acid in weeks 1 through 6 compared with 11 cases of NTDs among 3,157 women who did not take any supplements (OR, 0.27 [95% CI, 0.11 to 0.63]). By contrast, use of multivitamins containing folic acid from week 7 onward had no statistically significant effect on NTDs (25 cases in 7,883 supplemented women vs. 11 cases in 3,157 unsupplemented women; OR, 91 [95% CI, 0.45 to 1.80]) when compared with nonuse.^97^

#### Study Characteristics of Case-Control Studies

##### Data From Multiple States: National Birth Defects Prevention Study

Two included publications used the National Birth Defects Prevention Study.^9,87^ The National Birth Defects Prevention Study was established in 1997 and includes 10 population-based birth defects surveillance systems in Arkansas, California, Georgia, Iowa, Massachusetts, New Jersey, New York, North Carolina, Texas, and Utah. Eight of 10 surveillance sites include live births, fetal deaths, and elective pregnancy terminations, thus mitigating, but not entirely eliminating, the risk of selection bias.^9^ Cases were women with a pregnancy affected by anencephaly or spina bifida that did not result from a single-gene or chromosomal abnormality. Diagnosis from medical records of fetuses or infants were confirmed following review of clinical descriptions and surgery or autopsy reports. A random sample of women from each site who delivered live-born infants without structural birth defects served as controls. Interviews targeted for completion within 6 months of the expected delivery date collected information on dietary and supplement intake but could take place no earlier than 6 weeks and no later than 24 months following the expected date of delivery.^9^ Women were asked to recall use of multivitamins or supplements from 3 months before pregnancy through the last month of pregnancy, resulting in a maximum recall period of 3 years (24 months postpartum, 9 months of pregnancy, 3 months prepregnancy).

The two publications presented adjusted ORs for the risk of NTDs^9,87^ but did not report on the same time period. The more recent of these two publications, from 2013, focused on births from 1997 to 2007 and defined exposure as any use of folic acid, multivitamin, or prenatal vitamin supplement during the month before pregnancy and the first month of pregnancy. The earlier publication, from 2008, focused on births from 1998 to 2003. The authors compared the outcomes of consistent use (taking supplements at least half the number of days, ≥60 days, or from 3 months before pregnancy to the first month of pregnancy) with nonuse. The 2008 publication also provided data on outcomes associated with timing of folic acid supplementation (consistent use from 3 months before pregnancy to the first month after pregnancy vs. initiating supplement use in the first month of pregnancy).^87^

To avoid double-counting cases and to use the largest potential study, we focus primarily on the 2013 study,^9^ with the longer time span, and discuss the 2008 study in the results.^87^

##### Data From Multiple States: Slone Birth Defects Study

Three included studies drew on the Slone Birth Defects Study and were published in 2011,^11^ 2001,^95^ and 1993,^99^ respectively. The Slone Birth Defects Study began in 1976. It identifies cases, largely from hospital discharge records; randomly selects controls; and identifies exposure to folic acid supplements through an interview conducted within 6 months of delivery going back to 6 months before pregnancy. Over the course of several decades, the list of included sites and sources has shifted.

The most recent Slone Birth Defects Study, published in 2011, identifies cases as arising from discharge records of participating hospitals serving areas surrounding Boston, Philadelphia, San Diego, and Toronto (Canada).^11^ Additionally, the study included some cases identified through birth defect registries in Massachusetts and parts of New York. Nonmalformed controls were selected randomly each month from discharge lists from the same hospitals or from statewide birth records. Not all data sources in the study included fetal deaths and elective terminations of pregnancy.^11^ This publication focused on births in the postfortification era, from June 1998 to 2008, and defined nonusers as those who use supplements less than 1 day a week or only 2 lunar months before the last menstrual period. It compares the effect of supplementation on spina bifida for consistent users (≥4 days per week during at least 2 of the 3 periconceptional months, 1 or 2 lunar months before the last menstrual period, or 1 month after the last menstrual period), early pregnancy initiators (≥4 days per week beginning 1 or 2 months after the last menstrual period), and inconsistent users (all other use patterns) with nonuse. The maximum period of recall for this study is 17 months (6 months postpartum, 9 months of pregnancy, 2 months prepregnancy).

The 2001 Slone Birth Defects study includes births from 1976 to 1998 in the greater metropolitan areas of Boston, Philadelphia, and Toronto and, between 1983 and 1985, part of Iowa.^95^ The data sources for this study included fetal deaths and elective terminations from 1988 onward. The study defined folic acid supplementation as never, occasional, or daily use in the 2 months after the last menstrual period, but the primary focus of the study was on the effect of exposure to folic acid antagonists in the same 2-month postconceptional period. It compared cases of NTDs (anencephaly, spina bifida, encephalocele, and others) with controls that had non-NTD malformations (i.e., hypertrophic pyloric stenosis, indeterminate sex or pseudohermaphroditism, musculoskeletal anomalies of the skull or face, feet deformities, anomalies of the diaphragm, gastroschisis/omphalocele, esophageal stenosis, stenosis of the large intestine or anus, congenital dislocation of the hip, hypospadias, and others). The maximum period of recall for this study was 15 months (6 months postpartum, 9 months of pregnancy).

The 1993 study from the same center evaluated births from 1988 to 1991 in the greater metropolitan areas of Boston, Philadelphia, and Toronto.^99^ It compared cases (anencephaly, spina bifida, or encephalocele) with controls (other major malformations such as chromosomal abnormalities, ventricular septal defects, renal defects, transposition of great vessels, hypospadias, limb reduction defects, and craniosynostosis) for the effect of multivitamins. Exposure was defined as daily use of a vitamin supplement containing folic acid in the period spanning from 28 days before the last menstrual period to 28 days after, less than daily use in the same period, use of a multivitamin with unknown folic acid status any time in the periconceptional period, and use of a multivitamin with unknown folic acid status. The maximum period of recall for this study was 16 months (6 months postpartum, 9 months of pregnancy, 1 month prepregnancy).

We focus on the 2011 study spanning 1998 to 2008^11^ in the analysis because it is consistent with other studies in comparing NTD cases with nonmalformed controls. We also discuss and compare the results of the 2001 study^95^ and the 1993 study in the results.^99^

##### Single-State or Two-State Data Sources

The most recent study, from a more limited data source, collected data from January 1995 to February 1999 from 148 Mexican American women living along the Texas-Mexico border with NTD-affected pregnancies (including live births, stillbirths, spontaneous abortions, and elective terminations) and 158 control women with normal live births.^22^ NTDs included anencephaly, spina bifida, and encephalocele. Cases were ascertained using the Texas Department of Health's Neural Tube Defect Project, which relied on prospective case finding through hospitals, birthing centers, ultrasound centers, abortion centers, and midwives. Control women were randomly selected residents of the study area with normal births during the same time period. Exposure was defined as daily use in every month in the preconception period (≤3 months before conception), any reported use, or postconception use (≤3 months before conception). Interviews were conducted approximately 1 month postpartum. The average period of recall for this study was 13 months (1 month postpartum, 9 months of pregnancy, 1 month prepregnancy).

A case-control study drew on cases from the California Birth Defects Monitoring Program. These cases included singleton fetuses and live-birth infants diagnosed with an NTD (anencephaly, spina bifida, and other [combined anencephaly and spina bifida, craniorhachischisis, and iniencephaly]) between June 1989 and May 1991 and electively- terminated fetuses with an NTD from February 1989 to January 1991. The study identified cases randomly from area hospitals, drawing from each in proportion to the hospital's contribution to the total population of infants born alive.^82^ The study was able to reach 549 (88.0%) of 624 eligible case mothers and 540 (88.2%) of 612 eligible control mothers. Exposure was defined as any use in the 3 months before or after conception. Additionally, the study estimated, based on self-reports of composition and frequency of use, the average daily folic acid supplement intake from all supplements: less than 0.4 mg, 0.4 to 0.9 mg, and 1.0 mg or greater. Interviews were conducted on average 5 months after birth, leading to an average recall period of 17 months (5 months postpartum, 9 months of pregnancy, 3 months prepregnancy).

An older case-control study drew from cases identified in California and Illinois between 1985 and 1987 (the National Institute of Child Health and Human Development [NICHD] Neural Tube Defects Study).^96^ The authors included anencephaly, meningocele, myelomengocele, encephalocele, rachischisis, iniencephaly, and lipomeningocele in their definition of cases. In California, cases were identified through a state-mandated reporting systems for NTDs or through contracts with ultrasound centers, amniocentesis centers, disability services, and parents' support groups. In Illinois, cases were identified through ultrasound and genetic units, perinatal networks, hospital neurosurgery services, and vital records. Controls were matched for race/ethnicity, gestational age at diagnosis, date of diagnosis, and geographic area. In California, cases were matched by zip code, and in Illinois, they were matched by county. Exposure was defined as the RDA or more (i.e., women took supplements containing the RDA of at least four vitamins or a higher dose at least 6 days per week), less than the RDA, and none. The authors calculated the amount of folate received based on direct reports of use of brand-name supplements. Interviews were conducted no more than 3 months after birth, leading to a maximum recall period of 13 months (1 month postpartum, 9 months of pregnancy, 3 months prepregnancy).

#### Results of Included Case-Control Studies

Despite differences in definition of exposure, comparison, and timing across the two National Birth Defects Prevention Study publications, both are consistent in demonstrating a lack of effect of folic acid supplementation on benefits (aOR for anencephaly and spina bifida, 0.93 [95% CI, 0.82 to 1.06] and aOR for anencephaly, 1.2 [95% CI, 0.8 to 1.9], respectively).^9,87^ A potential explanation for the findings from this surveillance-based database is that in the postfortification era, the majority of cases of NTDs arising from folate deficiency have been averted, and the remainder of the cases represent other potential etiologies. A second explanation is that these findings could have arisen from bias. The National Birth Defects Prevention Study is a surveillance-based database in which eight of 10 sites recorded fetal deaths and elective pregnancy terminations in addition to live births. This case ascertainment approach mitigates the risk of bias from selection that otherwise occurs in studies focusing on live births only, where potentially eligible cases (i.e., fetal deaths and elective pregnancy terminations attributable to NTDs) are lost to analysis. If folic acid supplementation is protective, a sample that is selectively missing women who do not use folic acid supplements and have NTD-affected pregnancies that end in terminations or stillbirths will have higher odds of NTDs with folic acid supplementation than a sample without selection bias. The risk of recall bias, however, is a concern with all retrospective studies. An additional risk of differential recall bias may occur if study participants are generally aware of the potential benefits of folic acid and case mothers systematically overreport its use. A “yes/no” categorization of folic acid supplementation further risks misclassifying exposure.^9^ One publication attempted to address recall bias by focusing on consistent use,^87^ but the risks stemming from recall over the course of up to 3 years persist.

The 2011 Slone Birth Defects Study found no effect of folic acid supplementation on the risk of spina bifida, regardless of the level of supplementation. Consistent users, when compared with nonusers, had an adjusted odds of 1.11 (95% CI, 0.74 to 1.65). Early pregnancy initiators had an adjusted odds of 0.79 (95% CI, 0.54 to 1.16). Inconsistent users had an odds of 2.20 (95% CI, 0.64 to 7.62). These results could be explained by the ceiling effect—all cases of NTDs preventable through supplementation were averted by food fortification, and the remainder constitute a population with a different etiology. Alternatively, these results could arise from bias. Specifically, the sources of bias include 1) differential recall of supplementation, particularly in an era with more widespread knowledge of the support and claims for the use of folic acid supplementation in pregnancy, and 2) selection bias from incomplete case ascertainment, because the study did not consistently include terminated spina bifida cases, which were available consistently from only one site.

The two prefortification Slone Birth Defect Studies with overlapping time periods consistently demonstrate that daily use of supplements reduces the risk of NTDs compared with nonuse (aOR, 0.7 [95% CI, 0.5 to 0.8] in the 2001 study;^95^ adjusted relative risk [RR], 0.6 [95% CI, 0.4 to 0.8] in the 1993 study^99^). The Slone Birth Defect Study, particularly in the early years, had a potential risk of selection bias by not including stillbirths and elective terminations. Later rounds of analysis included a more complete case ascertainment process. The risks of recall bias were somewhat mitigated by having a shorter recall period and a calendar aid highlighting the woman's last menstrual period. Additionally, these two studies attempted to correct for the issue of differential recall of periconceptional exposure in cases and controls^95,99^ by comparing cases of NTDs with controls of other malformed infants. The 1993 study found a much higher rate of knowledge of the folic acid hypothesis among NTD case mothers than among control mothers of other malformed infants (74/432 [17%] vs. 65/2,561 [2.5%]), suggesting that the knowledge of the hypothesis could skew recollections of folic acid supplement intake.^99^ However, all cases in this study belong in the prefortification era and do not address the effect of folic acid supplementation in the current environment.

Notably, the 2001 study also offered, through the analysis of the effect of folic acid antagonists, a perspective on what would occur when women are folate deficient because of a folate antagonist. The study found that the adjusted odds of NTDs among women exposed to folic acid antagonists was 2.8 (95% CI, 1.7 to 4.6).

The study of Mexican Americans, spanning the pre- and postfortification era, found a nonsignificant reduction in the odds of NTDs associated with daily consumption of multivitamins containing folic acid (0.77 [95% CI, 0.19 to 3.22]); when adjusted for maternal age, education, obesity, and previous stillbirth or miscarriage, the direction of effect altered (aOR, 1.12 [95% CI, 0.22 to 5.78]; p-value not reported).^22^ Of note are the extremely low levels of folic acid supplement use in both arms (3 cases of daily use in the 3-month preconceptional period vs. 66 cases of no use in the 6-month periconceptional period among cases; 4 cases of daily use in the 3-month preconceptional period vs. 68 cases of no use in the 6-month periconceptional period among controls).

Two other studies were conducted in the prefortification era. Both studies drew on data from the California Birth Defects Monitoring Program, using cases from 1989 to 1991^82^ and 1985 to 1987. The Shaw et al study found an OR of 0.65 (95% CI, 0.45 to 0.94) for any use in the 3 months before conception. A larger analysis comprising women reporting supplement use in the 3 months before and after conception found an OR of 0.6 (95% CI, 0.46 to 0.79). The NICHD Neural Tube Defects Study, using a combination of slightly older California data (1985 to 1987) and Illinois data (also from 1985 to 1987), reported no effect of supplements on NTDs (calculated OR, 1.00 [95% CI, 0.73 to 1.40]; p=0.97).^96^ The Shaw et al study was able to ascertain the status of approximately 88 percent of eligible cases and controls.^82^ By contrast, the case ascertainment of the Mills et al study was estimated, based on a re-evaluation of the likely prevalence, to be as low as 43 percent.^82^

### KQ 1b Variation in Effect of Folic Acid Supplementation by Race/Ethnicity

#### Study Characteristics

Three case-control studies provide limited information about the effects of folic acid supplementation by racial/ethnic and other maternal characteristics.^11,82,87^ Table 3 presents study characteristics and Table 6 provides results. The Slone Birth Defects Study provides the most recent data (1998 to 2008).^11^ In this study, mothers of infants with and without birth defects were interviewed within 6 months of delivery about pregnancy exposures, including details of diet and vitamin intake. Periconceptional folic acid supplementation and dietary folate consumption were compared between 205 mothers of spina bifida cases and 6,357 mothers of nonmalformed controls. Women who reported folic acid supplement use of at least 4 days per week during at least 2 of the 3 periconceptional months (2 months before to 2 months after last menstrual period) were considered to be “consistent users.” A second case-control study analyzed the data from 1998 to 2003 from the National Birth Defects Prevention Study.^87^ It used logistic regression to compute crude and aORs between cases and controls assessing maternal periconceptional use of folic acid supplements and intake of dietary folic acid. The third case-control study used data from the California Birth Defects Monitoring Program (1989 to 1991). Mothers of 549 cases and 540 controls were interviewed about vitamin supplements used in the 3 months before or after conception.^82^

Table 6 Variations in the Effect of Folic Acid Supplementation on Neural Tube Defects by Race/Ethnicity

Author Design Risk of Bias | Subgroup | N | Results
Ahrens et al, 2011^11^ Case-control Medium (fair quality) | White, non-Hispanic black, non-Hispanic Hispanic | White, non-Hispanic G1: 128 G2: 4535 Black, non-Hispanic G1: 22 G2: 459 Hispanic G1: 39 G2: 892 | White, non-Hispanic Crude OR (95% CI) Consistent users: 0.78 (0.49–1.25) Early pregnancy initiators: 0.63 (0.38–1.06) Adjusted OR (95% CI) Consistent users: 0.93 (0.56–1.54) Early pregnancy initiators: 0.68 (0.40–1.16) Black, non-Hispanic Crude OR (95% CI) Consistent users: 1.11 (0.34–3.61) Early pregnancy initiators: 0.77(0.29–2.02) Adjusted OR (95% CI) Consistent users: NC Early pregnancy initiators: 0.86 (0.32–2.30) Hispanic Crude OR (95% CI) Consistent users: 1.81 (0.85–3.84) Early pregnancy initiators: 0.61 (0.27–1.38) Adjusted OR (95% CI) Consistent users: 2.20 (0.98–4.92) Early pregnancy initiators: 0.74 (0.32–1.70)
Mosley et al, 2009^87^ Case-control Medium (fair-quality) | White, black, Hispanic | Anencephaly White, non-Hispanic: 83 Black, non-Hispanic: 18 Hispanic: 67 Spina bifida White, non-Hispanic: 191 Black, non-Hispanic: 42 Hispanic: 134 Controls White, non-Hispanic: 2,173 Black, non-Hispanic: 431 Hispanic: 865 | Anencephaly White, non-Hispanic Crude OR (95% CI) 3 months before pregnancy: 1.2 (0.7–2.1) First month of pregnancy: 1.5 (0.9–2.6) Black, non-Hispanic Crude OR (95% CI) 3 months before pregnancy: 2.8 (0.8–10.4) 1st month of pregnancy: 3.9 (1.3–11.5) Hispanic Crude OR (95% CI) 3 months before pregnancy: 0.7 (0.2–2.2) 1st month of pregnancy: 1.4 (0.8–2.5) Spina bifida White, non-Hispanic Crude OR (95% CI) 3 months before pregnancy: 1.3 (0.9–1.9) 1st month of pregnancy: 1.1 (0.8–1.7) Black, non-Hispanic Crude OR (95% CI) 3 months before pregnancy: 1.2 (0.5–2.8) 1st month of pregnancy: 0.6 (0.3–1.6) Hispanic Crude OR (95% CI) 3 months before pregnancy: 0.4 (0.2–1.2) 1st month of pregnancy: 1.3 (0.9–2.0)
Shaw et al, 1995^82^ Case-control Medium (fair-quality) | Hispanic, non-Hispanic white, black, other | Hispanic G1: 265 G2: 196 Non-Hispanic white G1: 217 G2: 272 Black G1: 27 G2: 31 Other G1: 28 G2: 39 | OR for NTD from maternal use of a folic acid–containing vitamin in 3 months before conception OR (95% CI) Hispanic: 0.96 (0.44–2.10) Non-Hispanic: 0.62 (0.3 to -1.10) African American: 0.54 (0.09–3.20) Other: 4.3 (0.23–145) OR for NTD from maternal use of a folic acid–containing vitamin in first 3 months postconception OR (95% CI) Hispanic: 0.73 (0.49–1.10) Non-Hispanic: 0.58 (0.36–0.94) African American: 0.29 (0.08–1.10) Other: 1.9 (0.57–6.30)

Abbreviations: CI=confidence interval; N=number; NTD=neural tube defect; OR=odds ratio.

#### Results

The Slone Birth Defects Study found that in the setting of folic acid fortification, folic acid supplementation does not appear to offer further benefit for reducing spina bifida risk.^11^ Women who reported taking folic acid supplements at least 4 days per week during the months before neural tube closure did not have decreased risk of spina bifida compared with women who reported no supplementation. The lack of protective relationship was observed for white women. The study found a possible increased risk of spina bifida among consistent supplement users of Hispanic ethnicity compared with nonusers (aOR, 2.20 [95% CI, 0.98 to 4.92]); however, the authors note this finding may be due to chance.

The National Birth Defects Prevention Study found that periconceptional supplement use did not reduce the risk of having a pregnancy affected by an NTD, and there were no differences in the effects of folic acid supplementation by race/ethnicity.^87^ Supplement use-race interactions were not significant for anencephaly (p=0.57) or spina bifida (p=0.08). However, the authors note that the number of cases among non-Hispanic black and Hispanic populations were relatively small, so findings should be interpreted with caution.

The California Birth Defects Monitoring Program found that women who used any folic acid–containing vitamin in the 3 months before conception had a lower risk of having an NTD-affected pregnancy.^82^ Reduction in risk for Hispanics was of smaller magnitude (OR, 0.96 [95% CI, 0.44 to 2.10]) than that observed for non-Hispanic whites (OR, 0.62 [95% CI, 0.35 to 1.10]) and blacks (OR, 0.54 [95% CI, 0.09 to 3. 20]), but these results were not statistically significant and could have occurred due to chance.

Although a study focusing on Mexican Americans^22^ does not provide information about differences by race/ethnicity, it provides an estimate of effect among Hispanic women, albeit in a limited geographical context. When adjusted for maternal age, education, obesity, and previous stillbirth or miscarriage, the OR was 1.12 (95% CI, 0.22 to 5.78; p-value not reported).

### KQ 1c Variation in Effect of Folic Acid Supplementation by Dosage, Timing, and Duration of Therapy

#### Study Characteristics

One cohort study, set in New England (1984 to 1987) and described in two publications,^97,98^ and six case-control studies^11,22,82,87,96,99^ provided information on the effect of dosage and timing of folic acid supplementation on NTDs. Of these, the most recent case-control studies drew from the Slone Birth Defects Study (1998 to 2008)^11^ and the National Birth Defects Prevention Study (1998 to 2003).^87^ A third, focusing on Mexican Americans along the Texas-Mexico border, was conducted between 1995 and 1999.^22^ Two older case-control studies drew from the California Birth Defects Monitoring Program (1989 to 1991)^82^ and the Slone Birth Defects Study (1988 to 1991),^99^ respectively. The oldest case-control study, the NICHD Neural Tube Defects Study, drew from both California and Illinois (1985 to 1987).^96^ Four studies (one cohort^98^ and three case-control studies^82,96,99^) reported on dose of folic acid supplementation. Five studies (one cohort^97^ and four case-control studies^11,22,82,87^) reported on timing of folic acid supplementation.

Table 3 provides further details on study characteristics. We report the cohort study first and then report on the case-control studies in order of recency.

#### Results

##### Folic Acid Supplementation Variation by Dosage

All included studies on dose predate the food fortification era (Table 7). The New England cohort study (1984 to 1987)^98^ found no statistically significant differences by dose (1 to 399 DFEs, 400–799 DFEs, and ≥800 DFEs vs. none). Although authors infer that the study provides no evidence of a dose-response relationship, the number of NTDs for each dose category was low.

Table 7 Variations in Effect of Folic Acid Supplementation on Neural Tube Defects by Dosage

Author Design Risk of Bias | Subgroup | N | Results
Milunsky et al, 1989^97^ Moore et al, 2003^98^ Cohort Medium (fair quality) | 0, 1–399, 400–799, ≥800 | 0: 13,431 1–399: 2,489 400–799: 1,812 ≥800: 5,494 | Relative risk of NTD (95% CI) dietary folate from supplements dietary folate equivalent/day (weeks 1–5) 1–399: 0.29 (0.07–1.2) 400–799: 0.41 (0.10–1.7) ≥800: 0.56 (0.24–1.3)
Shaw et al, 1995^82^ Case-control Medium (fair-quality) | Any, <0.4, 0.4–0.9, ≥1.0 | Use in 3 months before conception <0.4 G1: 53 G2: 56 0.4–0.9 G1: 29 G2: 32 ≥1.0 G1: 5 G2: 6 Use in 3 months after conception <0.4 G1: 37 G2: 27 0.4–0.9 G1: 243 G2: 322 ≥1.0 G1:42 G2:33 None G1: 207 G2: 149 Unknown G1: 4 G2: 2 | OR for NTDs with maternal use of a folic acid–containing vitamin supplement in the 3 months before conception OR (95%) <0.4: 0.68 (0.43–1.10) 0.4–0.9: 0.65 (0.37–1.20) ≥1.0: 0.60 (0.16–2.30) OR for NTDs with maternal use of a folic acid–containing vitamin supplement 3 months after conception OR (95%) <0.4: 0.99 (0.56–1.80) 0.4–0.9: 0.54 (0.41–0.72) ≥1.0: 0.92 (0.54–1.60)
Werler et al, 1993^99^ Case-control Medium (fair quality) | ≥1 mg, 0.5–0.9 mg, 0.4 mg, <0.4 mg | Daily dose G1: 34 G2: 339 Less than daily dose G1: 41 G2: 234 RR according to daily folic acid dose in 18 case mothers (G1) and 322 control mothers (G2) who received periconceptional supplements and did not report knowledge of the hypothesis ≥1 mg G1: 3 G2: 52 0.5–0.9 mg G1: 2 G2: 15 0.4 mg G1: 8 G2: 185 <0.4 mg G1: 3 G2: 50 | Calculated OR for daily vs. less than daily dose: 0.57 (95% CI, 0.35–0.93) RR by dose among women who did not know hypothesis ≥1 mg folic acid dose in supplement RR (95% CI) (unclear if crude or multivariate): 0.4 (0.1–1.3) 0.5–0.9 mg folic acid dose in supplement RR (95% CI) (unclear if crude or multivariate): 0.9 (0.2–4.2) 0.4 mg folic acid dose in supplement RR (95% CI) (unclear if crude or multivariate): 0.3 (0.1–0.6) <0.4 mg folic acid dose in supplement RR (95% CI) (unclear if crude or multivariate): 0.5 (0.2–1.5)
Mills et al, 1989^96^ Case-control Medium (fair quality) | RDA or more vs. none Any amount vs. none | RDA or more G1: 86 G2: 70 G3: 84 Less than RDA G1: 15 G2: 17 G3: 27 None G1: 464 G2: 451 G3: 456 | Calculated OR of RDA or more vs. less than RDA: 1.84 (95% CI, 0.92–3.71)

Abbreviations: CI=confidence interval; G=group; N=number; NTD=neural tube defect; RDA=recommended daily allowance; OR=odds ratio; RR=relative risk.

The case-control study using data from the California Birth Defects Monitoring Program compared the effect of three levels of dosage (<0.4 mg, 0.4 to 0.9 mg, and ≥1.0 mg) with no folic acid supplementation in the 3 months before or after conception.^82^ The study found no differences by dose for women reporting use in the 3 months before conception. In a larger sample of women reporting use in the 3 months after conception (including those who started before conception and continued), the effect of doses below 0.4 mg or above 0.9 mg was not statistically significant compared with no use (OR for 0.4 mg, 0.99 [95% CI, 0.56 to 1.80]; OR for ≥1.0 mg, 0.92 [95% CI, 0.54 to 1.60]); only the use of 0.4 to 0.9 mg had a statistically significant effect on NTDs compared with nonuse (OR, 0.54 [95% CI, 0.41 to 0.72]). Of note, however, is the small sample size for the higher and lower doses (54 cases and controls took <0.4 mg and 75 cases and controls took ≥1.0 mg).

Data from the Slone Birth Defects Study (1988 to 1991)^99^ suggest lower odds of NTDs for daily use versus less than daily use (calculated OR, 0.57 [95% CI, 0.35 to 0.93]). A supplemental analysis in the same study of differences by dosage among women who did not know the hypothesis between folic acid supplementation and NTDs failed to find a dose-response effect. An older case-control study, the NICHD Neural Tube Defects Study, drawing from cases identified in California and Illinois between 1985 and 1987, reported on the number of NTDs in women receiving the RDA from supplements compared with those receiving less than the RDA.^96^ The study reported no statistically significant differences between different levels of exposure (calculated OR, 1.84 [95% CI, 0.92 to 3.71]). Of note, this study likely had problems with case ascertainment.

##### Folic Acid Supplementation Variation by Timing

The single cohort study (drawing on cases from 1984 to 1987 and set in New England^97^) reported that using multivitamins in weeks 1 through 6 resulted in a lower odds of NTDs than using multivitamins in weeks 7 and later (10/10,731 vs. 25/7,795; calculated OR, 0.29 [95% CI, 0.14 to 0.60]) (Table 8).

Table 8 Variations in Effect of Folic Acid Supplementation on Neural Tube Defects by Timing

Author Design Risk of Bias | Subgroup | N | Results
Ahrens et al, 2011^11^ Case-control Medium (fair quality) | Consistent users (4 or more days per week) 2 of 3 periconceptional months vs. initiating in the first month (4 or more days per week) | Spina bifida Consistent users G1: 83 G2: 2,573 Initiating in the first month G1: 60 G2: 2,293 | Calculated OR, 1.23 (95% CI, 0.88–1.73)
Mosley et al, 2009^87^ Case-control Medium (fair quality) | Consistent users 3 months before pregnancy through first month of pregnancy vs. initiating in the first month | Anencephaly Consistent users G1: 38 G2: 61 Initiating in the first month G1: 965 G2: 948 | Calculated OR, 0.61 (95% CI, 0.40–0.93)
Mosley et al, 2009^87^ Case-control Medium (fair quality) | Consistent users 3 months before pregnancy through first month of pregnancy vs. initiating in the first month | Spina bifida Consistent users G1: 97 G2: 100 Initiating in the first month G1: 965 G2: 948 | Calculated OR, 0.95 (95% CI, 0.71–1.28)
Milunsky et al, 1989^97^ Moore et al, 2003^98^ Cohort Medium (fair quality) | Women who did not use multivitamins after conception vs. women who used multivitamins in the first 6 weeks of pregnancy and women who started multivitamin use only after week 6 | Use in weeks 1-6 G1: 10 G2: 10,731 Use in weeks 7 and later G1: 25 G2: 7,795 | Calculated OR, 0.29 (95% CI, 0.14–0.60)
Suarez et al, 2000^22^ Case-control Medium (fair quality) | Preconceptional use vs. postconceptional use | Preconceptional use G1: 8 G2: 5 Postconceptional use G1: 74 G2: 85 | Calculated OR, 1.84 (95% CI, 0.58–5.86)
Shaw et al, 1995^82^ Case-control Medium (fair quality) | Use in 3 months before conception vs. use in 3 months before conception | Use in 3 months before conception Any G1: 88 G2: 98 Use in 3 months after conception Any G1: 322 G2: 384 | Calculated OR, 1.07 (95% CI, 0.77–1.48)

Abbreviations: CI=confidence interval; G=group; N=number; OR=odds ratio.

Of the four case-control studies, two were set in the postfortification era,^11,87^ one spanned the pre- and postfortification era,^22^ and one predated the food fortification era.^82^ The most recent case-control study^11^ reported the risk of consistent use (defined as ≥4 days of use per week in 2 of 3 periconceptional months) versus initiating use in the first month of pregnancy (≥4 days per week starting in the first or second month postconception). Consistent users had a higher but statistically nonsignificant risk of spina bifida (calculated OR, 1.23 [95% CI, 0.88 to 1.73]). The second postfortification case-control study^87^ reported the risk of anencephaly and spina bifida separately. Women who started folic acid supplementation use before pregnancy had a lower risk of anencephaly compared with women who started during the first month of pregnancy (calculated OR, 0.61 [95% CI, 0.40 to 0.93]). No difference was found for the spina bifida cases (calculated OR, 0.95 [95% CI, 0.71 to 1.28]).

A study of Mexican American women along the Texas-Mexico border, drawing from cases from 1995 to 1999, did not find any statistically significant differences in the odds of NTDs by preconceptional versus postconceptional use (calculated OR, 1.84 [95% CI, 0.58 to 5.86]).^22^

The case-control study using data from the California Birth Defects Monitoring Program (1989 to 1991) found lower odds but wide CIs for the use of folic acid supplements in the 3 months before conception compared with no use. It also found no statistically significant effect of NTDs compared with any use of folic acid supplements in the 3 months after conception (88 cases and 98 controls 3 months before vs. 322 cases and 384 controls 3 months after conception; calculated OR, 1.07 [95% CI, 0.77 to 1.48]).^82^

### KQ 2a Harms of Folic Acid Supplementation in Women of Childbearing Age

#### Study Characteristics

We included one RCT comparing folic acid supplementation with a multivitamin versus trace elements described in seven publications^88-94^ and one cohort study (Table 9).^83^ Additionally, the previous review also reported on twinning.^36,86,88-90,93,94^ The trial characteristics are described under KQ 1a.^101^ As noted previously, the trial included only “informative” cases in the analysis (i.e., live births and stillbirths [late fetal deaths]). The authors noted that it was generally not possible to recognize multiple gestations in miscarriages or ectopic pregnancies.

Table 9 Harms of Folic Acid Supplementation: Study Characteristics of Included Twinning Studies

Author Study Name Design Risk of Bias | Population | Intervention | Timing and Setting
Czeizel et al, 1992^88^ Czeizel et al, 1993^89^ Czeizel et al, 1994^90^ Czeizel et al, 1994^91^ Czeizel et al, 1993^92^ Czeizel et al, 1996^94^ Czeizel et al, 1998^93^ Hungarian RCT RCT Medium (fair quality) | Women planning a pregnancy without any delayed conception or infertility and not currently pregnant | G1: Vitamin supplement (0.8 folic acid and 12 vitamins, 4 minerals, 3 trace elements)^93^ (n=2,793) G2: Trace-element supplement (copper, manganese, zinc, low dose of vitamin C)^94^ (n=2,660) | 28 days before conception and at least until the date of the second missed menstrual period^91^ HPS began 3 months before a pregnancy is planned and continues for the first 3 months after conception. HPS provided information and counseling, examinations, and interventions during all trimesters by qualified nurses.
Vollset et al, 2005^83^ Medical Birth Registry of Norway Cohort Medium (fair quality) | Women with singleton and twin pregnancies | G1: Preconceptional use of folate (n=11,077) G2: No preconceptional use of folate (n=164,965) | Preconception Medical Birth Registry of Norway, women who gave birth from December 1998 through the end of 2001. Information on IVF pregnancies obtained by contacting fertility clinics in Denmark and Sweden.

Abbreviations: G=group; HPS=Hungarian Preconceptional Service; IVF=in vitro fertilization; n=number; RCT=randomized, controlled trials.

In a retrospective, population-based cohort study in Norway (N=176,042) of births from December 1998 through the end of 2001,^83^ the use of folic acid supplements and multivitamins was ascertained using a birth notification form submitted through the Norway Birth Registry. For multiple gestations, the registry received one form for each birth. Separate notification was made for pregnancies conceived through in vitro fertilization.

Three meta-analyses^101,108,109^ met our initial inclusion criteria and evaluated the effects of periconceptional folic acid supplementation on childhood respiratory illness. One meta-analysis^101^ with a low risk of bias evaluated the association of folic acid supplementation during the specified time frame of 1 month prior to pregnancy or the first 12 weeks of pregnancy with childhood asthma or wheezing and allergy-related outcomes. However, because of heterogeneity in the type of folic acid supplementation (e.g., folate, combination of folate and dietary folate) and measure of exposure during the periconceptional period, authors limited the pooled estimate to five studies (three cohort, two nested case-control)^102-106^ that assessed folic acid in the periconceptional period (from the month prior to pregnancy) or first trimester. Folic acid supplementation was operationalized as “yes/no.” In the three studies that reported the dose of folic acid, the range was 400 to 600 μg/day.^103-105^ In one study, the average dose was not reported but the investigators suggested it was 400 μg/day.^102^ Asthma or wheezing was assessed through a structured parental interview or parental completion of a medical questionnaire. Two studies reported on asthma,^105,106^ two studies reported on wheezing,^102,103^ and one study reported on wheezing and asthma.^104^

A second meta-analysis^108^ with a medium risk of bias included five published studies and data from a review of a longitudinal cohort study of folic acid supplementation and asthma. We describe the two meta-analyses noted above in Table 10. Additionally, a third eligible meta-analysis^109^ used a subset of the evidence in the other two meta-analyses; we focus on concordance of these results with other meta-analyses.

Table 10 Harms of Folic Acid Supplementation: Study Characteristics of Included Asthma/Wheezing Studies

Author Study Name Design Risk of Bias | Population | Intervention | Timing and Setting
Yang, 2014^108^ Meta-analysis Medium (fair quality) | Studies that examined folic acid exposure during the periconceptional period or during pregnancy and provided results on at least one allergic or respiratory outcome or outcome of interest | Folic acid supplementation | Supplementation during preconception and during pregnancy All available settings
Crider, 2013^101^ Meta-analysis Low (high quality) | Studies that examined maternal folic acid supplementation during pregnancy on infant asthma | Folic acid supplementation | Supplementation during preconception and during pregnancy All available settings

#### Results

##### Twinning in Women

In an analysis of informative pregnancies in the trial,^91^ the proportion of twin pregnancies and twin births (live and stillbirths) was not statistically significantly different between the multivitamin and trace-element arms (Table 11). Out of the total pregnancies in the multivitamin group, 1.9 percent (46/2,421) were determined to be twin gestations compared with 1.36 percent (32/2,346) of pregnancies in the trace element group (χ^2^=2.13; p=0.15). The RR (1.4 [95% CI, 0.87 to 2.26]) was not statistically significantly different between the two groups. The proportion of twin births (as opposed to pregnancies) was higher in the multivitamin group (93/2,468 [3.77%]) than in the trace element group (64/2,378 [2.69%]; RR, 1.42 [95% CI, 1.01 to 1.98]).

Table 11 Results of Prospective Studies on the Associations Between Folic Acid Supplementation and Twinning

First Author, Design Risk of Bias | Intervention Groups (n) | Timing of Measurement Exposure | Outcomes | Relative Risk or Odds Ratio (95% CI) | N | Adjustments
Czeizel, 1994^91,94^ RCT Medium (fair quality) | G1: Vitamin supplement (0.8 folic acid and 12 vitamins, 4 minerals, 3 trace elements)^93^ (n=2,793) G2: Trace-element supplement (copper, manganese, zinc, low dose of vitamin C)^94^ (n=2,660) | 28 days before conception and at least until the date of the second missed menstrual period^91^ | Twinning | Calculated OR: 1.40 (0.89–2.21) | Multiple pregnancy cases in exposed arm: 46 N informative pregnancies in exposed arm: 2,421 Multiple pregnancy cases in control arm: 32 N informative pregnancies in control arm: 2,346 | None
Czeizel, 1994^91,94^ RCT Medium (fair quality) | G1: Vitamin supplement (0.8 folic acid and 12 vitamins, 4 minerals, 3 trace elements)^93^ (n=2,793) G2: Trace-element supplement (copper, manganese, zinc, low dose of vitamin C)^94^ (n=2,660) | 28 days before conception and at least until the date of the second missed menstrual period^91^ | Twinning | Calculated OR: 1.70 (0.79–3.65) | Clomiphene (infertility treatment) subgroup: Multiple pregnancy cases in exposed arm: 19 N in exposed arm: 141 Multiple pregnancy cases in control arm: 12 N in control arm: 143 | None
Vollset et al, 2005^83^ Cohort Medium (fair quality) | All pregnancies: G1: Preconceptional use of folate (N=11,077) G2: No preconceptional use of folate (N=164,965) Natural conception: G1: 10,457 G2: 164,965 IVF: G1: 620 G2: 2,000 | Preconception | Twinning | OR of twin pregnancies with adjustments for maternal age and parity: 1.59 (1.41–1.78) | Multiple pregnancy cases in exposed arm for all women: 329 N in exposed arm: 11,077 Multiple pregnancy cases in comparison arm: 2,825 N in comparison arm: 164,965 | Maternal age and parity
Vollset et al, 2005^83^ Cohort Medium (fair quality) | All pregnancies: G1: Preconceptional use of folate (N=11,077) G2: No preconceptional use of folate (N=164,965) Natural conception: G1: 10,457 G2: 164,965 IVF: G1: 620 G2: 2,000 | Preconception | Twinning | OR of twin pregnancies with adjustments for maternal age, parity, and IVF: 1.04 (0.91–1.18) | Multiple pregnancy cases in exposed arm: 154 N in exposed arm: 620 Multiple pregnancy cases in comparison arm: 543 N in comparison arm: 2,000 | Maternal age, parity, and IVF

Abbreviations: CI=confidence interval; G=group; IVF=in vitro fertilization; n=number; N=number; OR=odds ratio; RR=relative risk.

In a further analysis for the same trial, women who were not supplemented were excluded (i.e., women who became pregnant before or during the first month of supplementation). The analysis continued to demonstrate a lack of significant difference in the risk of twin pregnancies (calculated RR, 1.5 [95% CI, 0.94 to 2.39]). The study found an increased risk of twin births in the multivitamin group compared with the trace element group (RR, 1.53 [95% CI, 1.08 to 2.16]). The increased risk in the multivitamin group may be due to several factors, including differences in maternal characteristics and pregnancy-specific or delivery-related complications. Limited information is available on differences in maternal characteristics and essentially no data are available on pregnancy-related factors. The findings should be interpreted with caution because births include live births and stillbirths, and there are no data to discern the proportion of live or stillbirths in each treatment arm.

##### Twinning and Ovarian Stimulation in Women

The Hungarian trial did not find evidence^91^ for an increased risk of twinning among women receiving fertility treatments and randomized to a multivitamin or trace element. The proportion of women in the multivitamin and trace element groups who received fertility treatment was similar at 6.4 and 6.6 percent, respectively. Among the 2,198 women who received multivitamin supplementation, 141 received clomiphene citrate, with or without other infertility drugs, and 19/141 (13.5%) resulted in a multiple gestation. Of the 2,057 women in the multivitamin group who did not receive fertility drugs, 25/2,057 (1.2%) resulted in a multiple gestation. Among the 2,170 women who received trace element supplementation, 143 underwent ovarian stimulation and 12/143 (8.4%) resulted in a multiple gestation. Of the remaining 2,027 pregnancies conceived without ovarian stimulation, 17/2,027 (0.8%) twin pregnancies were identified. Among pregnancies that were conceived without ovarian stimulation, the study found no statistically significantly increased risk of twinning among women who received multivitamin compared with trace element supplementation (OR, 1.46 [95% CI, 0.78 to 2.70]). Among women who underwent ovarian stimulation, the odds of twinning in those receiving multivitamins was calculated to be 1.70 [95% CI, 0.79 to 3.65]. The point estimates and wide CIs are largely due to the relatively small total number of twin gestations in this subgroup analysis (n=73) and the similarly small number (proportion) of twin gestations in the multivitamin and trace element groups.

The initial analysis of the cohort study^83^ found an increased odds (baseline adjustment for maternal age and parity) of twinning among pregnancies with folic acid supplementation use compared with those with no folic acid supplementation use. With further adjustment for in vitro fertilization, the OR was attenuated and no longer statistically significant (1.04 [95% CI, 0.91 to 1.18]).

In analyses stratified by method of conception (in vitro fertilization or natural conception), the odds of twinning with folic acid supplement use in natural conception (OR, 1.13 [95% CI, 0.97 to 1.33]) were slightly higher than with in vitro fertilization (OR, 0.90 [95% CI, 0.73 to 1.11]). In an analysis stratified by parity, women with no prior pregnancies had slightly higher odds of twinning with folic acid supplement use (OR, 1.31 [95% CI, 1.05 to 1.62]). In a subsequent modeling analysis, the authors assumed that 12.7 percent of pregnancies conceived by true in vitro fertilization were misclassified as natural conception and that 45 percent of women were misclassified as folic acid supplement users. Authors found an attenuated effect of folic acid supplementation and multivitamin use before pregnancy after adjusting for age, parity, and potential misclassification; neither was statistically significant (OR for folic acid supplements before pregnancy, 1.02 [95% CI, 0.85 to 1.24]; OR for multivitamins before pregnancy, 0.98 [95% CI, 0.83 to 1.17]). The authors found elevated risks of twinning with folic acid supplementation (OR, 1.14 [95% CI, 1.00 to 1.23]) or multivitamin use (OR, 1.30 [95% CI, 1.14 to 1.49]) during pregnancy after adjusting for age and parity. The authors note, however, that this effect could be explained by confounding by indication; that is, an increased use of folic acid or multivitamin supplements once the multiple gestation is recognized.

##### Childhood Asthma or Wheezing and Allergen-Related Outcomes

We identified eight eligible articles,^100,102-107,110^ which were synthesized in three systematic reviews.^101,108,109^ All included primary studies were observational, with attendant risks of misclassification and recall bias. We discuss pooled estimates from the meta-analyses below (Table 12). With regard to asthma, the pooled estimate from one meta-analysis^101^ focusing on the prepregnancy period through the first trimester (N not reported) found no evidence from three studies^104-106^ of an association between maternal folic acid supplementation compared with no use and childhood asthma (pooled RR, 1.01 [95% CI, 0.78 to 1.30]; I^2^=0.00; p=0.95 and 0.73, respectively). For the combined outcomes of wheezing in infants and toddlers and asthma in children, the pooled estimate from five studies^102-106^ resulted in a slightly elevated risk with the use of folic acid supplements before pregnancy or during the first trimester (RR, 1.05 [95% CI, 1.02 to 1.09]; I^2^=0.00; p=0.01 and 0.68, respectively).

Table 12 Results of Meta-Analyses on the Associations Between Folic Acid Supplementation and Asthma/Respiratory Illness

First Author, Design Quality | Intervention Groups (n) | Timing of Measurement Exposure | Outcomes | Relative Risk or Odds Ratio (95% CI)
Yang, 2014^108^ Meta-analysis Fair quality | G1: Periconceptional use of folic acid (NR) G2: No use (NR) | Periconceptional period through pregnancy | Child asthma | OR: 1.06 (0.99–1.14)
Crider, 2013^101^ Meta-analysis Fair quality | G1: Periconceptional use of folic acid (NR) G2: No use (NR) | Periconceptional or first trimester | Asthma or wheezing Other outcomes: atopy, eczema, and atopic dermatitis (includes LRTI, URTI, food reaction, sensitization) | Asthma: RR: 1.01 (0.78–1.30) Wheeze in infants/toddler; asthma in children: RR: 1.05 (1.02–1.09) Atopy, eczema, and atopic dermatitis (includes LRTI, URTI, food reaction, sensitization): no statistically significant differences

Abbreviations: CI=confidence interval; G=group; LRTI=lower respiratory tract infection; n=number; N=number; NR=not reported; OR=odds ratio; RR=relative risk; URTI=upper respiratory tract infection.

A second meta-analysis evaluating any exposure from the periconceptional period through pregnancy (n=14,438)^108^ included five studies in the pooled estimate.^100,104-107^ The meta-analysis found no association between folic acid supplementation during the periconceptional period or pregnancy and the development of child asthma (OR, 1.06 [95% CI, 0.99 to 1.14]), but the authors reported wide variations in the dose of folic acid supplementation across included studies. Other allergen-related outcomes included a combination of atopy, eczema, and atopic dermatitis. One meta-analysis^101^ evaluated these outcomes for periconceptional and first trimester exposure from four studies^102-104,107^ and found two reports of elevated risk from one study^102^ among 13 reported associations of lower respiratory tract infections (adjusted RR, 1.09 [95% CI, 1.01 to 1.15]) and hospitalizations from lower respiratory tract infections (adjusted RR, 1.24 [95% CI, 1.09 to 1.41]) among infants ages 0 to 18 months.

A third meta-analysis, using a smaller subset of studies,^100,103-105^ also found no statistically significant differences in the incidence of asthma, wheezing, atopic dermatitis, eczema, or sensitization.^109^

##### Other Reported Harms in Women

The Hungarian trial also reported on other harms.^93^ The presence or absence of these harms represents potential side effects of folic acid supplementation, many of which are common pregnancy symptoms, and provides reassurance of the safety of folic acid supplementation in the preconceptional period. The Hungarian trial^93^ reported on differences between weight gain, body weight, gastrointestinal symptoms (hunger or increased appetite, lack of appetite, heartburn and indigestion, constipation, diarrhea, irregular and/or colic defecation [urge to defecate after a meal]), and exanthema (a skin disorder characterized by a rash and skin eruptions) after periconceptional multivitamin and trace element supplementation (Figure 3). The study found no statistically significant differences in the report of most of these symptoms between the two groups from before pregnancy through pregnancy confirmation. Women who continued supplementation through the first 12 weeks of pregnancy had an increased risk of weight gain (calculated RR, 1.78 [95% CI, 1.23 to 2.57]), diarrhea (calculated RR, 7.09 [95% CI, 2.72 to 18.47]), and constipation (calculated RR, 1.67 [95% CI, 1.06 to 2.63]) compared with the trace element group. They also had a lower risk of irregular and/or colic defecation compared with the trace element group (RR, 0.33 [95% CI, 0.16 to 0.68]). The study found no difference in the risk of exanthema, although two participants in the multivitamin group and one in the trace element group withdrew from the study because of this disorder.

Figure 3 Folic Acid Supplementation and Adverse Events: Forest Plot

Figure 3 is a forest plot. The Hungarian trial reported on differences between weight gain, body weight, gastrointestinal symptoms, and exanthema after periconceptional multivitamin and trace element supplementation. The study found no statistically significant differences between the two groups from before pregnancy through pregnancy confirmation in the report of most of these symptoms. Women who continued supplementation through the first 12 weeks of pregnancy had an increased risk of weight gain, diarrhea, and constipation compared with the trace element group. They also had a lower risk of irregular and/or colic defecation compared with the trace element group. The study found no difference in the risk of exanthema, although 2 participants in the multivitamin and 1 in the trace element group withdrew from the study because of this disorder.

### KQ 2b Variation in Harms of Folic Acid Supplementation by Dose, Timing, and Duration of Therapy

#### Study Characteristics

One meta-analysis^101^ with a low risk of bias evaluated the association of folic acid supplementation with childhood asthma or wheezing and allergy-related outcomes. Studies were grouped by the timing of exposure: early (preconceptional, periconceptional, first trimester) versus late (second and third trimesters).^100,102,107^ A second meta-analysis also examined timing of supplementation (prepregnancy, early pregnancy, other period in pregnancy).^109^ One meta-analysis found one study reporting on dose (<200 μg/day, 200 to 499 μg/day, and >500 μg/day).^110^

#### Results

As noted in KQ 2, the meta-analysis that analyzed folic acid supplement use as a dichotomous variable and reported its association with asthma in childhood showed a pooled RR of 1.01 (95% CI, 0.78 to 1.30; I^2^=0.00; p=0.95 and 0.73, respectively) (Table 13).^101^ Two of the cohort studies included in the meta-analysis examined the association between prenatal use of a supplement containing folic acid (compared with no use) in the second or third trimester and asthma or wheezing in childhood.^100,102^

Table 13 Variation in Harms of Folic Acid Supplementation by Timing

First Author, Design | Intervention Groups (n) | Timing of Measurement Exposure | Outcomes | Relative Risk or Odds Ratio (95% CI)
Crider, 2013^101^ Systematic review | G1: Second or third trimester use of folic acid (NR) G2: No use (NR) | Second or third trimester | Asthma or wheezing | Wheeze in infants/toddler RR: 1.20 (1.04–1.39) in 1 study^100^ 14 other associations for asthma or wheezing not statistically significantly different^100,102^
Crider, 2013^101^ Systematic review | G1: Second or third trimester use of folic acid (NR) G2: No use (NR) | Second or third trimester | Other allergic outcomes | 38 associations for other allergic outcomes not statistically significant

Abbreviations: CI=confidence interval; G=group; NR=not reported; RR=relative risk.

Of the 15 associations across two studies, only one association was significantly elevated. Specifically, one study showed that maternal use of folic acid supplements in the third trimester was associated with increased risk of maternal report of wheezing at age 1 year (adjusted prevalence ratio, 1.20 [95% CI, 1.04 to 1.39]).^100^ Regarding other outcomes, three cohort studies examined the use of supplements containing folic acid during the second or third trimester and risk of other allergy outcomes.^100,102,107^ The meta-analysis reported no significant findings in 38 reported associations across these three studies.

A meta-analysis examined the incidence of asthma and wheezing by timing of supplementation (prepregnancy, early pregnancy, other period in pregnancy).^109^ Four of five reported associations showed no statistically significant effect of folic acid supplementation on asthma or wheezing in childhood. The one statistically significant effect on wheezing in childhood was associated with exposure in early pregnancy (RR, 1.06 [95% CI, 1.02 to 1.09]).^102-104^ One study separated the study population into tertiles (<0.2 mg/day, 0.2–0.499 mg/day, and >0.5 mg/day) and compared the second and third tertiles with the first for the incidence of any allergic disease, sensitization, recurrent wheezing, eczema, food reactions, immunoglobin E–mediated food allergy, and sensitization to food allergens (Table 14). In all cases, the number of events was small, ranging from 16 to 69. All results had wide CIs spanning or overlapping the line of no difference.^110^

Table 14 Variation in Harms of Folic Acid Supplementation by Dose

First Author, Design | Intervention Groups (n) | Timing of Measurement Exposure | Outcomes | Relative Risk or Odds Ratio (95% CI)
Crider, 2013^101^ (citing Dunstan, 2012^110^) Systematic review | G1: >0.5 mg/day G2: 0.2–0.499 mg/day G3: <0.2 mg/day | Third trimester | Any allergic disease, sensitization, recurrent wheeze, eczema, food reactions, IgE-mediated food allergy, and sensitization to food allergens | 12 associations overlap line of no difference; 2 span line of no difference for G3 vs. G1 (OR, 1.5 [1.0–2.5) and G2 vs. G1 (OR, 1.7 [1.0–2.8]) for eczema

Abbreviations: CI=confidence interval; G=group; IgE=immunoglobulin E; RR=relative risk.