# 2 Methods

## Key Questions and Analytic Framework

The investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers developed the scope, Key Questions (KQs), and analytic framework (Figure 1) that guided our literature search and review. Specifically, our KQs are:

1a To what extent does folic acid supplementation reduce the risk for NTDs (first occurrence) in women of childbearing age?
1b Does the effect of folic acid supplementation on NTDs (first occurrence) differ by race/ethnicity?
1c Do the benefits of folic acid supplementation differ by dosage, timing, or duration of therapy?
2a Are there harms associated with folic acid supplementation to the mother, fetus, neonate, or child?
2b Do the harms of folic acid supplementation differ by dosage, timing, or duration of therapy?

Figure 1 Analytic Framework

Abbreviations: KQ=Key Question; NTD=neural tube defect.

This figure depicts the analytic framework that outlines the key questions addressed and the evidence covered in this report, including populations, interventions, and outcomes. On the left, the population of interest is specified as women of childbearing age. Moving from left to right, the figure illustrates the overarching question: To what extent does folic acid supplementation reduce the risk for neural tube defects (first occurrence) in women of childbearing age (key question 1)? The figure depicts the pathway from folic acid supplementation to neural tube defects operating through serum folate levels. Folic acid supplementation may result in harms (key question 2).

The USPSTF also requested five contextual questions to help inform the report:

1. What is the current intake of folic acid from diet and other sources in women of childbearing age?
2. Does intake of folic acid from diet and other sources differ by pregnancy intention, age, race/ethnicity, or access to foods?
3. Does folic acid supplementation outside of the periconceptional period reduce the risk of NTDs?
4. Does the effect of folic acid supplementation on NTDs in the periconceptional period differ by medical risk factors (obesity, poorly controlled diabetes, seizure medications, methotrexate or other folate-antagonist therapies, or previous pregnancy with an NTD)?
5. Are there other potential fetal, neonatal, or maternal benefits from folic acid supplementation in the periconceptional period?

## Search Strategies

We searched PubMed/MEDLINE®, the Cochrane Library, and EMBASE for English-language articles published from database inception through January 28, 2016. We used Medical Subject Headings as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, interventions, outcomes, and study designs. Appendix A describes the complete search strategies. We conducted targeted searches for unpublished literature by searching ClinicalTrials.gov, HSRProj, the World Health Organization's International Clinical Trials Registry Platform, and NIH Reporter. To supplement electronic searches, we reviewed the reference lists of pertinent review articles and studies meeting our inclusion criteria and added all previously unidentified relevant articles. We also manually reviewed all literature suggested by peer reviewers or public comment respondents and, if appropriate, incorporated it into the final review.

## Study Selection

We selected studies on the basis of inclusion and exclusion criteria developed for each KQ based on the PICOTS (population, intervention, comparator, outcome, timing, setting) approach for identifying populations, interventions, comparators, outcomes, timing, settings, and study designs (Appendix B). Appendix C lists excluded studies. We imported all citations identified through searches and other sources into EndNote v.5 (Thomson Reuters, New York, NY). Two investigators independently reviewed titles and abstracts. We dually and independently reviewed the full text of abstracts marked for potential inclusion by either reviewer. Two experienced team members resolved disagreements. We did not apply date limits to our searches and therefore captured all the studies included in the 2009 review.^36^ We resolved disagreements by discussion and consensus; if necessary, we sought adjudication of conflicts from other experienced team members.

### Population

We included studies that focused on the use of folic acid supplementation for the prevention of NTD-affected pregnancies in women of childbearing age. We did not include studies of prepubertal girls or men or women without the potential for childbearing (e.g., postmenopausal women, women with genetic uterine or ovarian abnormalities).

### Interventions

We searched for studies that examined the use of folic acid supplementation with or without food fortification or naturally occurring folate for the prevention of NTDs. We also searched for studies that examined supplementation with micronutrients (e.g., multivitamin, iron) in combination with folic acid for the prevention of NTDs.

### Comparators

For KQs 1a, 1b, and 2a, we included studies that compared interventions with placebo, no treatment, dietary supplementation only, supplementation with prenatal vitamins not containing folic acid, or iron supplements not containing folic acid. For KQs 1b, 1c, and 2b, we included studies that compared interventions with lower or higher doses of folic acid supplementation.

### Outcomes and Timing

For KQs 1a and 1b, we searched for studies that reported on the benefits of folic acid supplementation initiated before the index pregnancy or in the first trimester to prevent NTDs. For KQs 1c, 2a, and 2b, we searched for studies that reported on the harms of folic acid supplementation initiated before the index pregnancy and during the first, second, and third trimesters of pregnancy.

### Settings

For all KQs, we searched for studies conducted in the United States or in countries with a very high Human Development Index.

### Study Designs

For KQs 1a, 1b, and 1c, we included randomized, controlled trials (RCTs), controlled trials, cohort studies, case-control studies, and systematic reviews. For KQs 2a and 2b, we included RCTs, controlled trials, cohort studies, case-control studies, systematic reviews, and registry data.

## Data Abstraction and Quality Rating

We abstracted pertinent information from each included study; details included methods and patient populations, interventions, comparators, outcomes, timing, settings, and study designs. A second investigator checked all data abstractions for completeness and accuracy. Using predefined criteria developed by the USPSTF and others^76-78^ for additional criteria for diagnostic accuracy studies, two investigators independently assessed the quality of each study as good, fair, or poor (Appendix D).^79^ Disagreements were resolved by discussion and consensus. Studies with “fatal flaws” were rated as having high risk of bias (i.e., poor quality). Particular considerations for this topic include the risk of misclassification bias (from retrospective recall of level and timing of exposure), the risk of selection bias (from not identifying all cases of the outcome, including fetal deaths), and the risk of confounding (from not appropriately accounting for factors such as infertility that might influence both exposure to folic acid supplementation and the outcome of twinning). We rated studies with one or more of these features as poor quality. Other fatal flaws that resulted in poor-quality ratings included initially assembled groups not close to being comparable or maintained throughout the study (including overall attrition of at least 20% or differential attrition of at least 15% between groups); use of unreliable or invalid measurement instruments or unequal application among groups (including not masking outcome assessment); and, for RCTs, the lack of intention-to-treat analysis.

Two reviewers dually reviewed the quality of all studies included in the 2009 report that met the inclusion criteria for the current review and resolved disagreement by discussion and consensus.

## Data Synthesis and Analysis

We qualitatively synthesized findings for each KQ by summarizing the characteristics and results of included studies in tabular or narrative format. To determine whether meta-analyses were appropriate, we assessed the clinical and methodological heterogeneity of the studies following established guidance.^80^ We qualitatively assessed the populations, similarities and differences in screening tests or treatments used, and similarities in outcomes and timing of outcomes assessed. We produced forest plots without summary estimates to illustrate patterns of effect size across studies.

## Expert Review and Public Comment

A draft report was reviewed by content experts, representatives of federal partners, USPSTF members, and AHRQ Medical Officers and was revised based on comments, as appropriate. It was also posted for public comment.

## USPSTF Involvement

This review was funded by AHRQ. AHRQ staff and USPSTF members participated in developing the scope of the work and reviewed draft manuscripts, but the authors are solely responsible for the content.