# Appendix G Ongoing Trials

Principal investigators | Location | Population | Approximate size | Investigations | Outcomes | Status as of 2015
Renata Bortolus, MD | Italy | Women 18-44 who intend to become pregnant | 5,000 | 4 vs. 0.4 mg/day | Number of congenital malformations Rate of selected congenital malformations Miscarriages and recurrent abortions Pre-eclampsia Abruption placenta Intrauterine growth restriction Pre-term delivery Multiple births | Recruiting; Estimated Study completion: September 2016
Fenneke Blom, PhD | The Netherlands | Women18-45 who want to become pregnant within 12 months | 5,000 | 4 vs. 0.4 mg/day | Folic acid related congenital anomalies Preterm birth Birth weight Preeclampsia Compliance with intervention | Recruiting; Estimated Study completion: December 2016