# Appendix F Overview of Study Characteristics

Appendix F Table 1 Characteristics of Included Randomized, Controlled Trials, Case-Control Studies, and Cohort Studies

First Author Study Name Design Country Funding Risk of Bias | Inclusion Exclusion Criteria | Groups | Timing Setting | Mean Age | % Nonwhite
Agopian et al, 2012^9^ National Birth Defects Prevention Study Case-control United States Centers for Disease Control and Prevention and Texas Department of State Health Services Medium | Included: National Birth Defects Prevention Study (NBDPS), data collected from population-based surveillance systems located in 10 states: Arkansas, California, Georgia, Iowa, Massachusetts, New Jersey, New York, North Carolina, Texas, and Utah. Cases included live births, fetal deaths, and elective pregnancy terminations. Live born controls without major birth defects were ascertained through birth certificate data or hospital birth logs. Controls were selected at random among infants delivered in the study regions. Excluded: Cases with additional major birth defects that were unlikely to be secondary to the NTD. Excluded potential cases with single-gene disorders or chromosome abnormalities | G1: Spina bifida or anencephaly live births, fetal deaths, and elective pregnancy terminations (n=1,239) G2: Live born controls without major birth defects (n=8,494) | Folic acid supplementation before pregnancy through first month of pregnancy Population-based surveillance systems in 10 states. Data collected from medical records, birth certificate data, or hospital birth logs. | NR | 42%
Ahrens et al, 2011^11^ Slone Birth Defects Study Case-control United States Centers for Disease Control and Prevention Medium | Included: Slone Birth Defects Study, infants with birth defects were identified from discharge records of participating hospitals serving the areas surrounding Boston; Philadelphia; San Diego; and Toronto; in addition, cases have been identified through birth defect registries in Massachusetts and parts of New York. Nonmalformed controls have been randomly selected each month from study hospitals' discharge lists or from statewide birth records. Malformed live-born infants, therapeutic abortions after 12 weeks' gestation, and fetal deaths after 20 weeks' gestation were eligible as cases for our study. Only live-born nonmalformed infants were eligible as controls. | G1: Malformed live-born infants, therapeutic abortions after 12 weeks' gestation, and fetal deaths after 20 weeks' gestation (n=205) G2: Live-born nonmalformed infants (n=6,357) | Folic acid supplements 2 months before the last menstrual period and 1 month after last menstrual period. Cases identified from discharge records of participating hospitals serving the areas surrounding Boston, Philadelphia, San Diego, and Toronto and through birth defect registries in Massachusetts and New York. Nonmalformed controls selected each month from study hospitals' discharge lists or from statewide birth records. | Median age at conception G1: 28 G2: 30 | 29%
Czeizel et al, 1992^88^ Czeizel et al, 1993^89^ Czeizel et al, 1993^92^ Czeizel et al, 1994^90^ Czeizel et al, 1994^91^ Czeizel et al, 1996^94^ Czeizel et al, 1998^93^ Hungarian RCT RCT Hungary NR Medium | Included: Women planning a pregnancy, did not have delayed conception or infertility, not currently pregnant. During the first four years of trial women had to be less than 35 years old and no previous wanted pregnancy.^90^ Excluded: Patients with genetically determined syndromes, including those involving NTDs (e.g., Meckel's syndrome or Patau's syndrome).^88^ | G1: Vitamin supplement (0.8 folic acid and 12 vitamins, 4 minerals, 3 trace elements)^93^ (n=2793) G2: Trace-element supplement (copper, manganese, zinc, low dose of vitamin C)^94^ (n=2660) | 28 days before conception and at least until the date of the second missed menstrual period^91^ Hungarian Preconceptional Service (HPS) began 3 months before a pregnancy is planned and continues for the first 3 months after conception. HPS provided information and counseling, exams, and interventions during all trimesters by qualified nurses. | 27 | NR
Czeizel et al, 2004^81^ Hungarian Cohort-Controlled Trial Cohort-controlled trial Hungary NR Medium | Included: Supplemented cohort was recruited from the Hungarian Periconceptional Service between May 1, 1993 and April 30, 1996. Routine care subjects for an unsupplemented cohort were recruited during their first visit at an antenatal care clinic between the 8th week and 12th week of gestation. Excluded: Supplemented group: did not conceive within 1 year. Unsupplemented group: multivitamin and/or folic acid use during the periconceptional period and before first visit. | G1: Women supplemented with multivitamin (n=3,056) G2: Nonsupplemented women (n=3,056) | Before conception and at least until first missed menstrual period. Supplemented cohort was recruited from the Hungarian Periconceptional Service (HPS). HPS provides information and counseling, exams, and interventions during all trimesters by qualified nurses. Unsupplemented cohort was recruited during their first visit at an antenatal care clinic. | 27 | NR
Hernandez-Diaz et al, 2001^95^ Slone Epidemiology Unit Birth Defects Study Case-control United States Pharmacoepidemiology Teaching and Research Fund of the Harvard School of Public Health: the National Center for Environmental Health, Centers for Disease Control and Prevention; the Massachusetts Department of Public Health: the National Institute of Child Health and Human Development and the National Heart, Lung, and Blood Institute Medium | Inclusion: Slone Epidemiology Unit Birth Defects Study. Cases, infants and fetuses with anencephaly, spina bifida, encephalocele, or other NTDs. Controls, infants with malformations other than NTDs. Excluded: Infants with chromosomal or Mendelian-inherited anomalies or with amniotic bands, caudal regression, or twin disruption. Subjects with oral clefts, urinary tract defects, limb reduction, heart defects, and conditions related to NTD (hydrocephalus, microcephalus, and other anomalies of the brain, spinal cord, or nervous system). | G1: Cases with NTDs (spina bifida, anencephaly, encephalocele, or other NTD) (n=1,242 ) G2: Infants with malformations not related to vitamin supplementation (n=6,660 ) | Any time during the 2 months after the last menstrual period. Participants of the Slone Epidemiology Unit Birth Defects Study. Study interviewed mothers of malformed children born in the greater metropolitan areas of Boston, Philadelphia, Toronto, and between 1983 and 1985, part of Iowa. Subjects identified through review of admissions and discharges at major referral hospitals and clinics and through regular contact with newborn nurseries in community hospitals. A random sample of nonmalformed infants was identified at the birth hospitals as potential controls (only after 1993). | Overall percentages < 24: 28.11% 25-29: 36.71% 30-34: 25.87% >35: 9.3% | 2%
Mills et al, 1989^96^ National Institute of Child Health and Human Development Neural Tube Defects Study Case-control United States Funding NR, conducted by NIH. Medium | Inclusion: National Institute of Child Health and Human Development Neural Tube Defects Study based in CA and IL. Cases were mothers of an infant or fetus with an NTD diagnosis prenatally or postnatally between June 15, 1985 and April 30, 1987 in IL or between August 1, 1985 and April 30, 1987 in CA. NTDs included anencephaly, meningocele, myelomeningocele, encephalocele, rachischisis, iniencephaly, and lipomeningocele. Two control groups, one mothers of a normal infant or fetus and one mothers of an abnormal or still-born infant or fetus. Exclusion: Cases excluded insolated hydrocephalus, hydranencephaly, dermal sinus, and spina bifida occulta. Abnormal control group excluded mothers of infants with malformations related to vitamin use. Mothers with a history of NTDs in a first-degree relative were excluded from both control groups. | G1: Cases, mothers of an infant or fetus with an NTD (n=571) G2: Controls, mothers of normal infants (n=573) G3: Controls, mothers of an abnormal or stillborn infant or fetus (n=546) | Vitamin use 30 days before the first day of the last menstrual period and ending about 45 days thereafter. Study based in CA and IL. Cases included mothers of an infant or fetus with an NTD diagnosis prenatally or postnatally between June 15, 1985 and April 30, 1987 in IL or between August 1, 1985 and April 30, 1987 in CA. | < 21: 11.60% 21-25: 25.92% 26-30: 34.14% 31-35: 20.18% 36-40: 7.04% 41-45: 1.01% Unknown: 0.12% | 39%
Milunsky et al, 1989^97^ Moore et al, 2003^98^ Cohort United States Study 1: National Institute of Neurological Disorders and Stroke Study 2: March of Dimes Birth Defects Foundation National Institute of Neurological Disorders and Stroke Medium | Inclusion: Women were identified and recruited when they had a MSAFP screen or amniocentesis. They were receiving prenatal care and routine MSAFP screening in the practices of over 100 participating obstetricians. MSAFP and amniotic fluid samples were analyzed at the Center for Human Genetics of Boston University School of Medicine. Remaining amniocenteses were performed and analyzed at other genetic centers throughout the country and the results were made available to the researchers. Exclusion: Interviews of mothers pregnant a 2nd or 3rd time during study were excluded. | G1: Use of multivitamins containing folic acid G2: No use of multivitamins containing folic acid (or use less than 1 a week) Total: (n=22,715; multivitamin use information available) | 3 months prior to pregnancy through 1st 3 months of pregnancy Women were identified and recruited when they had a MSAFP screen or amniocentesis at 16 weeks of pregnancy between October 1984 and June 1987. Women were receiving prenatal care and routine MSAFP screening in the practices of over 100 participating obstetricians. | Study 1 <20: 2% 20-29: 44% 30-39: 52% ≥40: 2% Study 2 <30: 2% 30-39: 44% ≥40: 2% | Study 1: 4% Study 2: NR
Moseley et al, 2009^87^ National Birth Defects Prevention Study Case-control United States Centers for Disease Control and Prevention Medium | Inclusion: National Birth Defects Prevention Study, began in 1997 and includes participants from 10 population-based birth defects surveillance systems (Arkansas, California, Georgia, Iowa, Massachusetts, New Jersey, New York, North Carolina, Texas, or Utah). Cases, pregnancy affected by anencephaly or spina bifida that did not result from a single gene or chromosomal abnormality. Controls, random sample of women from each center site who delivered a liveborn infant without a structural birth defect. Included pregnancies were conceived on or after July 1, 1998. Exclusion: Women with type 1 or 2 diabetes or use of periconceptional use of any folate antagonist medication. Pregnancies resulting in multiple births. Women with incomplete food frequency questionnaires or supplement use information. | G1: Women with a pregnancy affected by spina bifida or anencephaly that did not result from a single gene or chromosomal abnormality G2: Women who delivered a live-born infant without a structural birth defect | Folic acid supplementation 3 months before pregnancy through 1st month of pregnancy Population-based surveillance systems in 10 states. Data collected from medical records, birth certificate data, or hospital birth logs. | Median age at conception G1: 26 G2: 27 | 42%
Shaw et al, 1995^82^ California Birth Defects Monitoring Program Case-control United States NR Medium | Inclusion: California Birth Defects Monitoring Program (CBDMP): birth years between June 1, 1989 and May 31, 1991. Cases: women who had liveborn and stillborn infants with NTDs; place of delivery in California county other than Los Angeles, Ventura, or Riverside; mother was a resident of California; and those who had NTD-affected pregnancies that were terminated. Controls: singletons born alive in the specified month and year in that hospital; mother was a resident of California; and no reportable birth defect. Exclusion: Women who spoke only languages other than English or Spanish. Previous NTD affected pregnancies. | G1: Singleton liveborn infants and electively terminated fetuses with an NTD (anencephaly, spina bifida cystica, craniorrhachischisis, and iniencephaly) (n = 538) G2: Singleton live births without a reportable birth defect (n = 539) | 3 months before pregnancy and/or first 3 months after conception California Birth Defects Monitoring Program (CBDMP), birth years between June 1, 1989 and May 31, 1991. Cases, women who had live- and stillborn infants with NTDs and those who had NTD-affected pregnancies that were terminated after prenatal diagnosis (February 1, 1989-January 31, 1991). Controls, an equal number of singleton live births randomly selected in proportion to hospital's contributions to total population of infants born alive in California. | Overall <20: 10.86% 20-24: 27.21% 25-29: 29.80% 30-34: 22.47% ≥35: 9.66% | 54%
Suarez et al, 2000^22^ Texas Department of Health's Neural Tube Defect Project United States Centers for Disease Control and Prevention Medium | Inclusion: Texas Department of Health's Neural Tube Defect Project, projects occurs in 14 Texas counties along the US-Mexico border. Cases, infants or fetuses with anencephaly (including craniorachischisis and iniencephaly), spina bifida, or encephalocele identified at birth or prenatally between January 1995 and February 1999. Cases included diagnoses made among liveborns, stillborns, and fetuses at all gestational ages, and included abortions, whether induced or spontaneous. Control, women from study area who had normal births during the same time period. Exclusion: Controls were ineligible if they were not a resident of the area or if they had an infant with an apparent or prenatally diagnosed congenital abnormality | G1: Infants or fetuses who had anencephaly (including craniorachischisis and iniencephaly), spina bifida, or encephalocele identified at birth or prenatally (n=148) G2: Normal live births (n=158) | 3 months before conception to 3 months after conception Texas Department of Health's Neural Tube Defect Project, occurrence of NTDs in 14 Texas counties along the US-Mexico border identified at birth or prenatally between January 1995 and February 1999. Surveillance included hospitals, birthing centers, genetics clinics, ultrasound centers, licensed abortion centers, and approximately midwives in the region. | < 20: 25.50% 20-24: 32.68% 25-29: 24.84% >30-39: 16.99% | 100%
Vollset et al, 2005^83^ Medical Birth Registry of Norway Case-control Norway NR Medium | Inclusion: Medical Birth Registry of Norway, women who gave birth from December 1998 through the end of 2001. Information on IVF pregnancies obtained by contacting fertility clinics in Denmark and Sweden. Exclusion: NR | G1: Preconceptional use of folate (n=11,077) G2: No preconceptional use of folate (n=164,965) | Preconception Medical Birth Registry of Norway, women who gave birth from December 1998 through the end of 2001. Information on IVF pregnancies obtained by contacting fertility clinics in Denmark and Sweden. | NR | NR
Werler et al, 1993^99^ Case-control United States and Canada Maternal and Child Health Resources Development grant; Marion Merrell Dow; Food and Drug Administration Cooperative Agreement; Hoffmann-LaRoche Medium | Inclusion: Study subjects (liveborn and stillborn infants and therapeutic abortuses) recruited from tertiary and birth hospitals in greater metropolitan Boston, MA, Philadelphia, PA, and Toronto, Ontario. Primary physicians of potential subjects were asked for permission to contact mothers. Cases: subjects with anencephaly, spina bifida, or encephalocele. Controls: subjects with other major malformations. Exclusion: Subjects with chromosomal anomalies or mendelian-inherited disorders; recurrent NTD cases; oral clefts. | G1: Liveborn, stillborn infants, and therapeutic abortions with anencephaly, spina bifida, or encephalocele (n= 436) G2: Liveborn, stillborn infants, and therapeutic abortions with other major malformations (n=2615) | Periconceptional period (interval from 28 days before the last menstrual period (LMP) through the 28 days after the LMP (the first lunar month). Study subjects recruited from tertiary and birth hospitals in greater metropolitan Boston, MA, Philadelphia, PA, and Toronto, Ontario. Primary physicians of potential subjects were asked for permission to contact mothers. | NR | NR

G1 = group 1; G2 = group 2; G3 = group 3; N = sample; NR = not reported; NTD = neural tube defect

Appendix F Table 2 Characteristics of Included Systematic Reviews and Meta-Analyses

First Author Study Design Search Dates Country Funding | Eligibility Criteria | Studies Included in Review | Included Study Designs | Intervention Dose Time Period | Overall Sample Size | Countries Included
Crider et al, 2013^101^ SR/meta-analysis Inception of database to March 2012 United States CDC | 1) Randomized, controlled trial, cohort, case-control, or cross-sectional study; 2) report the exposure of natural food folate intake, folic acid intake from fortified foods, total folate intake from foods (e.g., dietary folate equivalents), folic acid intake from supplements, or maternal or cord blood serum, plasma, or red blood cell folate concentrations; 3) have an exposure timing during the periconceptional period or during pregnancy; 4) provide results on at least one allergic or respiratory outcome; and 5) include an evaluation of the direct association between folic acid exposure and one of the outcomes of interest | 5 in meta-analysis Håberg et al, 2009^102^ Kiefte-de Jong et al, 2012^103^ Magdelijns et al, 2011^104^ Martinussen et al, 2012^105^ Whitrow et al, 2009^106^ | 10 cohort studies, 3 nested case-control studies, 1 case-control, 2 cohort, 2 case-control | Folic acid supplementation 400-500 μg/d Prepregnancy and first trimester | 45,642 | The Netherlands, Norway, Australia, United States
Yang et al, 2015^108^ Meta-analysis Earliest available date to May 2013 China NR | Exposure was maternal folic acid supplementation during pregnancy; outcome was infant asthma; analytical study (case-control studies or cohort studies); available multivariate-adjusted relative risks (RRs), hazard ratios (HRs) or odds ratios (ORs) with 95% confidence intervals (CIs); unrelated case and control groups or exposed and unexposed groups in a cohort study and all subjects from the same temporally and geographically defined underlying population. | Bekkers et al, 2012^100^ Granell et al, 2008^107^ Magedlijns et al, 2011^104^ Martinussen et al, 2012^105^ Whitrow et al, 2009^106^ | 5 cohort studies | Folic acid supplementation Range NR Prepregnancy | 14,438 | Australia, the Netherlands, United Kingdom

G1 = group 1; G2 = group 2; N = sample; NR = not reported; NTD = neural tube defect.