# Appendix E Inclusion/Exclusion Status of Studies Included in 2009 Report

Appendix E Table 1 Overview of 2009 Included Studies and Inclusion/Exclusion Status in Current Report

First Author, Year | Status in Current Report | Reasons for Exclusion
Czeizel et al, 2004^81^ | Included
Goh et al, 2006^84^ | Excluded | Excluded due to poor quality.
Shaw et al, 1995^82^ | Included
Thompson et al, 2003^85^ | Excluded | Excluded for wrong intervention. Unable to separate out the effects of supplementation from diet.
Vollset et al, 2005^83^ | Included

Appendix E Table 2 Overview of Studies Excluded From the 2009 Report Due to Quality and Inclusion/Exclusion Status in Current Report

First Author, Year | Reasons for 2009 Exclusion | Status in Current Report | Reasons for Exclusion
Czeizel et al, 1996^158^ | Retrospective exposure assessment poses potential recall bias. Differential measurement of exposure causes potential measurement bias. Lower response rate in controls No adjustment for smoking | Excluded | Excluded for high risk of bias
Locksmith et al, 1998^174^ | Study type not included in review (not a systematic review) | Excluded | Excluded for wrong design
Kallen et al, 2002^175^ | Used involuntary childlessness as proxy for infertility Exposure assessed by questionnaire at gestational week 10–12: drugs taken “since she became pregnant” No information about dose, timing | Excluded | Excluded for wrong comparator
Lumley et al, 2001^176^ | Studies included were not recent (many published prior to 1995 and included in USPSTF previous evidence report). | Excluded | Excluded for wrong population
Medveczky et al, 2004^167^ | No information on overall effect of folic acid on NTDs | Excluded | Excluded for high risk of bias
Moore et al, 2003^98^ | This was a study of dose-response re-examining data from study reviewed in 1996 USPSTF report; no new information about overall benefits of folic acid supplementation | Included | Even though the previous report listed it as an exclude “after abstraction and quality rating”, the notes in the abstraction form indicate “This was a study of dose-response re-examining data from study reviewed in 1996 USPSTF report; no new information about overall benefits of folic acid supplementation
Shaw et al, 2002^170^ | No information on overall effect of folic acid on NTDs | Excluded | Excluded for high risk of bias
Shaw et al, 1998^177^ | No information on overall effect of folic acid on NTDs | Excluded | Excluded for wrong outcome
Shaw et al, 2001^178^ | No information on overall effect of folic acid on NTDs | Excluded | Excluded during title/abstract review
Shaw 1996^179^ | No information on overall effect of folic acid on NTDs | Excluded | Excluded during title/abstract review
Suarez et al, 2000^22^ | Study performed in high-risk population | Included | Even though the previous report listed it as an exclude “after abstraction and quality rating”, the notes in the abstraction form indicate that was excluded for “high-risk populations” - that is, the population of Mexican-Americans have a higher risk of NTDs
Ericson et al, 2001^161^ | Potential confounding by patients undergoing IVF or ovulation stimulation; subgroup analysis on women without “period of involuntary childlessness”, but authors reported known underreporting of infertility history (40% of women who underwent IVF or ovulation stimulation did not report involuntary childlessness.) Measurement validity issues: exposure measured at 10 weeks; reported folic acid use was 0.6% in this study based on Birth Registry, as compared to 8% in concurrent study. No information on doses or timing of initiation of folic acid Potential differential recall based on knowledge of twin gestation by 8–10 weeks | Excluded | Excluded for high risk of bias
Czeizel et al, 2004^157^ | No adjustment for possible confounders: IVF, ovulation induction, smoking No information on doses or timing of initiation of folic acid Potential differential recall based on knowledge of twin gestation early in pregnancy or twin delivery | Excluded | Excluded for high risk of bias
Kallen et al, 2004^164^ | Incomplete information on doses (women likely took either 400 micrograms or 5 mg) or whether prenatal vitamins with folic acid were included in analysis No information on timing of initiation or duration of exposure Initial comparability of groups unknown Potential differential recall based on knowledge of twin gestation by 8–10 weeks Residual confounding possible if incomplete reporting of fertility treatments. Unclear how many women were included in the final analysis. | Excluded | Excluded for high risk of bias