# Appendix D Risk of Bias Assessments for all Included Studies

Appendix D Table 1 Quality Assessments for All Included Systematic Reviews and Meta-Analyses (Part 1)

First Author, Year | Comprehensive literature search performed? | Was the status of publication used as an inclusion criterion? | Was an a priori design provided? | Was a list of studies provided? | Was there explicit inclusion/exclusion criteria for the selection of studies? | Were the characteristics of the included studies provided? | Was the likelihood of publication bias assessed? | Was there duplicate study selection and data extraction?
Brown et al, 2014^143^ | No | Unclear | No | No | No | Yes | No | Unclear
Crider et al, 2013^101^ | Yes | No | Unclear | No | Yes | Yes | Yes | Yes
Goh et al, 2006^84^ | Yes | No | No | No | No | No | Yes | Yes
Wang et al, 2015 ^109^ | Yes | No | Yes | Yes | Unclear | Yes | Yes | Yes
Wolff et al, 2009^36^ Wolff et al, 2009^86^ | Yes | Unclear | Yes | Yes | Yes | Yes | No | Yes
Yang et al, 2014^108^ | Yes | No | Unclear | No | Yes | Yes | Yes | Unclear

Appendix D Table 2 Quality Assessments for All Included Systematic Reviews and Meta-Analyses (Part 2)

First Author, Year | Was the scientific quality of the included studies assessed and documented? | Was the conflict of interest included? | Was the scientific quality of the included studies used appropriately in formulating conclusions? | Were the methods used to combine the findings of studies appropriate? | Were the authors' conclusions supported by the evidence they presented? | Quality Rating | Comments
Brown et al, 2014^143^ | No | No | NA | Unclear | No | Poor | Although the review is titled a systematic review the cruical aspects of a systematic review including details on searches, review, risk of bias appraisal, and synthesis are NR.
Crider et al, 2013^101^ | Yes | Unclear | Yes | Yes | Yes | Good
Goh et al, 2006^84^ | No | No | No | Yes | Yes | Poor | The quality of studies is not assessed. The characteristics of studies included in the meta-analysis were not presented; Includes an appropriate synthesis and statistical testing, but does not include a discussion of publication bias.
Wang et al, 2015 ^109^ | Yes | Yes | Yes | Yes | Yes | Fair | A list of excluded studies and the inclusion criteria was not provided.
Wolff et al, 2009^36^ Wolff et al, 2009^86^ | Yes | no | Yes | NA | Yes | Good
Yang et al, 2014^108^ | Yes | Unclear | Unclear | Yes | Yes | Fair | Unclear how authors used risk of bias assessments in the analysis. The study noted that they included high quality studies.

NA = not applicable

Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions.

Fair: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies.

Poor: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies.

Appendix D Table 3 Quality Assessments for All Included Randomized, Controlled Trials, Case Control Studies, and Cohort Studies (Part 1)

First Author, Year | Were eligibility criteria described clearly? | Are the inclusion/exclusion criteria measured using valid and reliable measures, implemented across all study participants? | Was the symptom status of subjects determined using valid and reliable methods, implemented across all study participant? | Was the intervention or exposure clearly defined, across all study participants? | Was method of randomization adequate? | Was allocation concealment adequate?
Abe et al, 2014^144^ | No | Unclear | NA | Unclear | NA | NA
Abe et al, 2013^145^ | No | Unclear | NA | No | NA | NA
Abe et al, 2015^146^ | No | Unclear | NA | Unclear | NA | NA
Agopian et al, 2013^9^ | Yes | Yes | Yes | No | NA | NA
Ahrens et al, 2011^11^ | Yes | Yes | Unclear | Yes | NA | NA
Berry et al, 2004^147^ | Yes | Yes | Yes | No | NA | NA
Botto et al, 2002^148^ | Yes | Yes | Yes | Yes | NA | NA
Bower et al, 1989^149^ Bower, 1992^150^ | Yes | Yes | Yes | No | NA | NA
Brescianini et al, 2012^151^ | No | Unclear | Yes | Unclear | NA | NA
Carmichael et al, 2010^152^ | Yes | Yes | Yes | No | NA | NA
Chandler et al, 2012^153^ | Yes | Yes | Yes | No | NA | NA
Charles et al, 2004^154^ Charles et al, 2005^155^ Taylor et al, 2015^156^ | Yes | Yes | Yes | Yes | No | Yes
Correa et al, 2012^28^ | Yes | Yes | Yes | No | NA | NA
Czeizel et al, 2004^157^ | Yes | Yes | Yes | Yes | NA | NA
Czeizel et al, 2004^81^ | Yes | Yes | NA | Yes | NA | NA
Czeizel et al, 1992^88^; Czeizel et al, 1993^89^ Czeizel et al, 1993^92^ Czeizel et al, 1994^90^ Czeizel et al, 1994^91^ Czeizel et al, 1996^94^ Czeizel et al, 1998^93^ | Yes | Yes | NA | Yes | Yes | Unclear
Czeizel et al, 1996^158^ | Yes | Yes | Yes | Yes | NA | NA
De Marco et al, 2011^159^ | Yes | Yes | Yes | Yes | NA | NA
DeSoto et al, 2012^160^ | Yes | Yes | Yes | No | NA | NA
Ericson et al, 2001^161^ | No | No | NA | No | NA | NA
Gildestad et al, 2013^162^ | Unclear | Unclear | Unclear | Unclear | NA | NA
Haberg et al, 1994^163^ | Unclear | Unclear | NA | Unclear | NA | NA
Hernandez et al, 2001^95^ | Yes | Yes | Yes | Unclear | NA | NA
Kallen et al, 2004^164^ | Yes | Yes | Yes | No | NA | NA
Kallen et al, 2007^165^ | Yes | Yes | NA | No | NA | NA
Kondo et al, 2015^166^ | No | Yes | Unclear | No | NA | NA
Medvezky et al, 2003^167^ | Yes | Yes | Yes | No | NA | NA
Mills et al, 1989^96^ | No | Yes | Yes | Yes | NA | NA
Moore et al, 2003^98^ Milunsky et al, 1989^97^ | Yes | Yes | NA | Yes | NA | NA
Mosley 2009 et al,^87^ | Yes | Yes | Yes | Yes | NA | NA
Mulinare et al, 1988^168^ | Yes | Yes | Yes | Yes | NA | NA
Ohya et al, 2011^169^ | No | Unclear | NA | Unclear | NA | NA
Shaw et al, 2002^170^ | Yes | Yes | Yes | No | NA | NA
Shaw et al, 1995^82^ | Yes | Yes | Yes | Yes | NA | NA
Suarez et al, 2000^22^ | Yes | Yes | Unclear | Yes | NA | NA
Veeranki et al, 2014^171^ | Yes | Yes | NA | No | NA | NA
Veeranki et al, 2014^172^ | No | Unclear | NA | No | NA | NA
Veeranki et al, 2015^173^ | Yes | Yes | NA | No | NA | NA
Vollset et al, 2005^83^ | Yes | Yes | Yes | No | NA | NA
Werler et al, 1993^99^ | Yes | Unclear | Yes | Yes | NA | NA

NA = not applicable

Appendix D Table 4 Quality Assessments for All Included Randomized, Controlled Trials, Case Control Studies, and Cohort Studies (Part 2)

First Author, Year | Was the strategy for recruiting participants into the study the same across study groups? | Do start of followup and start of intervention coincide? | Are baseline characteristics similar between groups? | Did the study control for baseline differences between groups? | Were the participants and the administrators of the intervention blinded to the intervention or exposure status of participants? | Were the outcome assessors blinded to the outcome status of participants?
Abe et al, 2014^144^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear
Abe et al, 2013^145^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear
Abe et al, 2015^146^ | Unclear | Unclear | Unclear | Unclear | No | Unclear
Agopian et al, 2013^9^ | No | NA | No | Yes | NA | NA
Ahrens et al, 2011^11^ | Unclear | NA | No | Yes | NA | NA
Berry et al, 2004^147^ | NA (registry) | No | Unclear | Unclear | NA | Unclear
Botto et al, 2002^148^ | No | NA | Yes | Yes | NA | Yes
Bower et al, 1989^149^ Bower et al, 1992^150^ | No | NA | Unclear | Unclear | NA | NA
Brescianini et al, 2012^151^ | Unclear | No | Unclear | Unclear | NA | NA
Carmichael et al, 2010^152^ | Yes | NA | No | Yes | NA | NA
Chandler et al, 2012^153^ | No | NA | No | Yes | NA | NA
Charles et al, 2004^154^ Charles et al, 2005^155^ Taylor et al, 2015^156^ | NA | NA | No | Yes | No | Unclear
Correa et al, 2012^28^ | No | NA | No | Yes | NA | NA
Czeizel et al, 2004^157^ | Yes | No | No | No | NA | NA
Czeizel et al, 2004^81^ | No | no | No | Yes | No | Unclear
Czeizel et al, 1992^88^; Czeizel et al, 1993^89^ Czeizel et al, 1993^92^ Czeizel et al, 1994^90^ Czeizel et al, 1994^91^ Czeizel et al, 1996^94^ Czeizel et al, 1998^93^ | NA | Yes | Yes | NA | Unclear | Unclear
Czeizel et al, 1996^158^ | Yes | No | Unclear | Unclear | NA | NA
De Marco et al, 2011^159^ | Yes | NA | No | Yes | NA | NA
DeSoto et al, 2012^160^ | Yes | NA | Yes | Yes | NA | NA
Ericson et al, 2001^161^ | Unclear | No | Unclear | Unclear | Unclear | Unclear
Gildestad et al, 2013^162^ | Unclear | No | Unclear | Unclear | Unclear | Unclear
Haberg et al, 1994^163^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear
Hernandez et al, 2001^95^ | Yes | NA | No | Yes | NA | Unclear
Kallen et al, 2004^164^ | NA (registry) | No | Unclear | Unclear | NA | Unclear
Kallen et al, 2007^165^ | Yes | No | No | Yes | Unclear | Unclear
Kondo et al, 2015^166^ | No | NA | No | Yes | NA | NA
Medvezky et al, 2003^167^ | Yes | NA | Unclear | Unclear | NA | NA
Mills et al, 1989^96^ | No | NA | No | Yes | NA | Unclear
Moore et al, 2003^98^ Milunsky et al, 1989^97^ | Yes | No | No | Yes | No | No
Mosley et al, 2009^87^ | Yes | NA | Yes | Yes | NA | Unclear
Mulinare et al, 1988^168^ | No | NA | Unclear | Unclear | NA | Unclear
Ohya et al, 2011^169^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear
Shaw et al, 2002^170^ | No | NA | Unclear | Unclear | NA | NA
Shaw et al, 1995^82^ | No | NA | No | Yes | NA | NA
Suarez et al, 2000^22^ | No | NA | Unclear | Yes | NA | NA
Veeranki et al, 2014^171^ | Yes | No | No | Yes | Unclear | Unclear
Veeranki et al, 2014^172^ | Yes | No | Unclear | Unclear | No | Unclear
Veeranki et al, 2015^173^ | Yes | No | No | Yes | No | Yes
Vollset et al, 2005^83^ | Yes | Unclear | Unclear | Yes | Unclear | Unclear
Werler et al, 1993^99^ | Unclear | Yes | Unclear | No | NA | NA

NA= not applicable

Appendix D Table 5 Quality Assessments for All Included Randomized, Controlled Trials, Case Control Studies, and Cohort Studies (Part 3)

First Author, Year | Were outcome assessors blinded to the exposure? | Was intervention fidelity adequate? | Was there a risk of recall bias? | Did the study focus on the time period that we are interested in? | Did researchers rule out any impact from a concurrent intervention or an unintended exposure that might bias results? | Did variation from the study protocol compromise the conclusions of the study?
Abe et al, 2014^144^ | NA | Unclear | Unclear | Unclear | Unclear | Unclear
Abe et al, 2013^145^ | NA | Unclear | Yes | Unclear | No | NA
Abe et al, 2015^146^ | NA | Unclear | Yes | Yes | Unclear | NA
Agopian et al, 2013^9^ | Unclear | Unclear | Unclear | Yes | Yes | NA
Ahrens et al, 2011^11^ | Yes | Unclear | Unclear | Yes | Yes | NA
Berry et al, 2004^147^ | NA | Unclear | Unclear | No | No | NA
Botto et al, 2002^148^ | Unclear | Yes | Unclear | Yes | Yes | NA
Bower et al, 1989^149^ Bower et al, 1992^150^ | Unclear | Unclear | Unclear | Unclear | Yes | NA
Brescianini et al, 2012^151^ | Unclear | Unclear | Unclear | Unclear | No | NA
Carmichael et al, 2010^152^ | Unclear | Unclear | Unclear | No | Yes | NA
Chandler et al, 2012^153^ | Unclear | Unclear | Yes | Yes | Yes | NA
Charles et al, 2004^154^ Charles et al, 2005^155^ Taylor et al, 2015^156^ | NA | Yes | No | Yes | No | No
Correa et al, 2012^28^ | Unclear | Unclear | Yes | No | No | NA
Czeizel et al, 2004^157^ | Unclear | Unclear | Unclear | Unclear | No | NA
Czeizel et al, 2004^81^ | Unclear | Unclear | No | Yes | No | No
Czeizel et al, 1992^88^; Czeizel et al, 1993^89^ Czeizel et al, 1993^92^ Czeizel et al, 1994^90^ Czeizel et al, 1994^91^ Czeizel et al, 1996^94^ Czeizel et al, 1998^93^ | NA | Yes | No | Yes | No | No
Czeizel et al, 1996^158^ | Unclear | Unclear | Unclear | Yes | No | NA
De Marco et al, 2011^159^ | Unclear | Yes | Unclear | No | No | NA
DeSoto et al, 2012^160^ | Unclear | Unclear | Yes | No | No | NA
Ericson et al, 2001^161^ | NA | Yes | Unclear | Unclear | No | NA
Gildestad et al, 2013^162^ | NA | Unclear | Unclear | Unclear | No | NA
Haberg, 1994^163^ | NA | Unclear | Unclear | Yes | Unclear | NA
Hernandez et al, 2001^95^ | Unclear | Yes | Unclear | No | No | NA
Kallen et al, 2004^164^ | NA | Unclear | Unclear | No | No | NA
Kallen et al, 2007^165^ | NA | Yes | Unclear | Unclear | No | NA
Kondo et al, 2015^166^ | No | Unclear | Yes | Unclear | No | NA
Medvezky et al, 2003^167^ | Unclear | Unclear | Unclear | No | Unclear | NA
Mills et al, 1989^96^ | Yes | Yes | Unclear | Yes | Yes | NA
Moore et al, 2003^98^ Milunsky et al, 1989^97^ | NA | Unclear | Unclear | No | Yes | NA
Mosley et al, 2009^87^ | Unclear | Yes | Unclear | Yes | Yes | NA
Mulinare et al, 1988^168^ | Yes | Unclear | Yes | No | No | NA
Ohya et al, 2011^169^ | NA | Unclear | Unclear | Unclear | Unclear | Unclear
Shaw et al, 2002^170^ | Unclear | Unclear | Yes | No | Yes | NA
Shaw et al, 1995^82^ | Yes | Unclear | Unclear | Yes | Yes | NA
Suarez et al, 2000^22^ | Unclear | Yes | Unclear | Yes | Unclear | NA
Veeranki et al, 2014^171^ | NA | Unclear | No | Unclear | No | NA
Veeranki et al, 2014^172^ | NA | Unclear | No | Yes | No | NA
Veeranki et al, 2015^173^ | NA | Unclear | No | Unclear | No | NA
Vollset et al, 2005^83^ | NA | Unclear | No | Unclear | No | NA
Werler et al, 1993^99^ | Unclear | Yes | Yes | Yes | Yes | NA

NA = not applicable

Appendix D Table 6 Quality Assessments for all Included Randomized, Controlled Trials, Case Control Studies, and Cohort Studies (Part 4)

First Author, Year | What was the overall attrition/overall response rate? | What was the overall differential attrition? | Did the study have high attrition or low response rate raising concern for bias? | Is the analysis conducted on an intention-to-treat basis? | Did the analysis adjust for potential confounders? | Did the study have cross-overs or contamination raising concern for bias?
Abe et al, 2014^144^ | Unclear | Unclear | Unclear | NA | Unclear | Unclear
Abe et al, 2013^145^ | Unclear | Unclear | Unclear | NA | Unclear | Unclear
Abe et al, 2015^146^ | Unclear | Unclear | Unclear | NA | Yes | Unclear
Agopian et al, 2013^9^ | Response rate (overall sample in original study; see Yoon et al, 2001 companion article) G1+G2: ∼74 (NR out of 7,470) G2: ∼63 (NR out of 3,821) | NA | Unclear | NA | Unclear | NA
Ahrens et al, 2011^11^ | G1: 66% G2: 53% | NA | No | NA | Yes | NA
Berry et al, 2004^147^ | Unclear | Unclear | Unclear | NA | Yes | Unclear
Botto et al, 2002^148^ | Overall sample G1: 69% G2: 71% NTD analysis G1: NR G2: NR | NA | Unclear | NA | Unclear | NA
Bower et al, 1989^149^ Bower et al, 1992^150^ | G1: 93% G2: 88% G3: 84% | Response rate G1: 93 (77/83) G2: 88 (77/87) G3: 84 (154/183) | No | NA | No | NA
Brescianini et al, 2012^151^ | G1: 93% G2: 88% G3: 84% | NA | No | NA | No | NA
Carmichael et al, 2010^152^ | G1: 73% (146/200) G2: 79% (191/241) G3: 80% (626/786) | NA | No | NA | Yes | NA
Chandler et al, 2012^153^ | 62% for anencephaly; 76% for spina bifida and 71% for controls | NA | No | NA | Unclear | NA
Charles et al, 2004^154^ Charles et al, 2005^155^ Taylor et al, 2015 ^156^ | Unclear | Unclear | Unclear | No | NA | No
Correa et al, 2012^28^ | Overall, 70% among mothers of case infants and 67% among mothers of control infants. Response rate NR for NTD mothers. | NA | Unclear | NA | Yes | NA
Czeizel et al, 2004^157^ | Unclear | NA | Unclear | NA | Yes | NA
Czeizel et al, 2004^81^ | Overall attrition unclear | G1: 3,069/3,981 (77.1%) G2: Unclear | Yes | No | Yes | Unclear
Czeizel et al, 1992^88^ Czeizel et al, 1993^89^ Czeizel et al, 1993^92^ Czeizel et al, 1994^90^ Czeizel et al, 1994^91^ Czeizel et al, 1996^94^ Czeizel et al, 1998^93^ | 1% | 0.10% | No | NA | NA | No
Czeizel et al, 1996^158^ | 63% for negative controls, rate for positive controls NR | NA | Unclear | Na | No | NA
De Marco et al, 2011^159^ | Response rate G1: 92% (133/145) G2: 82% (273/332) | NA | No | NA | Unclear | NA
DeSoto et al, 2012^160^ | Response rate G1: 48.1% (321/668) G2: 31.7% (774/2444) | NA | Yes | NA | Unclear | NA
Ericson et al, 2001^161^ | Unclear | Unclear | Unclear | NA | Yes | No
Gildestad et al, 2013^162^ | Unclear | NA | Unclear | NA | Unclear | Unclear
Haberg et al, 1994^163^ | Unclear | Unclear | NA | Unclear | Unclear | Unclear
Hernandez et al, 2001^95^ | Response rate G1: 84% (1,242/NR) G2: 83% (6,600/NR) G3: 80% (1,626/NR) G4: NR (2,138/NR) | NA | No | NA | No | NA
Kallen et al, 2004^164^ | Unclear | Unclear | Unclear | NA | Yes | Unclear
Kallen et al, 2007^165^ | Unknown | Unclear | Unclear | NA | Yes | No
Kondo et al, 2015^166^ | Response rate G1: 79% G2: 56% | NA | No | NA | Yes | NA
Medvezky et al, 2003^167^ | 96.9% cases; 96% other non-NTD cases; 83.1% controls | NA | Yes (was unclear) | NA | Unclear | NA
Mills et al, 1989^96^ | Response rate G1: 64.8%-82% (571/NR) G2: NR (546/NR) G3: NR (573/NR) | NA | No | NA | Unclear | NA
Moore et al, 2003^98^ Milunsky et al, 1989^97^ | 3% (715/23,491) | Unclear | No | NA | Unclear | No
Mosley et al, 2009^87^ | 62% anencephaly; 76% spina bifida; 71% controls | NA | No | NA | Yes | NA
Mulinare, 1988^168^ | G1: 347/519 (66.9%) G2: 2,829/4,043 (69.9%) | NA | No | NA | Yes | NA
Ohya et al, 2011^169^ | Unclear | Unclear | Unclear | NA | Unclear | Unclear
Shaw et al, 2002^170^ | Response rate G1 (NTD only): 84% G2: 76% from both control cohorts | NA | No | NA | No | NA
Shaw et al, 1995^82^ | 88% both groups | NA | No | NA | Yes | NA
Suarez et al, 2000^22^ | 72% cases; 53% controls | NA | No | NA | Yes | NA
Veeranki et al, 2014^171^ | Unclear | Unclear | Unclear | NA | Yes | Unclear
Veeranki et al, 2014^172^ | Unclear | Unclear | Unclear | NA | Yes | Unclear
Veeranki et al, 2015^173^ | Unclear | Unclear | Unclear | NA | Yes | Unclear
Vollset et al, 2005^83^ | Unclear | Unclear | Unclear | NA | Yes | Unclear
Werler et al, 1993^99^ | G1: 567-436/567=76.9% G2: 3672-2,615/3,672= 71.2% | NA | No | NA | Yes | NA

G1 = group 1; G2 = group 2; G3 = group 3; G4 = group 4; ITT = intent to treat; NA = not applicable; NR = not reported; NTD = neutral tube defect

Appendix D Table 7 Quality Assessments for all Included Randomized, Controlled Trials, Case Control Studies, and Cohort Studies (Part 5)

First Author, Year | Were outcomes prespecified/defined and adequately described? | Were outcome measures valid and reliable? | Were all important outcomes considered? | Was the duration of followup adequate to assess the outcome? | Was an appropriate method used to handle missing data? | Quality Rating | Comments
Abe et al, 2014^144^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Not enough information in the publication to assess quality.
Abe et al, 2013^145^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Not enough information in the publication to assess quality.
Abe et al, 2015^146^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Not enough information in the publication to assess quality.
Agopian et al, 2013^9^ | Yes | NA | NA | NA | Unclear | Fair | Most of the major confounders were adjusted for in the analyses. However, there was still a possibility of residual confounding because some NTD-specific variables not controlled for, specifically, previous NTD pregnancy or having or having partner(s) with NTDs. Cases and controls selected from different populations. Specifically, cases could be stillborn infants or therapeutic abortions, while all controls were liveborn infants. Definition of exposure not defined clearly. Positive response to folic acid supplement use question could have indicated any frequency of usage.
Ahrens et al, 2011^11^ | Yes | NA | NA | NA | Unclear | Fair | Ascertainment of cases for non-live births is not routine. Unclear how missing data was handled (although “all women were included” in the analysis).
Berry et al, 2004^147^ | Yes | Yes | Yes | Yes | Unclear | Poor | The study itself does not describe the data source well, but it cites other studies that do. Based on these other studies, we infer that the exposure period starts before pregnancy and extends to first attendance (in 90% of cases before the end of the first trimester and usually around week 10) with lack of clarity on degree of exposure, difficult to clearly distinguish exposure from non-exposure; authors did not specify definition of exposure clearly (defined as any vs. no supplement), so the degree of adherence is unclear; although the study does not appear to account for fetal deaths, the resulting selection bias would serve to mute rather than exaggerate the effect of FA on twinning; study uses probabilistic simulations to assess bias caused by misclassification of the use of IVF.
Botto, 2002^148^ | es | NA | NA | NA | Unclear | Poor | Cases and controls selected from different populations. Cases could be liveborn or stillborn infants, while all controls were liveborn infants. No information about 1) timing of data collection given to assess recall bias; 2) whether potential NTD-specific confounders were measured or adjusted for in analyses; 3) exposure to dietary folate; 4) response rates for patients analyzed for analysis of NTD outcomes; or 5) whether MVs contained similar and clinically effective doses of FA. Missing data not accounted for in an ITT analysis; covers a 6 month period of exposure (3 months before to 3 months after pregnancy); no controls for concurrent interventions such as exposure to dietary folate, however, this sample was drawn before dietary supplementation; significant risk of recall bias because women asked to remember for a period ranging from 1968-1980. Only still births, no information on terminations. Cases included live an still-borns controls only
Bower et al, 1989^149^ Bower et al, 1992^150^ | Yes | NA | NA | NA | Unclear | Poor | Cases and controls selected from different populations. Cases could be stillborn infants or elective terminations following antenatal NTD diagnosis, while Control group 1 included liveborn infants and terminated pregnancies with non-NTD malformations and Control group 2 included live born infants only. Possibility of residual confounding because no NTD-specific variables controlled for in analyses. Definition of exposure not defined clearly. Positive response to folic acid supplement use question could have indicated any frequency of usage. Risk of recall bias because mothers interviewed up to 99 weeks after last menstrual period. Also, minor risk of interviewer bias during 5 interviews because interviewers unintentionally learned case-control status.
Brescianini et al, 2012^151^ | Unclear | NA | NA | NA | Unclear | Unclear | Meeting abstract with very little information to base judgment on most domains. Although study does not appear to account for fetal deaths, the resulting selection bias would serve to mute rather than exaggerate the effect of folic acid on twinning.
Carmichael et al, 2010^152^ | Yes | NA | NA | NA | Unclear | Poor | Unclear how missing data was handled; time period extends to 2 months before and 2 months after and with lack of clarity on degree of exposure, difficult to clearly distinguish exposure from non-exposure; authors did not specify definition of exposure clearly (defined as any vs. no supplement), so the degree of adherence is Unclear. The control group only looked at live births and not fetal deaths.
Chandler et al, 2012^153^ | Yes | NA | NA | NA | Unclear | Fair | See Yoon et al. (2001) for recruitment information. Cases and controls selected from different populations. Cases could be stillborn infants or therapeutic abortions, while all controls were liveborn infants. Also, definition of exposure not defined clearly. Positive response to folic acid supplement use question could have indicated any frequency of usage. Possibility of residual confounding because some NTD-specific variables not controlled for, specifically, previous NTD pregnancy or having or having partner(s) with NTDs. In addition, analyses not adjusted for comparisons across different centers.
Charles et al, 2004^154^ Charles et al, 2005^155^ Taylor et al, 2015^156^ | Yes | Yes | Yes | Yes | NA | Poor | Randomization was inadequate: “tablets were kept in numbered drawers and distributed in sequence.” Unclear whether administrators or outcome assessors were blinded because “The patients' notes were marked with a sticker the same colour as the tablets they were receiving.” Some proportion of deaths not linked to patient files (occuring before 1980) but followup N not reported, so rate of overall attrition and differential attrition is Unclear. Because N at followup is not reported, it does not appear that the analysis used an intention-to-treat analysis for the missing data.
Correa et al, 2012^28^ | Yes | NA | NA | NA | No | Poor | Unclear how missing data was handled but appears to have been excluded in some tables. Definition of exposure does not account for adherence to meds (“any use during the month before conception or during the first 3 months of pregnancy) so exposed vs. non-exposed not clearly demarcated; additionally, the time period of recall is 1 month before conception to 3 months after, so folic acid supplementation after becoming aware of pregnancy would be misclassified as pre-pregnancy exposure; mothers interviewed up to 24 months after birth so risk of recall bias; authors did not specify definition of exposure clearly, so the degree of adherence is Unclear. Controls were only live borns.
Czeizel et al, 2004^157^ | Yes | NA | NA | NA | Unclear | Poor | Does not mention how missing data was handled. Unclear how authors determined who were clearly users of folic acid. Unable to determine response rate due to limited information. Women continued folic acid usage until at least 3rd trimester. There was only one product of folic acid at the time of the study (3mg) and required a prescription. Unclear on baseline differences and if they were controlled for.
Czeizel et al, 2004^81^ | Yes | Yes | Yes | Yes | Unclear | Fair | The trial recruited patients to each arm differently. Supplemented women were recruited before pregnancy and asked to take vitamins and were followed up for several months. This recruitment before exposure and continuous measurement would have meant that all pregnancies and terminations would have been counted. Unsupplemented women were identified at 8–12 weeks of pregnancy, by which time, early pregnancy losses would have occurred (possibly due to lack of folic acid). Because one arm differentially identified women, this could have potentially led to a high and differential risk of selection bias, but the study restricted the analysis for supplemented cases with a pregnancy at 14 weeks. Thus the risk of differential selection bias was reduced but the risk of attrition bias was increased. A second potential source of bias arises from the residual confounding effects of having a higher proportion in the supplemented group of previous fetal deaths and in fact mortality because of congenital abnormalities.
Czeizel et al, 1992^88^ Czeizel et al, 1993 Czeizel et al, 1993^92^ Czeizel et al, 1994^90^ Czeizel et al, 1994^91^ Czeizel et al, 1996^94^ Czeizel et al, 1998^93^ | Yes | Yes | Yes | Yes | NA | Fair | Does not include fetal death in the analysis (but provides data for that calculation; Unclear allocation concealment and blinding processes (participants blinded, Unclear whether administrators or outcome assessors were blinded); does not conduct ITT but dropout extremely low so risk of bias low from dropout. Study did not consider diet and did not mention how missing data was handled.
Czeizel et al, 1996^158^ | Yes | NA | NA | NA | No | Poor | Does not include fetal deaths; study does not control for dietary intake but this study predates food fortification; relevant analysis (supplementation vs. no supplementation in NTD in critical period vs. healthy births) does not control for confounding; does not measure adherence. Unclear on how missing data was handled.
De Marco et al, 2011^159^ | Yes | NA | NA | NA | Unclear | Poor | Well-defined outcomes; exposure is slightly outside our period of interest (i.e., 3 months prior to pregnancy, rather 2 months prior to pregnancy). Possibility of residual confounding because some NTD-specific variables not controlled for, specifically, use of antiepileptic drugs or having or having partner(s) with NTDs. Investigators measured percentages of mothers with previous NTD-affected pregnancies, but relationship to outcomes of interest unlikely (see pg. 1080). In addition, dietary folate intake either not assessed or not taken into account in analyses. Risk of recall bias because mothers completed interviews 18-24 months after childbirth. Unclear how missing data affected findings.
DeSoto et al, 2012^160^ | Yes | Yes | NA | NA | Unclear | Poor | Definition of folic acid exposure not defined clearly. Positive response to folic acid supplement use question could have indicated any frequency of usage. High risk of recall bias because mothers asked about FA use 6-13 years after childbirth. In addition, dietary folate not taken into account. Unclear if important confounders related to ASD included in statistical analyses.
Ericson et al, 2001^161^ | Yes | Yes | Unclear | Yes | Unclear | Poor | Participation rates not reported; unclear whether the two groups are actually comparable-one group included multivitamin use only but whether folic acid was in vitamins and the amount is unclear; also unclear whether those taking folic acid tablets were or were not also taking multivitamins with folic acid.
Gildestad et al, 2013^162^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Not enough information in the publication to assess quality.
Haberg et al, 1994^163^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Not enough information in the publication to assess quality.
Hernandez et al, 2001^95^ | Yes | NA | NA | NA | Unclear | Fair | Possibility of residual confounding because numerous NTD-specific variables not controlled for, specifically, diabetes, family history of NTDs, prior NTD-affected pregnancy, or having or having partner(s) with NTDs. Dietary folate intake not accounted for in analysis of interest. Authors make point in Discussion that unaccounted effects of folate intake would reduce the magnitude of their findings, which were statistically significant. Outcome assessors blind to study hypothesis, but that does not mean they were blind to women's' case-control status.
Kallen et al, 2004^164^ | Yes | Yes | Yes | Yes | Unclear | Poor | Exposure period starts before pregnancy and extends to first attendance (in 90% of cases before the end of the first trimester and usually around week 10) with lack of clarity on degree of exposure, difficult to clearly distinguish exposure from non-exposure; authors did not specify definition of exposure clearly (defined as any vs. no supplement), so the degree of adherence is unclear; although study does not appear to account for fetal deaths, the resulting selection bias would serve to mute rather than exaggerate the effect of FA on twinning; study does not control for dietary intake but this study predates food fortification; study does not control for dietary intake but this study predates food fortification; study controls for use of ovarian stimulation drugs, but this control variable is insufficient because fertility treatment includes several other options
Kallen et al, 2007^165^ | Yes | Yes | Yes | Yes | Unclear | Poor | Response rate unclear; percentage of women approached who agreed to participate is unclear. Also, total number of eligible women is unclear. Women were recruited at the first antenatal visit, but the total number of women presenting for care during the time period is unclear. Also, the extent of folic acid not ascertained from participants.
Kondo et al, 2015^166^ | Yes | NA | NA | NA | No | Poor | Selection bias from being limited to live births. Definition of folic acid exposure not defined clearly. Positive response to folic acid supplement use question could have indicated any frequency of usage. High risk of recall bias because half of the control and case mothers asked about folic acid use 6–12 years after childbirth. In addition, dietary folate not taken into account. Controls and cases not matched on year or place of birth, statistically significant differences in knowledge of FA benefits.
Medvezky et al, 2003^167^ | Yes | NA | NA | NA | Unclear | Poor | Unclear how missing data handled. Exposure not well defined or quantified.
Mills et al, 1989^96^ | Yes | NA | NA | NA | Unclear | Fair | Eligibility criteria for cases Unclear because they do not clarify whether infants or fetuses were eligible if stillborns or had been aborted. Possibility of residual confounding because numerous NTD-specific variables not controlled for, specifically, diabetes, family history of NTDs, prior NTD-affected pregnancy, having or having partner(s) with NTDs, or treatment with folic acid antagonists. Unclear how high response rates for control groups were. Unclear how missing data was handled.
Moore et al, 2003^98^ Milunsky et al, 1989^97^ | Yes | Unclear | Yes | | Unclear | Fair | Physicians provided 76.5% of the outcome data, but if physicians did not respond, mothers completed the outcome questionnaires; information provided by mothers may not have been entirely accurate in terms of prenatal test results, presence of birth defects or chromosomal abnormalities, complications of pregnancy or delivery, complications of the newborn, or perinatal maternal illnesses. Treatment fidelity not entirely clear, specifically weekly frequency of folic acid supplementation. Possibility of residual confounding because use of folic acid antagonists not taken into account in analyses. Not enough information provided to calculate differential attrition, but overall attrition rate was very low for full sample and therefore unlikely to bias findings
Mosley et al, 2009^87^ | Yes | NA | NA | NA | Yes | Fair | Exposure not well defined or quantified. Response rates didn't approached 80% but relevant, without major apparent selection or diagnostic work-up bias.
Mulinare et al, 1988^168^ | Yes | NA | NA | NA | No | Poor | Missing data not accounted for in an ITT analysis; covers a 6 month period of exposure (3 months before to 3 months after pregnancy); No controls for concurrent interventions such as exposure to dietary folate, however, this sample was drawn before dietary supplementation; significant risk of recall bias because women asked to remember for a period ranging from 1968-1980. Only still births, no information on terminations. Cases included live an still-borns controls only.
Ohya et al, 2011^169^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Not enough information in the publication to assess quality.
Shaw et al, 2002^170^ | Yes | NA | NA | NA | Unclear | Poor | Unclear how missing data was handle, did not adjust for potential NTD confounders; wide range between those who actually used vitamin (did they use vitamin or mineral supplements during 4 month period but does not say how they divided group out), study does consider cereal usage but not other forms of dietary folate. Potential recall bias 3.7 to 3.9 years later. Does not mention miscarriages and stillbirths.
Shaw et al, 1995^82^ | Yes | NA | NA | NA | Unclear | Fair | 3 months before and 3 months after; did not control for all of the confounders for folate antagonist medications; does not mention miscarriages and stillbirths. Differences based on ethnicity, age, and education but study controlled for. No mention of how missing data was handled.
Suarez et al, 2000^22^ | Yes | NA | NA | NA | Unclear | Fair | 1) Response rate less than 80%; 2) some selection bias as controls do not include recruitment at all of the same centers; 3) study collects data on dietary folate intake, but no data shown of association of folic acid with NTDs, adjusted for dietary intake. Strength is adjustment for other confounders. Several issues: (1) very low prevalence of folic acid supplements, limited power (2) food frequency questionnaire doesn't distinguish 3 months prior to conception (3) differential recall period produced by not matching case and control infants/fetuses for gestational age (control women recalling exposures further in past than case women); (4) different response rate between case (72%) and control (53%)
Veeranki et al, 2014^171^ | Yes | Yes | Yes | Yes | Unclear | Poor | Exposure to multivitamin supplement defined as filling rather than consuming prenatal vitamins; assumes no misclassification from consumption of over-the-counter supplements; also needed only 1 day of fill in period of exposure to count as exposed; differences between exposed (G1) and non-exposed (G3) in prenatal care, maternal asthma, number of siblings: does not separate out the potential effect of folic acid specifically from other micronutrients that may have an independent effect on respiratory outcomes; does not control for dietary folate exposure; does not control for environmental exposure; excludes stillbirths and miscarriages so risk of selection bias; because of definition of exposure, Unclear whether time period of fill for first trimester covers the first month of pregnancy); loss through poor response rate or missing data NR so cannot judge attrition bias
Veeranki et al, 2014^172^ | Unclear | No | Unclear | Yes | Unclear | Poor | Exposure to multivitamin supplement defined as filling rather than consuming prenatal vitamins; assumes no misclassification from consumption of over-the-counter supplements; does not separate out the potential effect of folic acid specifically from other micronutrients that may have an independent effect on allergic rhinitis; does not control for dietary folate exposure; does not control for environmental exposure; excludes stillbirths and miscarriages so risk of selection bias; because of definition of exposure, Unclear whether time period of fill for first trimester covers the first month of pregnancy); may not include all cases of allergic rhinitis
Veeranki et al, 2015^173^ | Yes | No | Yes | Yes | Unclear | Poor | Exposure to multivitamin supplement defined as filling rather than consuming prenatal vitamins; assumes no misclassification from consumption of over-the-counter supplements; also needed only 1 day of fill in period of exposure to count as exposed; differences between exposed (G1) and nonexposed (G3) in prenatal care, maternal asthma, number of siblings: does not separate out the potential effect of folic acid specifically from other micronutrients that may have an independent effect on respiratory outcomes; does not control for dietary folate exposure; does not control for environmental exposure; excludes stillbirths and miscarriages and preterm, so risk of selection bias; because of definition of exposure, Unclear whether time period of fill for first trimester covers the first month of pregnancy; loss through poor response rate or missing data NR so cannot judge attrition bias; may not include all cases of asthma
Vollset et al, 2005^83^ | Yes | Yes | Yes | Yes | Unclear | Fair | Risk of recall bias in original data assumed to be high - based on estimates of underreporting of folate use, they estimated that 45% of women who took folate before conception were registered as nonusers and adjusted potential misclassification as a result; however, periconceptional use not defined, as a result, cannot tell if exposed vs. non-exposed is clearly defined; looks at pregnancies, but Unclear how stillbirths and terminations were handled; no adjustment for dietary folate; because of lack of definition of exposure, Unclear whether time period of fill for first trimester covers the first month of pregnancy); loss through poor response rate or missing data NR so cannot judge attrition bias
Werler et al, 1993^99^ | Yes | NA | NA | NA | No | Fair | Cases and controls identified by “systematic contact” at tertiary and birth hospitals, details NR, as a result, unable to determine whether cases and controls came from similar populations and had a similar chance of selection; looked at the effect of dietary intake of folate, but only for those with no use of supplements, so does not fully control for concurrent interventions

G1 = group 1; G3 = group 3; NA = not applicable; NR = not reported; NTD = neutral tube defect

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80%; reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention to treat analysis is used.

Fair: Studies will be graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred with follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention to treat analysis is done for RCTs.

Poor: Studies will be graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention to treat analysis is lacking.