# Appendix C Excluded Studies

X 1 | Wrong publication type (Editorials, Letters, Opinions, or Commentaries to the editor with no primary data, Nonsystematic Review articles)
X 2 | Wrong population (Populations were not women of childbearing age [e.g., pre-menarchy, post-menopausal, no potential for childbearing)
X 3 | Wrong or no comparator (Single group design with no comparator; Active comparator [e.g., head-to-head trial])
X 4 | Wrong or no outcome (See Include/Exclude criteria for exceptions)
X 5 | Wrong timing (supplementation initiated after the first trimester for benefits only)
X 6 | Wrong geographical setting (Countries with human development index of low to high)
X 7 | Wrong Study Design (Case reports, case series, cross-sectional designs)
X 8 | Wrong or no intervention (As defined in the Include/Exclude criteria)
X 9 | Study size <50 subjects
X 10 | Wrong language (non-English)
X 11 | Full-text irretrievable

1 (1968). Folic acid and combined iron and folic acid preparations. Br Med J.
2 (1977). Folates and the fetus. Lancet.
3 (1981). Trial of folate treatment to prevent recurrence of neural tube defects. Br Med J (Clin Res Ed).
4 (1982). Vitamin supplements to prevent neural tube defects. Lancet.
5 (1990). Vitamins during pregnancy and neural tube defects. JAMA.
6 (1990). Periconceptional use of multivitamins and the prevalence of neural-tube defects. N Engl J Med.
7 (1991). Vitamins to prevent neural tube defects. Lancet.
8 Centers for Disease Control. (1991). Use of folic acid for prevention of spina bifida and other neural tube defects--1983-1991. JAMA.
9 (1991). Folic acid to prevent neural tube defects. Lancet.
10 (1991). Folic acid and neural tube defects. Lancet.
11 (1991). Folic acid in the prevention of neural tube defects. Geneesmiddelenbulletin.
12 (1992). CDC report: Folic acid and pregnancy. Am Fam Physician.
13 (1994). Periodic health examination, 1994 update: 3. Primary and secondary prevention of neural tube defects. Canadian Task Force on the Periodic Health Examination. CMAJ.
14 (1996). Folic acid fortification. Nutr Rev.
15 (1997). Folic acid. Can Pharm J.
16 (1997). Low-dosage folic acid reduces the incidence of neural tube defects. Drugs and Therapy Perspectives.
17 (2002). Folate delivers head-to-toe health advantages. The B vitamin that benefits unborn babies may also protect the hearts and minds (and colons) of adults. Health News.
18 (2004). Folic acid supplementation to prevent neural tube defects. Med Lett Drugs Ther.
19 (2008). Folate and vitamin B12 deficiencies: proceedings of a WHO technical consultation held 18-21 October, 2005, in Geneva, Switzerland. Introduction. Food Nutr Bull.
20 Cochrane Pregnancy and Childbirth Group. (2015). About The Cochrane Collaboration.
21 Abramsky L, Noble J. (2002). Effects of folic acid. Lancet.
22 Al-Mendalawi MD. (2014). Towards a national program to combat neural tube defects in Iraq. Congenital Anomalies.
23 Althaus F. (1990). Folic acid supplementation during early pregnancy appears to lessen risk of neural tube defects. Fam Plann Perspect.
24 Banhidy F, Czeizel AE. (2012). Primary prevention of congenital abnormalities with specified origin. Clin Chem Lab Med.
25 Baxter P. (2014). Valproate and folic acid in pregnancy: associations with autism. Dev Med Child Neurol.
26 Bitran JD, Miller JB, Golomb HM. (1977). Megaloblastic anemia during pregnancy. J Reprod Med.
27 Bland JM. (2005). Taking folate in pregnancy and risk of maternal breast cancer: what's in a name?. BMJ.
28 Bower C. (1995). Folate and neural tube defects. Nutr Rev.
29 Bower C, Kurinczuk JJ, Stanley FJ. (1999). Spina bifida and folate. Med J Aust.
30 Bower C, Raymond M, Lumley J, et al. (1993). Trends in neural tube defects 1980-1989. Med J Aust.
31 Bower C, Werler MM. (2001). Folate before pregnancy: are we doing enough?. Med J Aust.
32 Breach J. (2007). Folic acid - Pharmacy or flour?. Australian Journal of Pharmacy.
33 Britton T. (1998). Women need to take folic acid sooner rather than later. Nurs Times.
34 Buehler JW, Mulinare J. (1997). Preventing neural tube defects. Pediatr Ann.
35 Burry J. (2008). Preventing neural tube defects with folic acid in pregnancy. Canadian Pharmacists Journal.
36 Buyse M. (2001). Preconceptual folic acid: opportunity for preconceptual counseling offers opportunity to help prevent neural tube defects. Med Health R I.
37 Byran JA. (1973). Use and abuse of hematinics. Am Fam Physician.
38 Campbell RK. (2001). The unnecessary epidemic of folic acid-preventable spina bifida and anencephaly. Pediatrics.
39 Capel I, Corcoy R. (2007). What dose of folic acid should be used for pregnant diabetic women?. Diabetes Care.
40 Chalmers TC, Sacks H. (1982). Vitamin supplements to prevent neural tube defects. Lancet.
41 Chan A, Pickering J, Haan E, et al. (2001). “Folate before pregnancy”: the impact on women and health professionals of a population-based health promotion campaign in South Australia. Med J Aust.
42 Chidambaram B. (2012). Folate in pregnancy. J Pediatr Neurosci.
43 Clarke R, Bennett D. (2014). Folate and prevention of neural tube defects. BMJ.
44 Crandall BF, Corson VL, Goldberg JD, et al. (1995). Folic acid and pregnancy. Am J Med Genet.
45 Cumming FJ, Bradley S. (1999). Spina bifida and folate. Med J Aust.
46 Czeizel AE. (1999). Folic acid fortification and supplementation. Am J Med Genet.
47 Czeizel AE. (2001). Folic acid and human malformations: misunderstandings. Reprod Toxicol.
48 Davis JA. (1980). Multivitamin prophylaxis against neural-tube defects. Lancet.
49 Davis RE. (1992). Folate supplementation. Med J Aust.
50 Davis RE. (2002). Effects of folic acid. Lancet.
51 Drife J, MacNab G. (1986). Prescribing in pregnancy. Mineral and vitamin supplements. Clin Obstet Gynaecol.
52 Ebrahim GJ. (2001). Role of folate in preventive medicine. J Trop Pediatr.
53 Elwood M. (1991). Folic acid prevents neural tube defects. Med J Aust.
54 Emery AE. (1977). Folates and fetal central-nervous-system malformations. Lancet.
55 Eskes TK, Steegers-Theunissen RP. (1994). Primary prevention of neural-tube defects with folic acid. Eur J Obstet Gynecol Reprod Biol.
56 Etzel RA. (2014). Foreword: Environmental chemical exposures and autism spectrum disorders: A review of the epidemiological evidence. Curr Probl Pediatr Adolesc Health Care.
57 Facchinetti F, Dante G. (2011). How we might do without vitamins. Pregnancy Hypertens.
58 Fekete K, Berti C, Cetin I, et al. (2010). Perinatal folate supply: relevance in health outcome parameters. Matern Child Nutr.
59 Fleming A. (2001). The role of folate in the prevention of neural tube defects: human and animal studies. Nutr Rev.
60 Franzen W. (1994). Prevention of neural tube defects. Lancet.
61 Freda MC. (1999). “Point four” the future. MCN Am J Matern Child Nurs.
62 Freeman NV, Rajab A. (1999). Neural tube defects. Trop Doct.
63 Frenkel EP, Yardley DA. (2000). Clinical and laboratory features and sequelae of deficiency of folic acid (folate) and vitamin B12 (cobalamin) in pregnancy and gynecology. Hematol Oncol Clin North Am.
64 Frost J. (1993). Folic acid: consider the evidence. MCN Am J Matern Child Nurs.
65 Gaull GE. (1996). Fortifying policy with science--the case of folate. J Nutr.
66 Gillies A, McLeod S, Carter Y. (1996). Periconceptual folate supplementation. Br J Gen Pract.
67 Glanville NT, Cook HW. (1992). Folic acid and prevention of neural tube defects. CMAJ.
68 Goldenberg RL, Tamura T. (1996). Prepregnancy weight and pregnancy outcome. JAMA.
69 Goldsmith GA. (1975). Vitamin B complex. Thiamine, riboflavin, niacin, folic acid (folacin), vitamin B12, biotin. Prog Food Nutr Sci.
70 Goodman M. (1992). Vital ingredient. Interview by Claire Laurent. Nurs Times.
71 Gordon N. (1995). Folate metabolism and neural tube defects. Brain Dev.
72 Greydanus DE, Van Dyke D. (2005). The sacred disease and the clinician's sacred duty. Int Pediatr.
73 Griffin JP. (1988). Vitamins and neural tube defects. Br Med J (Clin Res Ed).
74 Gupta H, Gupta P. (2004). Neural tube defects and folic acid. Indian Pediatr.
75 Guthrie EW. (2007). Bariatric surgery.
76 Hacohen Y, Lerman-Sagie T. (2006). Should folic acid fortification be mandatory in Israel?. Isr Med Assoc J.
77 Haddow JE. (2011). Folic acid and neural tube defects. Genet Med.
78 Hall JG. (1997). Give the embryo a chance. Nat Med.
79 Hall JG. (1997). Terathanasia, folic acid, and birth defects. Lancet.
80 Hall JG, Solehdin F. (1998). Folate and its various ramifications. Adv Pediatr.
81 Hall JG, Solehdin F. (1998). Genetics of neural tube defects. Mental Retardation and Developmental Disabilities Research Reviews.
82 Hansen HA. (1967). On the diagnosis of folic acid deficiency. Acta Obstet Gynecol Scand.
83 Harris R, Read AP. (1982). Spina bifida and vitamins. Br Med J.
84 Harrison KA. (1976). Sickle cell disease in pregnancy. Trop Doct.
85 Harrison KA. (1982). Anaemia, malaria and sickle cell disease. Clin Obstet Gynaecol.
86 Hauser WA. (2009). Folic acid supplementation: too much of a good thing?. J Neurol Neurosurg Psychiatry.
87 Havens DH, Levin BR. (1999). Good news for women and babies: folic acid prevents birth defects. J Pediatr Health Care.
88 Hawkins DF. (1986). Antimicrobial drugs in pregnancy and adverse effects on the fetus. J Obstet Gynaecol.
89 Hayden MR. (2003). New use for folic acid. Mo Med.
90 Hendricks K. (2001). Fecal folate. Am J Clin Nutr.
91 Herbert V. (1973). The five possible causes of all nutrient deficiency: illustrated by deficiencies of vitamin B 12. Am J Clin Nutr.
92 Herbert V. (1977). Anemias. Curr Concepts Nutr.
93 Herbert V. (1985). Megaloblastic anemias. Lab Invest.
94 Heseker H. (2011). Folic acid and other potential measures in the prevention of neural tube defects. Ann Nutr Metab.
95 Hibbard BM. (1993). Folates and fetal development. Br J Obstet Gynaecol.
96 Hibbard ED. (1972). Folate and vitamin B12 metabolism in pregnancy. Midwife Health Visit.
97 Hine RJ. (1996). What practitioners need to know about folic acid. J Am Diet Assoc.
98 Ho Jacqueline J, Chun Wearn KOH, Chang Alvin SM. (2011). Folic acid supplementation for the prevention of anaemia in preterm neonates. Cochrane Database of Systematic Reviews.
99 Holmes LB. (1992). Prevention of neural tube defects. J Pediatr.
100 Hook EB. (2000). Neural-tube defects. N Engl J Med.
101 Howell S, Underwood M, Carter Y. (1998). Folic acid supplements. Br J Gen Pract.
102 Howse JL. (1999). Stopping neural tube defects. AWHONN Lifelines.
103 Hróbjartsson A, Gøtzsche Peter C. (2010). Placebo interventions for all clinical conditions. Cochrane Database of Systematic Reviews.
104 Huang HY, Caballero B, Chang S, et al. (2006). The efficacy and safety of multivitamin and mineral supplement use to prevent cancer and chronic disease in adults: a systematic review for a National Institutes of Health state-of-the-science conference. Ann Intern Med.
105 Hueston WJ. (1993). Folic acid for the prevention of neural tube defects. Am Fam Physician.
106 Hughes R. (2009). In this issue. Public Health Nutr.
107 Hume K. (1980). Fetal defects and multivitamin therapy. Med J Aust.
108 Hume K. (1981). Neural tube defect. Med J Aust.
109 Inman K. (1998). Flour power. Nurs Times.
110 Iqbal MM. (1999). Birth defects: prevention of neural tube defects by periconceptional use of folic acid and screening. J Prev Soc Med.
111 Jacobsen DW. (1996). Serum and erythrocyte folates: a matter of life and premature death. Clin Chem.
112 Jacobson B. (1995). Folic acid and the prevention of neural tube defects. Chapati flour should be fortified as well. BMJ.
113 Jain R, Acharya AS. (2010). Supplemental folic acid in pregnancy and childhood asthma. Natl Med J India.
114 Johnston RB. (1997). Folic acid: new dimensions of an old friendship. Adv Pediatr.
115 Jukes TH. (1983). Folic acid deficiency. Nature.
116 Kadir RA, Economides DL. (2002). Neural tube defects and periconceptional folic acid. CMAJ.
117 Kalter H. (2001). Folic acid and NTD-disputed connection. Teratology.
118 Kaneko S. (1986). Epilepsy, pregnancy and antiepileptic drugs. Hirosaki Medical Journal.
119 Kee M. (1983). Spina bifida trial. Research council goes public. Nature.
120 Kennedy D, Pastuszak A, Koren G. (1997). Taking folic acid during pregnancy. Don't leave it too late. Can Fam Physician.
121 Kennedy DS. (1998). Spina bifida. Med J Aust.
122 Kirsch SH, Herrmann W, Obeid R. (2013). Genetic defects in folate and cobalamin pathways affecting the brain. Clin Chem Lab Med.
123 Klein NW. (1996). Caution advised before rushing to start folic acid supplements. Teratology.
124 Knight M. (2013). Sharper focus on uncomplicated pregnancy. BMJ (Online).
125 Kokalj TS, Rejc B, Gersak K. (2011). Incidence and prevention of neural tube defects in Slovenia. Eur J Obstet Gynecol Reprod Biol.
126 Koren G, Cohn T, Chitayat D, et al. (2002). Use of atypical antipsychotics during pregnancy and the risk of neural tube defects in infants. Am J Psychiatry.
127 Koren G, Goh I. (2007). Increasing folate supplementation for selected groups of Canadian women. J Obstet Gynaecol Can.
128 Krone CA, Ely JTA, Harms LC. (2004). Nutritional supplements: Friend or foe?. N Z Med J.
129 Kumana CR, Yu YL, Richens A. (1985). Antiepileptic treatment during pregnancy. Journal of the Hong Kong Medical Association.
130 Kurzawinska G, Seremak-Mrozikiewicz A, Drews K, et al. (2009). Ginekol Pol.
131 Laurence KM. (1982). Neural tube defects: a two-pronged approach to primary prevention. Pediatrics.
132 Laurence KM, Campbell H. (1981). Trial of folate treatment to prevent recurrence of neural tube defect. Br Med J (Clin Res Ed).
133 Leung DT, Ernest JM. (2007). Pre-conceptional folic acid supplementation in uninsured pregnant Hispanic women. South Med J.
134 Levy T, Blickstein I. (2006). Does the use of folic acid increase the risk of twinning?. Int J Fertil Womens Med.
135 Lewis DP, Van Dyke DC, Stumbo PJ, et al. (1998). Drug and environmental factors associated with adverse pregnancy outcomes. Part III: Folic acid: pharmacology, therapeutic recommendations, and economics. Ann Pharmacother.
136 Lewis DP, Van Dyke DC, Stumbo PJ, et al. (1998). Drug and environmental factors associated with adverse pregnancy outcomes. Part II: Improvement with folic acid. Ann Pharmacother.
137 Lewis DP, Van Dyke DC, Stumbo PJ, et al. (1998). Drug and environmental factors associated with adverse pregnancy outcomes. Part I: Antiepileptic drugs, contraceptives, smoking, and folate. Ann Pharmacother.
138 Leyva M. (2002). Folic acid intake and its effects on the prevention of neural tube defects, the masking of vitamin B12 deficiency and the reduction of homocysteine. J Okla State Med Assoc.
139 Lin KW, Birmingham E. (2010). Folic Acid for the prevention of neural tube defects. Am Fam Physician.
140 Louis-Ferdinand RT. (1994). Myelotoxic, neurotoxic and reproductive adverse effects of nitrous oxide. Adverse Drug React Toxicol Rev.
141 Mackerras D, Cunningham J, Hunt A, et al. (2010). Re: “effect of supplemental folic acid in pregnancy on childhood asthma: a prospective birth cohort study”. Am J Epidemiol.
142 Mahomed K. (2006). Iron supplementation in pregnancy. Cochrane Database of Systematic Reviews.
143 Mahomed K. (2006). Iron and folate supplementation in pregnancy. Cochrane Database of Systematic Reviews.
144 Makatsariya N, Bitsadze V, Panfilova O, et al. (2013). Maternal and paternal hypergomocysteinemia and prophylaxis of recurrent antenatal fetal death. J Perinat Med.
145 Mamtani R, Watkins SJ. (1981). Trial of folate treatment to prevent recurrence of neural tube defects. Br Med J (Clin Res Ed).
146 Markova V, Nørgaard A, Jørgensen Karsten J, et al. (2013). Treatment for women with postpartum iron deficiency anaemia. Cochrane Database of Systematic Reviews.
147 Meher S, Duley L. (2005). Interventions for preventing pre-eclampsia and its consequences: generic protocol. Cochrane Database of Systematic Reviews.
148 Melse-Boonstra A, Kruger S. (2006). Potential health risks of folic acid supplementation of 5 mg per day during pregnancy. South Afr J Clin Nutr.
149 Metz J. (1995). Folate, B12 and neural tube defects. Med J Aust.
150 Metz J. (2013). Haematological implications of folate food fortification. S Afr Med J.
151 Michie CA, Narang I, Rogers J, et al. (2000). Folate supplementation and neural-tube defects. Lancet.
152 Mills JL, Signore CC. (2004). Folic acid and the prevention of neural-tube defects. N Engl J Med.
153 Mills JL, Signore CC. (2004). Folic acid and the prevention of neural-tube defects. N Engl J Med.
154 Milunsky A. (1992). Folic acid and neural tube defect avoidance. Prenat Diagn.
155 Molloy AM. (2004). Folate and homocysteine interrelationships including genetics of the relevant enzymes. Curr Opin Lipidol.
156 Morrison G. (2001). Neural tube defects. Int Pediatr.
157 Mulinare J. (1993). Epidemiologic associations of multivitamin supplementation and occurrence of neural tube defects. Ann N Y Acad Sci.
158 Mulinare J, Erickson JD. (1997). Prevention of neural tube defects. Teratology.
159 Murphy PA. (1993). Beneficial effects of folic acid supplementation in the prevention of neural tube defects (NTDs). J Nurse Midwifery.
160 Murthy EK, Pavlic-Renar I, Metelko Z. (2002). Diabetes and pregnancy. Diabetol Croat.
161 Oakeshott P, Hunt G. (1994). Prevention of neural tube defects. Lancet.
162 Oakley GP. (1999). Prevention of neural-tube defects. N Engl J Med.
163 Pearson K. (1999). Folic acid to prevent recurrence of neural tube defects. J Okla State Med Assoc.
164 Pendleton HJ. (1969). Acute folic acid deficiency of pregnancy associated with oral ulceration and anencephaly. Proc R Soc Med.
165 Pennell PB. (2004). Neurology illnesses and pregnancy. Neurol Clin.
166 Quinlivan EP, Gregory JF. (2004). Folic acid and the prevention of neural-tube defects. N Engl J Med.
167 Rader JI, Schneeman BO. (2006). Prevalence of neural tube defects, folate status, and folate fortification of enriched cereal-grain products in the United States. Pediatrics.
168 Rhoads GG, Mills JL. (1984). The role of the case-control study in evaluating health interventions. Vitamin supplementation and neural tube defects. Am J Epidemiol.
169 Rose NC, Mennuti MT. (1994). Periconceptional folate supplementation and neural tube defects. Clin Obstet Gynecol.
170 Rush D, Rosenberg IH. (1992). Folate supplements and neural tube defects. Nutr Rev.
171 Ryan M. (2004). Folic acid to prevent neural tube defects: A potential pharmacy initiative with public health implications. Hosp Pharm.
172 Salvi VS. (2003). Folic acid and birth defects. J Postgrad Med.
173 Schiller-Fruhwirth I, Mittermayr T, Wild C. (2010). Gesundheitswesen.
174 Schorah C. (2009). Dick Smithells, folic acid, and the prevention of neural tube defects. Birth Defects Res A Clin Mol Teratol.
175 Schwantzer M, Colvin J, Robertson A. (1994). Folic acid supplementation in the periconceptional period [2]. Australian Journal of Hospital Pharmacy.
176 Scioscia AL. (1995). Maternal-fetal medicine. Curr Opin Obstet Gynecol.
177 Scott J, Weir DG, Kirke PN. (1994). Prevention of neural tube defects with folic acid a success but. QJM.
178 Sharland E, Montgomery B, Granell R. (2011). Folic acid in pregnancy - is there a link with childhood asthma or wheeze?. Aust Fam Physician.
179 Sharma JB, Newman MR, Smith RJ. (1994). Folic acid, pernicious anaemia, and prevention of neural tube defects. Lancet.
180 Shaw MT, Hoffbrand AV. (1970). The use and abuse of folic acid. Practitioner.
181 Sheikh A. (1997). Folic acid supplements and NTDs. Br J Gen Pract.
182 Simister K. (1993). Primary prevention of neural tube defects with folic acid. BMJ.
183 Simpson JL, Mills JL, Rhoads GG, et al. (1991). Vitamins, folic acid and neural tube defects: comments on investigations in the United States. Prenat Diagn.
184 Smith RB, Davies N, Davies J. (1994). Prevention of neural tube defects. Lancet.
185 Smithells RW, Sheppard S, Schorah CJ. (1977). Folates and the fetus. Lancet.
186 Speidel BD. (1973). Folic acid deficiency and congenital malformation. Dev Med Child Neurol.
187 Stewart CP, Christian P, West KP, et al. (2011). Low maternal B12 status is associated with offspring insulin resistance but B12 or folate supplementation does not alter that risk. FASEB J.
188 Stirrat G. (2005). Taking folate in pregnancy and risk of maternal breast cancer: authors and publishers must not disclaim ethical responsibility. BMJ.
189 Super M, Summers EM, Meylan B. (1991). Preventing neural tube defects. Lancet.
190 Toriello HV. (2005). Folic acid and neural tube defects. Genet Med.
191 Van Allen MI. (1994). “Folate up” for healthy babies. CMAJ.
192 Wald N. (1993). Folic acid and the prevention of neural tube defects. Ann N Y Acad Sci.
193 Wald NJ. (2004). Folic acid and the prevention of neural-tube defects. N Engl J Med.
194 Wald NJ, Bower C. (1994). Folic acid, pernicious anaemia, and prevention of neural tube defects. Lancet.
195 Wald NJ, Gilbertson MP. (1995). Folic acid in prevention of neural tube defects. Lancet.
196 Wald NJ, Hackshaw AK. (2002). Folic acid supplementation and neural tube defects. Am J Med Genet.
197 Wald NJ, Law MR, Morris JK, et al. (2001). Quantifying the effect of folic acid. Lancet.
198 Wani MA. (2000). Neural tube defect and folic acid. JK Pract.
199 Watermeyer G. (2007). Pregnancy and inflammatory bowel disease. South African Gastroenterology Review.
200 Welch JP. (1994). Folic acid supplementation to prevent neural tube defects. CMAJ.
201 Werler MM, Mitchell AA. (1995). More on folic acid and neural tube defects. Am J Public Health.
202 Wild J, Lucock MD, Schorah CJ. (1995). Periconceptional folate and neural tube defects. Am J Clin Nutr.
203 Wilson RD, Audibert F, Brock JA, et al. (2015). Pre-conception Folic Acid and Multivitamin Supplementation for the Primary and Secondary Prevention of Neural Tube Defects and Other Folic Acid-Sensitive Congenital Anomalies. Journal d'obstétrique et gynécologie du Canada : JOGC.
204 Wilson RD, Johnson JA, Wyatt P, et al. (2007). Pre-conceptional vitamin/folic acid supplementation 2007: the use of folic acid in combination with a multivitamin supplement for the prevention of neural tube defects and other congenital anomalies. J Obstet Gynaecol Can.
205 Yerby MS. (2003). Erratum: Clinical Care of Pregnant Women with Epilepsy: Neural Tube Defects and Folic Acid Supplementation (Epilepsia (2003) 44: Suppl 3 (33-40)). Epilepsia.
206 Yoder DK. (1999). Preventing neural tube defects with folic acid. Tenn Med.
207 (1992). Folate supplements prevent recurrence of neural tube defects. Nutr Rev.
208 (1994). Neural tube defects and folic acid supplements. J Okla State Med Assoc.
209 Molloy AM, Kirke PN, Brody LC, et al. (2008). Effects of folate and vitamin B12 deficiencies during pregnancy on fetal, infant, and child development. Food Nutr Bull.
210 Willett WC. (1992). Folic acid and neural tube defect: can't we come to closure?. Am J Public Health.
211 (1988). Periconceptional use of multivitamins and the occurrence of anencephaly and spina bifida. MMWR Morb Mortal Wkly Rep.
212 (2008). Iron/folate for iron deficiency anaemia in pregnancy. Australian Journal of Pharmacy.
213 Berry RJ, Kihlberg R. (2005). Folic acid supplementation is not associated with an increase in dizygotic twinning. Early Hum Dev.
214 Bower C. (1994). Epilepsy in pregnancy: neural tube defects and folate. Med J Aust.
215 Butterworth CE. (1973). Interactions of nutrients with oral contraceptives and other drugs. J Am Diet Assoc.
216 Buttriss J. (2004). Strategies to increase folate/folic acid intake in women: An overview. Nutr Bull.
217 Chanarin I. (1985). Folate and cobalamin. Clin Haematol.
218 Cunningham GC. (1995). California's public health policy on preventing neural tube defects by folate supplementation. West J Med.
219 Czeizel AE. (1998). Terathanasia, folic acid, and birth defects. Lancet.
220 Czeizel AE. (2004). Folic acid and the prevention of neural-tube defects. N Engl J Med.
221 de Benoist B. (2008). Conclusions of a WHO Technical Consultation on folate and vitamin B12 deficiencies. Food Nutr Bull.
222 Doyle W. (1995). Folic acid in prevention of neural tube defects. Lancet.
223 Einarson A, Parshuram C, Koren G. (2000). Periconceptional use of folic acid to reduce the rates of neural tube defects: is it working?. Reprod Toxicol.
224 Evans JA. (2008). Pre-conceptional vitamin/folic acid supplementation 2007. J Obstet Gynaecol Can.
225 Friel JK, Frecker M, Fraser FC. (1995). Nutritional patterns of mothers of children with neural tube defects in Newfoundland. Am J Med Genet.
226 Halsted CH. (1990). Periconceptional use of multivitamins and the prevalence of neural-tube defects (I). N Engl J Med.
227 Hawkins DF. (1986). Teratogenesis and other adverse effects on the fetus of antimicrobial drugs used in pregnancy. Clin Exp Obstet Gynecol.
228 Holzgreve W, Pietrzik K, Koletzko B, et al. (2012). Adding folate to the contraceptive pill: a new concept for the prevention of neural tube defects. J Matern Fetal Neonatal Med.
229 Koren G. (2011). Folic acid and colorectal cancer: unwarranted fears. Can Fam Physician.
230 Mason JB. (1998). Folate and colon cancer: a fascinating puzzle we have yet to complete. Clin Nutr.
231 Mathews F, Murphy M, Wald NJ, et al. (1999). Twinning and folic acid use. Lancet.
232 Milunsky A, Jick H, Jick SS, et al. (1990). Periconceptional use of multivitamins and the prevalence of neural-tube defects (II). N Engl J Med.
233 Mulinare J, Cordero JF, Erickson JD, et al. (1989). Periconceptional use of multivitamins and the occurrence of neural tube defects. Obstet Gynecol Surv.
234 Mulinare J, Cordero JF, Erickson JD, et al. (1990). Periconceptional use of multivitamins and the prevalence of neural-tube defects (III). N Engl J Med.
235 Obeid R, Koletzko B, Pietrzik K. (2014). Critical evaluation of lowering the recommended dietary intake of folate. Clin Nutr.
236 O'Connor G, Doherty CP. (2013). Folic acid: When to supplement and by how much. European Neurological Journal.
237 Olsen J. (2015). Some options in studying side effects of drugs taken during pregnancy. Eur J Epidemiol.
238 Ownby DR. (2009). Has mandatory folic acid supplementation of foods increased the risk of asthma and allergic disease?. J Allergy Clin Immunol.
239 Reynolds EH. (1995). Folic acid and the prevention of neural tube defects. Folate has potential to cause harm. BMJ.
240 Scott JM. (1998). How does folic acid prevent neural tube defects?. Nat Med.
241 Strohle A, Bohn T. (2015). Folate and Prevention of Neural Tube Defects: New Insights from a Bayesian Model. Int J Vitam Nutr Res.
242 Sutcliffe M, Schorah CJ, Perry A, et al. (1993). Prevention of neural tube defects. Lancet.
243 Tuerxunjiang M, Wang YP. (2007). Folic acid, zinc, iodine, selenium and maternal health. Journal of Clinical Rehabilitative Tissue Engineering Research.
244 Wald NJ. (2001). Folic acid and neural tube defects. Bibl Nutr Dieta.
245 Wen SW, Walker M. (2005). An exploration of health effects of folic acid in pregnancy beyond reducing neural tube defects. J Obstet Gynaecol Can.
246 Wilson RD, Davies G, Desilets V, et al. (2003). The use of folic acid for the prevention of neural tube defects and other congenital anomalies. J Obstet Gynaecol Can.
247 Yu J. (2015). Gene-environment interactions should be considered in future studies to understand the association between prenatal folate supplementation and asthma development. Allergy, Asthma and Immunology Research.
248 (2010). Japanese Teratology Society 50th Annual Meeting. Congenital Anomalies.
249 Phull E, Hirst SL. (1995). Folic acid in pregnancy. Br J Gen Pract.
250 Daly L, Doyle S. (2002). Peri-conceptual folic acid. Ir Med J.
251 Fraser FC. (1995). Folic acid and neural tube defects. CMAJ.
252 Laurence KM. (1982). Towards the prevention of neural tube defects: discussion paper. J R Soc Med.
253 Smithells RW. (1982). Neural tube defects: prevention by vitamin supplements. Pediatrics.
254 Smithells RW. (1989). Multivitamins for the prevention of neural tube defects. How convincing is the evidence? Drugs.
255 Weggemans RM, Schaafsma G, Kromhout D. (2009). Toward an optimal use of folic acid: an advisory report of the Health Council of the Netherlands. Eur J Clin Nutr.
256 Metson D, Kassianos GS, Kremer MG, et al. (1995). Supplementation with folic acid. BMJ.
257 Suarez L, Felkner M, Brender JD, et al. (2012). Neural tube defects on the Texas-Mexico border: what we've learned in the 20 years since the Brownsville cluster. Birth Defects Res A Clin Mol Teratol.
258 Dean H, Watson K, Sellers EA. (2005). Neural tube defects. CMAJ.
259 Livingstone A. (1993). Primary prevention of neural tube defects with folic acid. BMJ.
260 Schorah CJ, Smithells RW. (1993). Primary prevention of neural tube defects with folic acid. BMJ.
261 Wang FL, Quan H, Schopflocher D. (2005). Neural tube defects. CMAJ.
262 Girling JC, Shennan AH. (1993). Epilepsy and pregnancy. Emphasise the importance of extra folate. BMJ.
263 Harris AA, Barger MK. (2010). Specialized care for women pregnant after bariatric surgery. J Midwifery Womens Health.
264 Hauer P. (2001). Neural tube defects in relation to use of folic Acid antagonists during pregnancy. Pediatr Phys Ther.
265 Kaplan JS, Iqbal S, England BG, et al. (1999). Is pregnancy in diabetic women associated with folate deficiency?. Diabetes Care.
266 Kim H, Lee YA, Hwang JY, et al. (2011). Relationship between body-mass index and serum folate concentrations in pregnant women: Mothers and Children's Environmental Health (MOCEH). FASEB J.
267 Jenkins KJ, Correa A, Feinstein JA, et al. (2007). Noninherited risk factors and congenital cardiovascular defects: current knowledge: a scientific statement from the American Heart Association Council on Cardiovascular Disease in the Young: endorsed by the American Academy of Pediatrics. Circulation.
268 Shaw GM, Todoroff K, Lammer EJ. (1997). NTD phenotypes in infants and fetuses whose mothers used multivitamins containing folic acid in early pregnancy compared to those who did not. Am J Med Genet.
269 Silver RM. (2014). Folic acid: Building bigger babies. BJOG.
270 Czeizel AE. (2009). Periconceptional folic acid and multivitamin supplementation for the prevention of neural tube defects and other congenital abnormalities. Birth Defects Res A Clin Mol Teratol.
271 (1991). Prevention of neural tube defects: results of the Medical Research Council Vitamin Study. MRC Vitamin Study Research Group. Lancet.
272 Akinshina S, Makatsaria A, Bitsadze V, et al. (2013). Management principles in pregnancy, delivery and postnatal period in patients with thromboembolism in anamnesis. Hamostaseologie.
273 Brent RL, Oakley GP, Mattison DR. (2000). The unnecessary epidemic of folic acid-preventable spina bifida and anencephaly. Pediatrics.
274 Collins JS, Atkinson KK, Dean JH, et al. (2011). Long term maintenance of neural tube defects prevention in a high prevalence state. J Pediatr.
275 De-Regil LM, Pena-Rosas JP, Fernandez-Gaxiola AC, et al. (2015). Effects and safety of periconceptional oral folate supplementation for preventing birth defects. Cochrane Database Syst Rev.
276 Harden CL, Meador KJ, Pennell PB, et al. (2009). Practice parameter update: management issues for women with epilepsy - focus on pregnancy (an evidence-based review): teratogenesis and perinatal outcomes. Report of the Quality Standards Subcommittee and Therapeutics and Technology Assessment Subcommittee of the American Academy of Neurology and American Epilepsy Society. Neurology.
277 Heseker HB, Mason JB, Selhub J, et al. (2009). Not all cases of neural-tube defect can be prevented by increasing the intake of folic acid. Br J Nutr.
278 Holmes-Siedle M, Dennis J, Lindenbaum RH, et al. (1992). Long term effects of periconceptional multivitamin supplements for prevention of neural tube defects: a seven to 10 year follow up. Arch Dis Child.
279 Jeha LE, Morris HH. (2005). Optimizing outcomes in pregnant women with epilepsy. Cleve Clin J Med.
280 Kent A. (2013). Research snippets. BJOG.
281 Khoury MJ, Shaw GM, Moore CA, et al. (1996). Does periconceptional multivitamin use reduce the risk of neural tube defects associated with other birth defects? data from two population-based case-control studies. Am J Med Genet.
282 Kirke PN, Daly LE, Elwood JH. (1992). A randomised trial of low dose folic acid to prevent neural tube defects. The Irish Vitamin Study Group. Arch Dis Child.
283 Laurence KM, James N, Miller MH, et al. (1981). Double-blind randomised controlled trial of folate treatment before conception to prevent recurrence of neural-tube defects. Br Med J (Clin Res Ed).
284 Lumley J, Watson L, Watson M, et al. (2001). Periconceptional supplementation with folate and/or multivitamins for preventing neural tube defects. Cochrane Database Syst Rev.
285 Marik PE, Flemmer M. (2012). Do dietary supplements have beneficial health effects in industrialized nations: what is the evidence?. Journal of Parenteral and Enteral Nutrition.
286 MRC Vitamin Study Research Group. (1991). Prevention of neural tube defects: results of the Medical Research Council Vitamin Study. Lancet.
287 Muggli EE, Halliday JL. (2007). Folic acid and risk of twinning: a systematic review of the recent literature, July 1994 to July 2006. Med J Aust.
288 Noventa M, Vitagliano A, Quaranta M, et al. (2015). Preventive and Therapeutic Role of Dietary Inositol Supplementation in Periconceptional Period and During Pregnancy: A Summary of Evidences and Future Applications. Reprod Sci.
289 Schorah CJ, Habibzadeh N, Wild J, et al. (1993). Possible abnormalities of folate and vitamin B12 metabolism associated with neural tube defects. Ann N Y Acad Sci.
290 Zetstra-van der Woude PA, De Walle HE, Hoek A, et al. (2014). Maternal high-dose folic acid during pregnancy and asthma medication in the offspring. Pharmacoepidemiol Drug Saf.
291 Smithells RW, Sheppard S, Schorah CJ, et al. (1980). Possible prevention of neural-tube defects by periconceptional vitamin supplementation. Lancet.
292 Akinshina S, Makatsariya A, Bitsadze V, et al. (2009). Pathogenetic prophylaxis of obstetric complications and recurrent thrombosis in pregnant women with history of stroke. International Journal of Gynecology and Obstetrics.
293 Wald NJ, Hackshaw AD, Stone R, et al. (1996). Blood folic acid and vitamin B12 in relation to neural tube defects. Br J Obstet Gynaecol.
294 Jentink J, Bakker MK, Nijenhuis CM, et al. (2010). Does folic acid use decrease the risk for spina bifida after in utero exposure to valproic acid?. Pharmacoepidemiol Drug Saf.
295 Parker SE, Yazdy MM, Tinker SC, et al. (2013). The impact of folic acid intake on the association among diabetes mellitus, obesity, and spina bifida. Am J Obstet Gynecol.
296 Harden CL, Pennell PB, Koppel BS, et al. (2009). Practice parameter update: management issues for women with epilepsy--focus on pregnancy (an evidence-based review): vitamin K, folic acid, blood levels, and breastfeeding: report of the Quality Standards Subcommittee and Therapeutics and Technology Assessment Subcommittee of the American Academy of Neurology and American Epilepsy Society. Neurology.
297 Akinshina SV, Makatsaria AD. (2011). Prevention of recurrent thrombothic and thromboembolic complications during pregnancy. J Thromb Haemost.
298 Korenbrot CC, Steinberg A, Bender C, et al. (2002). Preconception care: a systematic review. Maternal and Child Health Journal.
299 (1995). Prevention program for reducing risk for neural tube defects--South Carolina, 1992-1994. MMWR Morb Mortal Wkly Rep.
300 Ballas SK, Baxter JK, Riddick G. (2006). Folate supplementation and twinning in patients with sickle cell disease. Am J Hematol.
301 Ben-Ami I, Vaknin Z, Reish O, et al. (2005). Is there an increased rate of anencephaly in twins?. Prenat Diagn.
302 Binkley KE, Leaver C, Ray JG. (2011). Antenatal risk factors for peanut allergy in children. Allergy Asthma Clin Immunol.
303 Gucciardi E, Pietrusiak MA, Reynolds DL, et al. (2002). Incidence of neural tube defects in Ontario, 1986-1999. CMAJ.
304 Hutson JR, Lubetsky A, Eichhorst J, et al. (2013). Adverse placental effect of formic acid on hCG secretion is mitigated by folic acid. Alcohol Alcohol.
305 Kallen BA, Olausson PO. (2002). Use of folic acid and delivery outcome: a prospective registry study. Reprod Toxicol.
306 Laurence KM, Carter CO, David PA. (1968). Major central nervous system malformations in South Wales. II. Pregnancy factors, seasonal variation, and social class effects. Br J Prev Soc Med.
307 Rosano A, Smithells D, Cacciani L, et al. (1999). Time trends in neural tube defects prevalence in relation to preventive strategies: an international study. J Epidemiol Community Health.
308 Van Allen MI, Boyle E, Thiessen P, et al. (2006). The impact of prenatal diagnosis on neural tube defect (NTD) pregnancy versus birth incidence in British Columbia. J Appl Genet.
309 Wang L, Wang F, Guan J, et al. (2010). Relation between hypomethylation of long interspersed nucleotide elements and risk of neural tube defects. Am J Clin Nutr.
310 Lassi ZS, Bhutta ZA. (2012). Clinical utility of folate-containing oral contraceptives. Int J Womens Health.
311 Stevenson RE, Allen WP, Pai GS, et al. (2000). Decline in prevalence of neural tube defects in a high-risk region of the United States. Pediatrics.
312 Wild J, Sutcliffe M, Schorah CJ, et al. (1997). Prevention of neural-tube defects. Lancet.
313 Jentink J, Bakker MK, De Jong-van Den Berg LTW. (2009). Effect of correct folic acid use on spina bifida in pregnancies exposed to valproic acid or carbamazepine in the Netherlands. Pharmacoepidemiol Drug Saf.
314 (1982). M.R.C. trial of multivitamin prophylaxis in pregnancies at risk of neural tube defects. Lancet.
315 (1984). Medical Research Council Vitamin Study. Lancet.
316 (1995). Does folic acid decrease the risk of orofacial clefts?. Geneesmiddelenbulletin.
317 (2000). Neural tube defect surveillance and folic acid intervention--Texas-Mexico border, 1993-1998. MMWR Morb Mortal Wkly Rep.
318 Centers for Disease Control and Prevention. (2000). Neural tube defect surveillance and folic acid intervention--Texas-Mexico border, 1993-1998. JAMA.
319 Ajayi G. (1993). Dehydroepiandrosterone sulphate (DHAS) in non pregnant women, during normal pregnancy and puerperium and the effect of combined iron (Chemiron(registered trademark)) and single iron therapy. J Foetal Med.
320 Al-Ani ZR, Al-Hiali SJ, Al-Mehimdi SM. (2010). Neural tube defects among neonates delivered in Al-Ramadi Maternity and Children's Hospital, western Iraq. Saudi Med J.
321 Bailey S, Ayling J. (2014). Comparison of 5-methyltetrahydrofolic acid with folic acid for rapid folate repletion to reduce the risk for neural tube and other birth defects. Basic and Clinical Pharmacology and Toxicology.
322 Bitsko RH, Reefhuis J, Romitti PA, et al. (2007). Periconceptional consumption of vitamins containing folic acid and risk for multiple congenital anomalies. Am J Med Genet A.
323 Bower C, Ryan A, Rudy E. (2001). Ascertainment of pregnancies terminated because of birth defects: effect on completeness of adding a new source of data. Teratology.
324 Boyles AL, Ballard JL, Gorman EB, et al. (2011). Association between inhibited binding of folic acid to folate receptor alpha in maternal serum and folate-related birth defects in Norway. Hum Reprod.
325 Castrén O, Levanto A, Rauramo L, et al. (1968). Preventive iron and folic acid therapy in pregnancy. Ann Chir Gynaecol Fenn.
326 Chanarin I, Rothman D, Ward A, et al. (1968). Folate status and requirement in pregnancy. Br Med J.
327 Csaky-Szunyogh M, Vereczkey A, Kosa Z, et al. (2013). Risk and protective factors in the origin of conotruncal defects of heart--a population-based case-control study. Am J Med Genet A.
328 Czeizel A, Rode K. (1984). Trial to prevent first occurrence of neural tube defects by periconceptional multivitamin supplementation. Lancet.
329 Dalziel K, Segal L, Katz R. (2010). Cost-effectiveness of mandatory folate fortification v. other options for the prevention of neural tube defects: results from Australia and New Zealand. Public Health Nutr.
330 de Smit DJ, de Jong-van den Berg LT. (2006). Ned Tijdschr Geneeskd.
331 De-Regil LM, Fernandez-Gaxiola AC, Dowswell T, et al. (2010). Effects and safety of periconceptional folate supplementation for preventing birth defects. Cochrane Database Syst Rev.
332 Diez-Ewald M, Molina RA. (1972). Iron and folic acid deficiency during pregnancy in western Venezuela. Am J Trop Med Hyg.
333 Forns J, Torrent M, Garcia-Esteban R, et al. (2012). Longitudinal association between early life socio-environmental factors and attention function at the age 11 years. Environ Res.
334 Fryer AA, Nafee TM, Ismail KM, et al. (2009). LINE-1 DNA methylation is inversely correlated with cord plasma homocysteine in man: a preliminary study. Epigenetics.
335 Gardiki-Kouidou P, Seller MJ. (1988). Amniotic fluid folate, vitamin B12 and transcobalamins in neural tube defects. Clin Genet.
336 Giebe K, Counts C. (2000). Comparison of Prenate Advance with other prescription prenatal vitamins: a folic acid dissolution study. Adv Ther.
337 Gildestad T, Bjorge T, Vollset SE, et al. (2015). Folic acid supplements and risk for oral clefts in the newborn: A population-based study. Br J Nutr.
338 Giusti B, Gori AM, Marcucci R, et al. (2006). Homocysteine as an emerging risk factor for cardiovascular disease in the elderly. Aging Health.
339 Gjergja Juraski R, Miskov S, Cvitanovic Sojat L, et al. (2010). Prospective surveillance of Croatian pregnant women with epilepsy and their offspring - Pregnancy outcome and effects of antiepileptic drugs exposure. Eur J Neurol.
340 Gringras M. (1982). A comparison of two combined iron-folic acid preparations in the prevention of anaemia in pregnancy. J Int Med Res.
341 Grosse SD, Collins JS. (2007). Folic acid supplementation and neural tube defect recurrence prevention. Birth Defects Res A Clin Mol Teratol.
342 Grossmith A, Nair M, Thompson R, et al. (2009). Observational study of the management of vitamin B12 deficiency during pregnancy. International Journal of Gynecology and Obstetrics.
343 Guven F, Say A, Uygur Kulcu N, et al. (2012). Vitamin B12 and folate deficiency in healthy neonates and their mothers. Arch Dis Child.
344 Habibzadeh N, Wild J, Lucock MD, et al. (1995). One-carbon metabolism in pregnancies complicated by neural tube defects. Lancet.
345 Halicioglu O, Sutcuoglu S, Koc F, et al. (2012). Vitamin B12 and folate statuses are associated with diet in pregnant women, but not with anthropometric measurements in term newborns. J Matern Fetal Neonatal Med.
346 Hancock KW, Walker PA, Harper TA. (1968). Mobilisation of iron in pregnancy. Lancet.
347 Hansen HA. (1967). The incidence of pernicious anaemia and the etiology of folic acid deficiency in pregnancy. Acta Obstet Gynecol Scand.
348 Hernandez-Diaz S, Werler MM, Walker AM, et al. (2000). Folic acid antagonists during pregnancy and the risk of birth defects. N Engl J Med.
349 Hibbard BM, Hibbard ED. (1969). The prophylaxis of folate deficiency in pregnancy. Acta Obstet Gynecol Scand.
350 Hirahara F, Hamanoue H, Ebisawa Y, et al. (2010). Recent trends in prevalence of neural tube defects in Japan. Birth Defects Research Part A - Clinical and Molecular Teratology.
351 Hobbs CA, Cleves MA, Melnyk S, et al. (2005). Congenital heart defects and abnormal maternal biomarkers of methionine and homocysteine metabolism. Am J Clin Nutr.
352 Hoyo C, Murtha AP, Schildkraut JM, et al. (2011). Methylation variation at IGF2 differentially methylated regions and maternal folic acid use before and during pregnancy. Epigenetics.
353 Illsley NP, Felkner M, Fik E, et al. (2010). Autoantibody inhibition of placental microvillous folate receptor alpha (FR(alpha)) binding measured using a fluorescent folate analog. Reprod Sci.
354 Iyengar L, Apte SV. (1970). Prophylaxis of anemia in pregnancy. Am J Clin Nutr.
355 Kerr MA, McNulty H, Livingstone MBE. (2011). Response to vitamin B12 intervention in lean versus obese women. Obes Rev.
356 Khoshnood B, Loane M, De Walle H, et al. (2015). Long term trends in prevalence of neural tube defects in Europe: Population based study. BMJ (Online).
357 Kocak G, Onal C, Kocak A, et al. (2008). Prevalence and outcome of congenital heart disease in patients with neural tube defect. J Child Neurol.
358 Lassi Zohra S, Salam Rehana A, Haider Batool A, et al. (2013). Folic acid supplementation during pregnancy for maternal health and pregnancy outcomes. Cochrane Database of Systematic Reviews.
359 Laurence KM, James N, Miller M. (1982). A double randomised controlled trial for preconceptional folic acid supplementation for the prevention of recurrence of neural tube defects in high risk pregnancies. J-Med-Genet.
360 Lee JI, Lee JA, Lim HS. (2005). Effect of time of initiation and dose of prenatal iron and folic acid supplementation on iron and folate nutriture of Korean women during pregnancy. Am J Clin Nutr.
361 Lu QB, Wang ZP, Gao LJ, et al. (2015). Nausea and vomiting in early pregnancy and the risk of neural tube defects: a case-control study. Sci Rep.
362 Mahale AR, Shah SH. (1993). New schedule of intramuscular iron administration for pregnant women. Asia-Oceania journal of obstetrics and gynaecology / AOFOG.
363 Makatsariya AD, Bitsadze VO, Baimuradova SM, et al. (2010). Low molecular weight heparin and natural progesteron in prophylaxis of reccurent pregnancy complications in women with thrombophilia. Journal of Maternal-Fetal and Neonatal Medicine.
364 Makatsariya AD, Bitsadze VO, Baimuradova SM, et al. (2010). Low molecular weight heparin in prophylaxis of reccurent pregnancy complications in women with thrombophilia. Pathophysiol Haemost Thromb.
365 Milne E, Royle JA, Miller M, et al. (2010). Maternal folate and other vitamin supplementation during pregnancy and risk of acute lymphoblastic leukemia in the offspring. Int J Cancer.
366 Myhre R, Myking S, Pay A, et al. (2011). Dietary and supplementary folate intake before and during pregnancy and the risk for spontaneous preterm delivery. Am J Obstet Gynecol.
367 Nooij LS, van Eyck J, Klip H, et al. (2011). The reliability of methionine challenge test is not affected by a deficiency in pyridoxal phosphate, folic acid, or cobalamin. Hypertens Pregnancy.
368 Oladejo M, Bewley S. (2012). Adherence in pregnancy: A systematic review of the literature. Fetal Matern Med Rev.
369 Panfilova O, Natalia M. (2013). Preconceptive treatment and principles of prophylaxis of recurrent placental abruptions in thrombophilic patients. J Perinat Med.
370 Pei L, Li Z, Ye R, et al. (2015). Interaction between maternal spontaneous abortion and periconceptional folic acid use on NTDs risks. Birth Defects Research Part A - Clinical and Molecular Teratology.
371 Pietrzik K, Prinz R, Reusch K, et al. (1992). Folate status and pregnancy outcome. Ann N Y Acad Sci.
372 Robitaille J, Carmichael SL, Shaw GM, et al. (2009). Maternal nutrient intake and risks for transverse and longitudinal limb deficiencies: data from the National Birth Defects Prevention Study, 1997-2003. Birth Defects Res A Clin Mol Teratol.
373 Rosenblatt DS. (1999). Folate and homocysteine metabolism and gene polymorphisms in the etiology of Down syndrome. Am J Clin Nutr.
374 Saravanan P, Maheswaran H, Stranges S, et al. (2010). Population levels of folic acid and vitamin B12 and their implications: Do we need to consider B12 fortification to prevent gestational diabetes and future cardiovascular risk?. Diabet Med.
375 Scott J, Kirke P, Molloy A, et al. (1994). The role of folate in the prevention of neural-tube defects. Proc Nutr Soc.
376 Scott JM, Sommerville JW. (1965). PRACTICAL EVALUATION OF THE FIGLU TEST IN PREGNANCY WITH SPECIAL REFERENCE TO THE WHITE CELL CHANGES. J Clin Pathol.
377 Selhub J, Morris MS, Jacques PF. (2007). In vitamin B12 deficiency, higher serum folate is associated with increased total homocysteine and methylmalonic acid concentrations. Proc Natl Acad Sci U S A.
378 Sengpiel V, Bacelis J, Myhre R, et al. (2014). Folic acid supplementation, dietary folate intake during pregnancy and risk for spontaneous preterm delivery: A prospective observational cohort study. BMC Pregnancy Childbirth.
379 Shaw GM, Lammer EJ, Zhu H, et al. (2002). Maternal periconceptional vitamin use, genetic variation of infant reduced folate carrier (A80G), and risk of spina bifida. Am J Med Genet.
380 Shaw GM, Lu W, Zhu H, et al. (2009). 118 SNPs of folate-related genes and risks of spina bifida and conotruncal heart defects. BMC Med Genet.
381 Shaw GM, Rozen R, Finnell RH, et al. (1998). Maternal vitamin use, genetic variation of infant methylenetetrahydrofolate reductase, and risk for spina bifida. Am J Epidemiol.
382 Sheppard S, Nevin NC, Seller MJ, et al. (1989). Neural tube defect recurrence after ‘partial’ vitamin supplementation. J Med Genet.
383 Streiff RR, Little AB. (1967). Folic acid deficiency in pregnancy. N Engl J Med.
384 Swain R, Kaplan B. (1995). Vitamins as therapy in the 1990s. J Am Board Fam Pract.
385 Tamura T, Goldenberg RL, Freeberg LE, et al. (1992). Maternal serum folate and zinc concentrations and their relationships to pregnancy outcome. Am J Clin Nutr.
386 Tarrant RC, Younger KM, Sheridan-Pereira M, et al. (2011). Maternal health behaviours during pregnancy in an Irish obstetric population and their associations with socio-demographic and infant characteristics. Eur J Clin Nutr.
387 Trigg KH, Rendall EJ, Johnson A, et al. (1976). Folate supplements during pregnancy. J R Coll Gen Pract.
388 Tsang B, Sandalinas F, De-Regil Luz M. (2015). Folate supplementation in women of reproductive age. Cochrane Database of Systematic Reviews.
389 Ubeda N, Reyes L, Gonzalez-Medina A, et al. (2011). Physiologic changes in homocysteine metabolism in pregnancy: a longitudinal study in Spain. Nutrition.
390 Van Allen MI, Kalousek DK, Chernoff GF, et al. (1993). Evidence for multi-site closure of the neural tube in humans. Am J Med Genet.
391 Watanabe H, Suganuma N, Hayashi A, et al. (2010). No relation between folate and homocysteine levels and depression in early pregnant women. Biosci Trends.
392 Werler MM, Cragan JD, Wasserman CR, et al. (1997). Multivitamin supplementation and multiple births. Am J Med Genet.
393 Wickramasinghe SN. (1981). The deoxyuridine suppression test: a review of its clinical and research applications. Clin Lab Haematol.
394 Willoughby ML, Jewell FJ. (1966). Investigation of folic acid requirements in pregnancy. Br Med J.
395 Yang Q, Atkinson M, Erickson JD. (2003). Method of weighted proportion of reproductive-aged women taking folic acid supplements to predict a neural tube defect rate decline. Birth Defects Res A Clin Mol Teratol.
396 Jentink J, Vrie-Hoekstra NW, Jong-Van Den Berg LT, et al. (2008). Economic evaluation of folic acid food fortification in the Netherlands. Eur J Public Health.
397 Julvez J, Fortuny J, Mendez M, et al. (2009). Maternal use of folic acid supplements during pregnancy and four-year-old neurodevelopment in a population-based birth cohort. Paediatr Perinat Epidemiol.
398 Chitayat D, Matsui D, Amitai Y, et al. (2015). Folic acid supplementation for pregnant women and those planning pregnancy: 2015 update. J Clin Pharmacol.
399 Meltzer HM, Brantsaeter AL, Nilsen RM, et al. (2011). Effect of dietary factors in pregnancy on risk of pregnancy complications: results from the Norwegian Mother and Child Cohort Study. Am J Clin Nutr.
400 de Walle HE, de Jong-van den Berg LT, Cornel MC. (1999). Periconceptional folic acid intake in the northern Netherlands. Lancet.
401 Bukowski R, Malone FD, Porter FT, et al. (2009). Preconceptional folate supplementation and the risk of spontaneous preterm birth: a cohort study. PLoS Med.
402 (2010). Teratology Society 50th Annual Meeting - 23rd International Conference of the Organization of Teratology Information Specialists, OTIS and the 34th Annual Meeting of the Neurobehavioral Teratology Society, NBTS. Birth Defects Research Part A - Clinical and Molecular Teratology.
403 Hamilton E, Graham P, Edwards J. (2009). Folic acid supplementation in women with epilepsy. Epilepsia.
404 Nichols JAA, Curtis EPP, Rayman MP. (2008). Survey of total folate intake at conception and assessment of impact of fortification. Journal of Nutritional and Environmental Medicine.
405 Norman M, Penman A. (2001). Neural tube defects and folic acid knowledge and use in Mississippi women. J Miss State Med Assoc.
406 Hamner HC, Mulinare J, Cogswell ME, et al. (2009). Predicted contribution of folic acid fortification of corn masa flour to the usual folic acid intake for the US population: National Health and Nutrition Examination Survey 2001-2004. Am J Clin Nutr.
407 Kim H, Cain R, Viner-Brown S, et al. (2011). Multivitamin use prior to pregnancy in Rhode Island. Med Health R I.
408 Walsh T, O'Broin S, Cooley S, et al. (2007). Maternal folate status and neural tube defects in Ireland: the need for a national food fortification program. Ir Med J.
409 Bouthoorn SH, Gaillard R, Steegers EA, et al. (2012). Ethnic differences in blood pressure and hypertensive complications during pregnancy: the Generation R study. Hypertension.
410 Sotres-Alvarez D, Siega-Riz AM, Herring AH, et al. (2013). Maternal dietary patterns are associated with risk of neural tube and congenital heart defects. Am J Epidemiol.
411 Czeizel AE. (2012). Preterm birth preventive effect of folic acid. Clin Chem Lab Med.
412 Couto FD, Moreira LM, Dos Santos DB, et al. (2007). Folate, vitamin B12 and total homocysteine levels in neonates from Brazil. Eur J Clin Nutr.
413 Khodr ZG, Lupo PJ, Agopian AJ, et al. (2014). Preconceptional folic acid-containing supplement use in the national birth defects prevention study. Birth Defects Res A Clin Mol Teratol.
414 Kulier R, de Onis M, Gulmezoglu AM, et al. (1998). Nutritional interventions for the prevention of maternal morbidity. Int J Gynaecol Obstet.
415 Liu JM, Mei Z, Ye R, et al. (2013). Micronutrient supplementation and pregnancy outcomes: double-blind randomized controlled trial in China. JAMA internal medicine.
416 Talalaeva IN, Makatsaria AD, Kiss LN. (2009). Folatdeficiency State and hyperhomocysteinemia as cause of antenatal fetal death. J Thromb Haemost.
417 Banhidy F, Acs N, Puho EH, et al. (2011). Iron deficiency anemia: pregnancy outcomes with or without iron supplementation. Nutrition.
418 Bailey HD, Miller M, Langridge A, et al. (2012). Maternal dietary intake of folate and vitamins B6 and B12 during pregnancy and the risk of childhood acute lymphoblastic leukemia. Nutr Cancer.
419 Bortolus R, Blom F, Filippini F, et al. (2014). Prevention of congenital malformations and other adverse pregnancy outcomes with 4.0 mg of folic acid: Community-based randomized clinical trial in Italy and the Netherlands. BMC Pregnancy Childbirth.
420 Csaky-Szunyogh M, Vereczkey A, Kosa Z, et al. (2014). Risk factors in the origin of congenital left-ventricular outflow-tract obstruction defects of the heart: a population-based case-control study. Pediatr Cardiol.
421 Fleming AF, Martin JD, Hahnel R, et al. (1974). Effects of iron and folic acid antenatal supplements on maternal haematology and fetal wellbeing. Med J Aust.
422 Haider BA, Yakoob MY, Bhutta ZA. (2011). Effect of multiple micronutrient supplementation during pregnancy on maternal and birth outcomes. BMC Public Health.
423 Hayes C, Werler MM, Willett WC, et al. (1996). Case-control study of periconceptional folic acid supplementation and oral clefts. Am J Epidemiol.
424 Hininger I, Favier M, Arnaud J, et al. (2004). Effects of a combined micronutrient supplementation on maternal biological status and newborn anthropometrics measurements: a randomized double-blind, placebo-controlled trial in apparently healthy pregnant women. Eur J Clin Nutr.
425 Holmes VA, Wallace JM, Alexander HD, et al. (2005). Homocysteine is lower in the third trimester of pregnancy in women with enhanced folate status from continued folic acid supplementation. Clin Chem.
426 Izak G, Levy S, Rachmilewitz M, et al. (1973). The effect of iron and folic acid therapy on combined iron and folate deficiency anaemia: the results of a clinical trial. Scand J Haematol.
427 Johnson CY, Little J. (2008). Folate intake, markers of folate status and oral clefts: is the evidence converging?. Int J Epidemiol.
428 Merviel P, Cabry R, Temstet R, et al. (2011). Comparison between two preventive treatments in women with recurrent miscarriages carrying a C677T methylenetetrahydrofolate reductase mutation: A prospective study. Hum Reprod.
429 Morse NL. (2012). Benefits of docosahexaenoic acid, folic acid, vitamin D and iodine on foetal and infant brain development and function following maternal supplementation during pregnancy and lactation. Nutrients.
430 Mukherjee MD, Sandstead HH, Ratnaparkhi MV, et al. (1984). Maternal zinc, iron, folic acid, and protein nutriture and outcome of human pregnancy. Am J Clin Nutr.
431 Schmidt RJ, Tancredi DJ, Ozonoff S, et al. (2012). Maternal periconceptional folic acid intake and risk of autism spectrum disorders and developmental delay in the CHARGE (CHildhood Autism Risks from Genetics and Environment) case-control study. Am J Clin Nutr.
432 Sengpiel V, Bacelis J, Myhre R, et al. (2014). Folic acid supplementation, dietary folate intake during pregnancy and risk for spontaneous preterm delivery: a prospective observational cohort study. BMC Pregnancy Childbirth.
433 Sikora J, Magnucki J, Zietek J, et al. (2007). Homocysteine, folic acid and vitamin B12 concentration in patients with recurrent miscarriages. Neuro Endocrinol Lett.
434 Stoltenberg C. (2013). Effects of periconceptional folate on language delay and autism spectrum disorders: The Norwegian mother and child cohort study. Neuropsychopharmacology.
435 Wilcox AJ, Lie RT, Solvoll K, et al. (2007). Folic acid supplements and risk of facial clefts: National population based case-control study. Obstet Gynecol Surv.
436 Yakoob MY, Bhutta ZA. (2011). Effect of routine iron supplementation with or without folic acid on anemia during pregnancy. BMC Public Health.
437 Yuskiv N, Honein MA, Moore CA. (2005). Reported multivitamin consumption and the occurrence of multiple congenital anomalies. Am J Med Genet A.
438 Haider BA, Bhutta ZA. (2006). Multiple-micronutrient supplementation for women during pregnancy. Cochrane Database Syst Rev.
439 Muggli EE, Halliday JL. (2007). Folic acid and risk of twinning: a systematic review of the recent literature, July 1994 to July 2006. Med J Aust.
440 Berry RJ, Li Z, Erickson JD, et al. (1999). Prevention of neural-tube defects with folic acid in China. China-U.S. Collaborative Project for Neural Tube Defect Prevention. N Engl J Med.
441 Chen G, Song X, Ji Y, et al. (2008). Prevention of NTDs with periconceptional multivitamin supplementation containing folic acid in China. Birth Defects Res A Clin Mol Teratol.
442 Dean SV, Lassi ZS, Imam AM, et al. (2014). Preconception care: Nutritional risks and interventions. Reproductive Health.
443 Elhusseini MA, Kassab M, Krawinkel M, et al. (2012). Folic acid intake and neural tube defects (NTDS) in a cohort of Egyptian mothers. International Journal of Gynecology and Obstetrics.
444 Esmaeili A, Hanaei S, Fadakar K, et al. (2013). Risk factors associated with lipomyelomeningocele: a case-control study. Pediatr Neurosurg.
445 Esmaeili A, Hanaei S, Fadakar K, et al. (2014). Risk Factors Associated with Lipomyelomeningocele: A Case-Control Study. Pediatr Neurosurg.
446 Fujimori E, Baldino CF, Sato AP, et al. (2013). Cad Saude Publica.
447 Garcia-Casal MN, Osorio C, Landaeta M, et al. (2005). High prevalence of folic acid and vitamin B12 deficiencies in infants, children, adolescents and pregnant women in Venezuela. Eur J Clin Nutr.
448 Golalipour MJ, Qorbani M, Mirfazeli A, et al. (2014). Risk factors of neural tube defects in northern Iran. Iranian Red Crescent Medical Journal.
449 Gong R, Wang ZP, Gao LJ, et al. (2010). A case-control study of the effects of pregnancy planning on neural tube defects and its primary preventive measures. Birth Defects Res A Clin Mol Teratol.
450 Green TJ, Skeaff CM, Venn BJ, et al. (2007). Red cell folate and predicted neural tube defect rate in three Asian cities. Asia Pac J Clin Nutr.
451 Gu Q, Li Y, Cui ZL, et al. (2012). Homocysteine, folate, vitamin B12 and B6 in mothers of children with neural tube defects in Xinjiang, China. Acta Paediatr.
452 Hibbard BM, Hibbard ED. (1972). Anaemia and folate status in late pregnancy in a mixed Asiatic population. J Obstet Gynaecol Br Commonw.
453 Khattak ST, Khan M, Naheed T, et al. (2010). Prevalence and management of anencephaly at Saidu Teaching Hospital, Swat. J Ayub Med Coll Abbottabad.
454 Kothari BV, Bhende YM. (1950). Crude liver extract, refined liver extract and folic acid in the treatment of pernicious anaemia of pregnancy. Indian J Med Res.
455 Krishnaveni GV, Hill JC, Veena SR, et al. (2009). Low plasma vitamin B12 in pregnancy is associated with gestational ‘diabesity’ and later diabetes. Diabetologia.
456 Kulkarni ML, Jose S. (1997). Folic acid prevents neural tube defects in high prevalence area. Indian Pediatr.
457 Lehti KK. (1993). Stillbirth rates and folic acid and zinc status in low-socioeconomic pregnant women of Brazilian Amazon. Nutrition.
458 Mathur RK, Jain DK, Paliwal G. (2009). Review of etiology of neural tube defects: A hospital based study. Internet J Pediatr Neonatol.
459 Mendu V, Athe R, Ku RK, et al. (2013). Maternal nutrition and adverse birth outcomes in developing countries: A systematic review and meta-analysis. Ann Nutr Metab.
460 Metayer C, Milne E, Dockerty JD, et al. (2014). Maternal supplementation with folic acid and other vitamins and risk of leukemia in offspring: a Childhood Leukemia International Consortium study. Epidemiology.
461 Metz J, Festenstein H, Welch P. (1965). EFFECT OF FOLIC ACID AND VITAMIN B12 SUPPLEMENTATION ON TESTS OF FOLATE AND VITAMIN B12 NUTRITION IN PREGNANCY. Am J Clin Nutr.
462 Mobasheri E, Keshtkar A, Golalipour MJ. (2010). Maternal folate and vitamin b(12) status and neural tube defects in northern iran: a case control study. Iran J Pediatr.
463 Nili F, Jahangiri M. (2006). Risk factors for neural tube defects: a study at university-affiliated hospitals in Tehran. Arch Iran Med.
464 Ogunbode O, Damole IO. (1984). Treatment of anaemia in obstetric patients with sustained-release (Ferrograd Folic 500 Plus) and conventional fersolate and folic acid as separate drugs. Current Therapeutic Research - Clinical and Experimental.
465 Ouarhlent YY, Boudjerra N, Bounecer H. (2013). The risk of venous thromboembolic during pregnancy. J Thromb Haemost.
466 Pradhan M, Anand B, Malhotra M. (2012). Causes of neural tube defects: Environmental and genetic factors. Prenat Diagn.
467 Stewart CP, Christian P, Schulze KJ, et al. (2011). Low maternal vitamin B-12 status is associated with offspring insulin resistance regardless of antenatal micronutrient supplementation in rural Nepal. J Nutr.
468 Tunc T, Karadag YS, Dogulu F, et al. (2007). Predisposing factors of restless legs syndrome in pregnancy. Mov Disord.
469 Vergel RG, Sanchez LR, Heredero BL, et al. (1990). Primary prevention of neural tube defects with folic acid supplementation: Cuban experience. Prenat Diagn.
470 Viteri FE, Casanueva E, Tolentino MC, et al. (2012). Antenatal iron supplements consumed daily produce oxidative stress in contrast to weekly supplementation in Mexican non-anemic women. Reprod Toxicol.
471 Wang M, Wang ZP, Gao LJ, et al. (2013). Maternal body mass index and the association between folic acid supplements and neural tube defects. Acta Paediatr.
472 Yajnik C. (2014). Intrauterine programming of adiposity and diabetes. Obes Rev.
473 Zhang L, Ren A, Li Z, et al. (2006). Folate concentrations and folic acid supplementation among women in their first trimester of pregnancy in a rural area with a high prevalence of neural tube defects in Shanxi, China. Birth Defects Res A Clin Mol Teratol.
474 Blencowe H, Cousens S, Modell B, et al. (2010). Folic acid to reduce neonatal mortality from neural tube disorders. Int J Epidemiol.
475 Wehby GL, Felix TM, Goco N, et al. (2013). High dosage folic acid supplementation, oral cleft recurrence and fetal growth. Int J Environ Res Public Health.
476 (1990). Evidence for an association between periconceptional use of multivitamins and neural tube defects. Nutr Rev.
477 Center for Disease Control and Prevention. (1995). Prevention program for reducing risk for neural tube defects--South Carolina, 1992-1994. JAMA.
478 Alasfoor D, Elsayed MK, Mohammed AJ. (2010). Spina bifida and birth outcome before and after fortification of flour with iron and folic acid in Oman. East Mediterr Health J.
479 Averbeck P. (1980). Multivitamin prophylaxis as a cause of neural tube defect. Lancet.
480 Barua S, Kuizon S, Junaid MA. (2014). Folic acid supplementation in pregnancy and implications in health and disease. J Biomed Sci.
481 Beard CM, Panser LA, Katusic SK. (2011). Is excess folic acid supplementation a risk factor for autism?. Med Hypotheses.
482 Bendich A. (1993). Folic acid and neural tube defects. Introduction to Part II. Ann N Y Acad Sci.
483 Bognar M, Ponyi A, Hauser P, et al. (2008). Improper supplementation habits of folic acid intake by Hungarian pregnant women: improper recommendations. J Am Coll Nutr.
484 Chan AC, van Essen P, Scott H, et al. (2008). Folate awareness and the prevalence of neural tube defects in South Australia, 1966-2007. Med J Aust.
485 Clemmensen D, Thygesen M, Rasmussen MM, et al. (2011). Decreased incidence of myelomeningocele at birth: effect of folic acid recommendations or prenatal diagnostics?. Childs Nerv Syst.
486 Crider K, Devine O, Qi Y, et al. (2015). Predicting the impact of folic acid fortification, ready to eat cereals and supplement use on the risk of neural tube defects in the United States. FASEB J.
487 Czeizel AE. (1995). Folic acid in the prevention of neural tube defects. J Pediatr Gastroenterol Nutr.
488 Dixon J. (2007). Folic acid and neural tube defects in New Zealand: a cautionary tale?. N Z Med J.
489 Eros E, Géher P, Gömör B, et al. (1998). Epileptogenic activity of folic acid after drug induces SLE (folic acid and epilepsy). Eur J Obstet Gynecol Reprod Biol.
490 Haggarty P, Campbell DM, Duthie S, et al. (2008). Folic acid use in pregnancy and embryo selection. BJOG.
491 Harrison RJ. (1971). Vitamin B12 levels in erythrocytes in anaemia due to folate deficiency. Br J Haematol.
492 Herbert V. (1968). Inborn errors in folate metabolism--a cause of mental retardation?. Ann Intern Med.
493 Hernan MA, Hernandez-Diaz S, Werler MM, et al. (2002). Causal knowledge as a prerequisite for confounding evaluation: an application to birth defects epidemiology. Am J Epidemiol.
494 House JD, March SB, Ratnam MS, et al. (2006). Improvements in the status of folate and cobalamin in pregnant Newfoundland women are consistent with observed reductions in the incidence of neural tube defects. Can J Public Health.
495 Israels MC, Da Cunha FA. (1952). Megaloblastic anaemia of pregnancy. Lancet.
496 Jackson IM, Doig WB, McDonald G. (1967). Pernicious anaemia as a cause of infertility. Lancet.
497 James SJ. (2004). Maternal metabolic phenotype and risk of Down syndrome: beyond genetics. Am J Med Genet A.
498 Kar A, Kar T, Kanungo S, et al. (2015). Risk factors, organ weight deviation and associated anomalies in neural tube defects: A prospective fetal and perinatal autopsy series. Indian J Pathol Microbiol.
499 Klusmann A, Heinrich B, Stopler H, et al. (2005). A decreasing rate of neural tube defects following the recommendations for periconceptional folic acid supplementation. Acta Paediatr.
500 Latha V, Sridhar M. (2010). Vitamin B supplementation to prevent neural tube defects?. Indian Pediatr.
501 Locksmith GJ, Duff P. (1998). Preventing neural tube defects: the importance of periconceptional folic acid supplements. Obstet Gynecol.
502 Matsubara S, Imai K, Murayama K, et al. (2012). Severe liver dysfunction during nausea and vomiting of pregnancy: folic acid supplement as a suggested culprit. J Obstet Gynaecol.
503 Navamani H. (2009). The real scenario of a preventable defect. International Journal of Gynecology and Obstetrics.
504 Novy J, Ballhausen D, Bonafe L, et al. (2010). Recurrent postpartum cerebral sinus vein thrombosis as a presentation of cystathionine-beta-synthase deficiency. Thromb Haemost.
505 Poretti A, Anheier T, Zimmermann R, et al. (2008). Neural tube defects in Switzerland from 2001 to 2007: are periconceptual folic acid recommendations being followed?. Swiss Med Wkly.
506 Richard-Tremblay AA, Sheehy O, Berard A. (2013). Annual trends in use of periconceptional folic acid and birth prevalence of major congenital malformations. Curr Drug Saf.
507 Rush D. (1994). Periconceptional folate and neural tube defect. Am J Clin Nutr.
508 Sole-Navais P, Cavalle-Busquets P, Fernandez-Ballart JD, et al. (2015). Early pregnancy B vitamin status, one carbon metabolism, pregnancy outcome and child development. Biochimie.
509 Stephenson HE. (2005). Folic acid and neural tube defects. South Med J.
510 Stumpf DA. (2003). Symptoms of B(12) deficiency can occur in women of childbearing age supplemented with folate. Neurology.
511 (1990). Evidence against an association between periconceptional use of multivitamins and neural tube defects. Nutr Rev.
512 (1992). Recommendations for the use of folic acid to reduce the number of cases of spina bifida and other neural tube defects. MMWR Recomm Rep.
513 Felkner M, Suarez L, Hendricks K, et al. (2005). Implementation and outcomes of recommended folic acid supplementation in Mexican-American women with prior neural tube defect-affected pregnancies. Prev Med.
514 Hamanoue H, Ebisawa Y, Mizusawa M, et al. (2010). For the occurrence of neural tube defects in Japan, is folate intake effective?. Congenital Anomalies.
515 Mosley BS, Hobbs CA, Flowers BS, et al. (2007). Folic acid and the decline in neural tube defects in Arkansas. J Ark Med Soc.
516 Millar WJ. (2004). Folic acid supplementation. Health Rep.
517 Dougan C, Armstrong N, Bell S, et al. (2014). Audit of identification of antenatal patients with a raised BMI requiring high dose folate. Arch Dis Child Fetal Neonatal Ed.
518 Harden CL, Pennell PB, Koppel BS, et al. (2009). Management issues for women with epilepsy--focus on pregnancy (an evidence-based review): III. Vitamin K, folic acid, blood levels, and breast-feeding: Report of the Quality Standards Subcommittee and Therapeutics and Technology Assessment Subcommittee of the American Academy of Neurology and the American Epilepsy Society. Epilepsia.
519 Hartridge T, Illing HM, Sandy JR. (1999). The role of folic acid in oral clefting. Br J Orthod.
520 (1997). Interactions with periconceptional use of folic acid?. Geneesmiddelenbulletin.
521 Abramsky L, Botting B, Chapple J, et al. (1999). Has advice on periconceptional folate supplementation reduced neural-tube defects?. Lancet.
522 Afshar M, Golalipour MJ, Farhud D. (2006). Epidemiologic aspects of neural tube defects in South East Iran. Neurosciences (Riyadh).
523 Alperin JB, Haggard ME, McGanity WJ. (1969). Folic acid, pregnancy, and abruptio placentae. Am J Clin Nutr.
524 Alto WA, Czarnecki DF. (2002). Pregnancy tests and folic acid. J Reprod Med.
525 Azzena A, Sciortino R, Salmaso R. (1998). Acrania, MTHFR 677C-->T mutation and role of folate intake. Int J Gynaecol Obstet.
526 Bergen N, Timmermans S, Hofman A, et al. (2010). First trimester homocysteine and folate levels are associated with increased adverse pregnancy outcomes. Pregnancy Hypertens.
527 Bhatla N, Kaul N, Lal N, et al. (2009). Comparison of effect of daily versus weekly iron supplementation during pregnancy on lipid peroxidation. J Obstet Gynaecol Res.
528 Bissenden JG. (1982). The role of nutrition in pregnancy. Practitioner.
529 Chandler AL, Hobbs CA, Mosley BS, et al. (2012). Neural tube defects and maternal intake of micronutrients related to one-carbon metabolism or antioxidant activity. Birth Defects Res A Clin Mol Teratol.
530 Cherry FF, Bennett EA, Bazzano GS, et al. (1981). Plasma zinc in hypertension/toxemia and other reproductive variables in adolescent pregnancy. Am J Clin Nutr.
531 Cornel MC, Erickson JD. (1997). Comparison of national policies on periconceptional use of folic acid to prevent spina bifida and anencephaly (SBA). Teratology.
532 Daniel WA, Mounger JR, Perkins JC. (1971). Obstetric and fetal complications in folate-deficient adolescent girls. Am J Obstet Gynecol.
533 De Wals P, Rusen ID, Lee NS, et al. (2003). Trend in prevalence of neural tube defects in Quebec. Birth Defects Res A Clin Mol Teratol.
534 DeRuiter J, Holston PL. (2010). Review of selected NMEs 2010.
535 Elsinga J, Jong-Potjer LC, Pal-de Bruin KM, et al. (2008). The effect of preconception counselling on lifestyle and other behaviour before and during pregnancy. Womens Health Issues.
536 Fleming AF, Broquist HP. (1967). Biopterin and folic acid deficiency. Am J Clin Nutr.
537 Freire WB, Hertrampf E, Cortes F. (2000). Effect of folic acid fortification in Chile: preliminary results. Eur J Pediatr Surg.
538 Froessler B, Cocchiaro C, Saadat-Gilani K, et al. (2013). Intravenous iron sucrose versus oral iron ferrous sulfate for antenatal and postpartum iron deficiency anemia: A randomized trial. Journal of Maternal-Fetal and Neonatal Medicine.
539 Furness DL, Yasin N, Dekker GA, et al. (2012). Maternal red blood cell folate concentration at 10-12 weeks gestation and pregnancy outcome. J Matern Fetal Neonatal Med.
540 Giles C. (1966). An account of 335 cases of megaloblastic anaemia of pregnancy and the puerperium. J Clin Pathol.
541 Giugliani ER, Jorge SM, Goncalves AL. (1984). Folate and vitamin B12 deficiency among parturients from Porto Alegre, Brazil. Rev Invest Clin.
542 Gochhait S, Gupta A, Shekhar S, et al. (2013). A cross-sectional study of nutritional markers in pregnancy. Indian Journal of Hematology and Blood Transfusion.
543 Gomes TS, Lindner U, Tennekoon KH, et al. (2010). Homocysteine in small-for-gestational age and appropriate-for-gestational age preterm neonates from mothers receiving folic acid supplementation. Clin Chem Lab Med.
544 Gordon TE, Leeth EA, Nowinski CJ, et al. (2003). Geographic and temporal analysis of folate-sensitive fetal malformations. J Soc Gynecol Investig.
545 Grandinetti CA. (2009). Inflammatory bowel disease.
546 Groenen PM, van Rooij IA, Peer PG, et al. (2004). Marginal maternal vitamin B12 status increases the risk of offspring with spina bifida. Am J Obstet Gynecol.
547 Haberg SE, London SJ, Nafstad P, et al. (2011). Maternal folate levels in pregnancy and asthma in children at age 3 years. J Allergy Clin Immunol.
548 Haberg SE, London SJ, Ueland P, et al. (2010). Maternal folate levels in pregnancy and asthma at 3 years of age. J Allergy Clin Immunol.
549 Haider Batool A, Bhutta Zulfiqar A. (2015). Multiple-micronutrient supplementation for women during pregnancy. Cochrane Database of Systematic Reviews.
550 Hall MH. (1977). Folates and the fetus. Lancet.
551 Halliday JL, Riley M. (2000). Fortification of foods with folic acid. N Engl J Med.
552 Hambidge M, Hackshaw A, Wald N. (1993). Neural tube defects and serum zinc. Br J Obstet Gynaecol.
553 Hegde UM, Khunda S, GW MA, et al. (1975). Thalassaemia, iron, and pregnancy. Br Med J.
554 Hibbard BM, Hibbard ED. (1971). Neutrophil hypersegmentation and defective folate metabolism in pregnancy. J Obstet Gynaecol Br Commonw.
555 Hibbard ED, Spencer WJ. (1970). Low serum B12 levels and latent Addisonian anaemia in pregnancy. J Obstet Gynaecol Br Commonw.
556 Hogg BB, Tamura T, Johnston KE, et al. (2000). Second-trimester plasma homocysteine levels and pregnancy-induced hypertension, preeclampsia, and intrauterine growth restriction. Am J Obstet Gynecol.
557 Huch R. (1999). Anaemia during pregnancy. Med Hyg (Geneve).
558 Imdad A, Yakoob MY, Bhutta ZA. (2011). The effect of folic acid, protein energy and multiple micronutrient supplements in pregnancy on stillbirths. BMC Public Health.
559 Janz D. (1994). Are antiepileptic drugs harmful when taken during pregnancy?. J Perinat Med.
560 Johnston RB. (2008). Will increasing folic acid in fortified grain products further reduce neural tube defects without causing harm?: consideration of the evidence. Pediatr Res.
561 Jongbloet PH, Zielhuis SA, Pasker-de Jong PC. (2002). Outcomes in pregnancy. Lancet.
562 Joy J, McClure N, Cooke IE. (2008). A comparison of spontaneously conceived twins and twins conceived by artificial reproductive technologies. J Obstet Gynaecol.
563 Joy R, Dick A, Love C. (2010). Pregnant women with epilepsy: Incidence, management and outcomes. Arch Dis Child Fetal Neonatal Ed.
564 Kancherla V, Druschel CM, Oakley Jr GP. (2014). Population-based study to determine mortality in spina bifida: New York State congenital malformations registry, 1983 to 2006. Birth Defects Research Part A - Clinical and Molecular Teratology.
565 Kapur B, Soldin OP, Koren G. (2002). Potential prevention of neural tube defects by assessment of women of childbearing age through monitoring of folate. Ther Drug Monit.
566 Kennedy DA, Stern SJ, Moretti M, et al. (2011). Folate intake and the risk of colorectal cancer: a systematic review and meta-analysis. Cancer Epidemiol.
567 Kershaw PW, Girdwood RH. (1964). SOME INVESTIGATIONS OF FOLIC-ACID DEFICIENCY. Scott Med J.
568 Khanna S, Dube B, Kumar S. (1977). Anaemia of pregnancy in northern India. Nature and therapeutic follow-up. Trop Geogr Med.
569 Kim JH, Jeong KS, Ha EH, et al. (2013). Relationship between maternal mid pregnancy folate levels and the risk of allergic and respiratory diseases in early childhood: The mothers and children's environmental health (MOCEH) study. J Allergy Clin Immunol.
570 Kim JH, Jeong KS, Ha EH, et al. (2013). Prenatal and postnatal exposure to folate and risk of allergic and respiratory diseases in children: The mothers and children's environmental health study in South Korea. Allergy: European Journal of Allergy and Clinical Immunology.
571 Kirke PN, Daly LE, Molloy A, et al. (1996). Maternal folate status and risk of neural tube defects. Lancet.
572 Kirke PN, Molloy AM, Daly LE, et al. (1993). Maternal plasma folate and vitamin B12 are independent risk factors for neural tube defects. Q J Med.
573 Koc A, Kocyigit A, Soran M, et al. (2006). High frequency of maternal vitamin B12 deficiency as an important cause of infantile vitamin B12 deficiency in Sanliurfa province of Turkey. Eur J Nutr.
574 Koch MC, Stegmann K, Ziegler A, et al. (1998). Evaluation of the MTHFR C677T allele and the MTHFR gene locus in a German spina bifida population. Eur J Pediatr.
575 Kosus N, Kosus A, Hizli D, et al. (2012). Can serum ferritin, vitamin B(12) and folic acid levels affect serum screening tests during pregnancy?. J Matern Fetal Neonatal Med.
576 Laurence KM. (1985). Prevention of neural tube defects by improvement in maternal diet and preconceptional folic acid supplementation. Prog Clin Biol Res.
577 Lawrence C, Klipstein FA. (1967). Megaloblastic anemia of pregnancy in New York City. Ann Intern Med.
578 Leck I. (1977). Folates and the fetus. Lancet.
579 Lindhe BA. (1967). Pregnancy anemia with special reference to folic acid deficiency. Acta Obstet Gynecol Scand.
580 Lindhout D, Wegner I. (2013). Periconceptional folic acid supplementation in pregnancies with antiepileptic drugs use. Epilepsia.
581 Manizheh SM, Mandana S, Hassan A, et al. (2009). Comparison study on the effect of prenatal administration of high dose and low dose folic acid. Saudi Med J.
582 Matos A, Ferreira J, Portelinha A, et al. (2011). Study of C677T methylene tetrahydrofolate reductase (MTHFR) polymorphism in preeclampsia. Pregnancy Hypertens.
583 Merialdi M, Caulfield LE, Zavaleta N, et al. (2004). Randomized controlled trial of prenatal zinc supplementation and the development of fetal heart rate. Am J Obstet Gynecol.
584 Molen EF, Verbruggen B, Nováková I, et al. (2000). Hyperhomocysteinemia and other thrombotic risk factors in women with placental vasculopathy. BJOG.
585 Murphy M, Whiteman D, Stone D, et al. (2000). Dietary folate and the prevalence of neural tube defects in the British Isles: the past two decades. BJOG.
586 Nagy GR, Gyorffy B, Galamb O, et al. (2006). Use of routinely collected amniotic fluid for whole-genome expression analysis of polygenic disorders. Clin Chem.
587 Nazer HJ, Cifuentes OL, Aguila RA, et al. (2007). Rev Med Chil.
588 Ohya Y, Futamura M, Saito H, et al. (2010). Maternal retinol intake during pregnancy was a risk factor of offspring's atopic eczema at 18 months. Allergy: European Journal of Allergy and Clinical Immunology.
589 Padula AM, Yang W, Carmichael SL, et al. (2015). Traffic-related air pollution, neighborhood socioeconomic factors, and neural tube defects in the San Joaquin Valley of California. Birth Defects Research Part A - Clinical and Molecular Teratology.
590 Padula AM, Yang W, Carmichael SL, et al. (2015). Air Pollution, Neighbourhood Socioeconomic Factors, and Neural Tube Defects in the San Joaquin Valley of California. Paediatr Perinat Epidemiol.
591 Sata F, Yamada H, Kishi R, et al. (2012). Maternal folate, alcohol and energy metabolism-related gene polymorphisms and the risk of recurrent pregnancy loss. J Dev Orig Health Dis.
592 Shah PS, Ohlsson A. (2009). Effects of prenatal multimicronutrient supplementation on pregnancy outcomes: a meta-analysis. CMAJ.
593 Simmons CJ, Mosley BS, Fulton-Bond CA, et al. (2004). Birth defects in Arkansas: is folic acid fortification making a difference?. Birth Defects Res A Clin Mol Teratol.
594 Thame G, Guerra-Shinohara EM, Moron AF. (2002). Serum folate by two methods in pregnant women carrying fetuses with neural tube defects. Clin Chem.
595 Trivedi M, Sharma S, Rifas-Shiman S, et al. (2014). Maternal intake of dietary methyl donors in pregnancy and childhood asthma at 7 years. Am J Respir Crit Care Med.
596 Valera-Gran D, Garcia de la Hera M, Navarrete-Munoz EM, et al. (2014). Folic acid supplements during pregnancy and child psychomotor development after the first year of life. JAMA Pediatr.
597 van der Pal-de Bruin KM, van der Heijden PG, Buitendijk SE, et al. (2003). Periconceptional folic acid use and the prevalence of neural tube defects in The Netherlands. Eur J Obstet Gynecol Reprod Biol.
598 Volcik KA, Shaw GM, Lammer EJ, et al. (2003). Evaluation of infant methylenetetrahydrofolate reductase genotype, maternal vitamin use, and risk of high versus low level spina bifida defects. Birth Defects Res A Clin Mol Teratol.
599 Waller DK, Tita AT, Annegers JF. (2003). Rates of twinning before and after fortification of foods in the US with folic acid, Texas, 1996 to 1998. Paediatr Perinat Epidemiol.
600 Wang T, Zhang HP, Liang ZA, et al. (2015). Is folate at risk for development of asthma or other allergic diseases?. Am J Respir Crit Care Med.
601 Zlotogora J, Amitai Y, Leventhal A. (2006). Surveillance of neural tube defects in Israel: the effect of the recommendation for periconceptional folic acid. Isr Med Assoc J.
602 Persad VL, Van den Hof MC, Dube JM, et al. (2002). Incidence of open neural tube defects in Nova Scotia after folic acid fortification. CMAJ.
603 Haider BA, Olofin I, Wang M, et al. (2013). Anaemia, prenatal iron use, and risk of adverse pregnancy outcomes: systematic review and meta-analysis. BMJ.
604 Czeizel AE, Medveczky E. (2003). Periconceptional multivitamin supplementation and multimalformed offspring. Obstet Gynecol.
605 Alwan NA, Greenwood DC, Simpson NA, et al. (2010). The relationship between dietary supplement use in late pregnancy and birth outcomes: a cohort study in British women. BJOG.
606 Bergen NE, Timmermans S, Hofman A, et al. (2011). First trimester homocysteine and folate levels are associated with increased adverse pregnancy outcomes. Reprod Sci.
607 Evers IM, de Valk HW, Visser GH. (2004). Risk of complications of pregnancy in women with type 1 diabetes: nationwide prospective study in the Netherlands. BMJ.
608 Thompson S, Torres M, Stevenson R, et al. (2000). Periconceptional vitamin use, dietary folate and occurrent neural tube defected pregnancies in a high risk population. Ann Epidemiol.
609 Thompson SJ, Torres ME, Stevenson RE, et al. (2003). Periconceptional multivitamin folic acid use, dietary folate, total folate and risk of neural tube defects in South Carolina. Ann Epidemiol.
610 Lindsay K, McNulty B, Brennan L, et al. (2013). Dietary intakes in obese pregnancy. Proc Nutr Soc.
611 Lopez-Quesada E, Vilaseca MA, Lailla JM. (2003). Plasma total homocysteine in uncomplicated pregnancy and in preeclampsia. Eur J Obstet Gynecol Reprod Biol.
612 Smithells RW, Sheppard S, Schorah CJ. (1976). Vitamin dificiencies and neural tube defects. Arch Dis Child.
613 Wasserman CR, Shaw GM, Selvin S, et al. (1998). Socioeconomic status, neighborhood social conditions, and neural tube defects. Am J Public Health.
614 de Walle HE, van der Pal KM, de Jong-van den Berg LT, et al. (1998). Periconceptional folic acid in The Netherlands in 1995. Socioeconomic differences. J Epidemiol Community Health.
615 Ibba RM, Zoppi MA, Floris M, et al. (2003). Neural tube defects in the offspring of thalassemia carriers. Fetal Diagn Ther.
616 Brough L, Rees GA, Crawford MA, et al. (2010). Effect of multiple-micronutrient supplementation on maternal nutrient status, infant birth weight and gestational age at birth in a low-income, multi-ethnic population. Br J Nutr.
617 Ramakrishnan U, Grant F, Goldenberg T, et al. (2012). Effect of women's nutrition before and during early pregnancy on maternal and infant outcomes: a systematic review. Paediatr Perinat Epidemiol.
618 Berg MJ, Van Dyke DC, Chenard C, et al. (2001). Folate, zinc, and vitamin B-12 intake during pregnancy and postpartum. J Am Diet Assoc.
619 (1993). Folic acid and neural tube defects. Practica Pediatrica.
620 (1996). Duodecim.
621 (1996). Folic acid during conception: Supplements or natural food?. Geneesmiddelenbulletin.
622 Ahrndt S. (1997). Folic acid during pregnancy and against depressions. Dtsch Apoth Ztg.
623 Antal R, Siffel C, Czeizel E. (1996). Orv Hetil.
624 Bailon ME, Landa GS. (2003). Aten Primaria.
625 Bodem S. (1994). Folic acid in the prevention of neural tube defects in newborns. Pharm Ztg.
626 Bognar M, Hauser P, Jakab Z, et al. (2006). Orv Hetil.
627 Burdan F. (2002). Ginekol Pol.
628 Calvani M. (1981). Recenti Prog Med.
629 Chiaffarino F, Ascone GB, Bortolus R, et al. (2010). Minerva Ginecol.
630 Czeizel E. (1999). Orv Hetil.
631 Czeizel E, Dudas I. (1994). Orv Hetil.
632 Daltveit AK. (2004). Tidsskr Nor Laegeforen.
633 de la Rosa Morales V, Guzman Juarez L, Guarneros Cortes CA. (2000). Ginecol Obstet Mex.
634 Eichholzer M, Weil C, Stahelin HB, et al. (2002). Folic acid to prevent spina bifida. Should wheat be fortified in combination with vitamin B6 and vitamin B12?. Schweizerische Zeitschrift fur GanzheitsMedizin.
635 Elsborg L, Norgaard-Pedersen B, Lange AP. (1993). Ugeskr Laeger.
636 Engin-Ustun Y, Ustun Y, Turkcuoglu I, et al. (2007). Evaluation of cases with neural tube defects in an University Hospital in Eastern Anatolia. Jinekoloji ve Obstetrik Dergisi.
637 Feferbaum R, Maspes V, Vaz FA. (1982). Rev Paul Med.
638 Fessler B. (2005). Preventive use of folic acid for women who want to become pregnant. Dtsch Apoth Ztg.
639 Gibert MJ, Martin I, Ramos M. (2003). Med Clin (Barc).
640 Goeltner E. (1981). Anemia of pregnancy. Therapiewoche.
641 Goltner E. (1971). Med Klin.
642 Gross N, Bruhwiler H, Luscher KP. (2002). Preconceptional folic acid prophylaxis: More promotion is required. Gynakologie fur Hausarzte.
643 Hallmans G. (2007). Lakartidningen.
644 Heilmann E, Boving K, Dame WR. (1977). Z Geburtshilfe Perinatol.
645 Hoffmann I. (1993). Is prevention of neural tube defects possible by means of folic acid substitution?. Fortschr Med.
646 Hong SC, Choi JS, Han JY, et al. (2011). Essence of preconception counseling and care. Journal of the Korean Medical Association.
647 Jungmayr P. (1994). Folic acid administration reduces incidence of neural tube defects. Dtsch Apoth Ztg.
648 Katan MB, Verhoef P. (2006). Uncertain effects of folic acid on disorders other than neural-tube defects [6]. Ned Tijdschr Geneeskd.
649 Kharb S, Smiti N, Dipti A. (2012). Study of maternal and cord blood levels of homocysteine, vitamin B12 and folic acid in pregnancy induced hypertension. Salud(i)Ciencia.
650 Kloosterman J, de Jong N, Rompelberg CJ, et al. (2006). Ned Tijdschr Geneeskd.
651 Koletzko B, Von Kries R. (1995). Prevention of neural tube defects by folic acid supplementation in early pregnancy. Monatsschr Kinderheilkd.
652 Konopka L. (1970). Pol Tyg Lek.
653 Kwee-Zuiderwijk WJM. (2003). Standard on pregnancy and puerperium of the Dutch College of General Practitioners: Information, stimulation and surveillance. Pharm Weekbl.
654 Lee WH, Park CH, Ko HY, et al. (2008). Two cases of pulmonary thromboembolism in young patients with hyperhomocysteinemia. Tuberculosis and Respiratory Diseases.
655 Leemans L. (2012). J Pharm Belg.
656 Levy S, Rachmilewitz EA, Izak G, et al. (1968). A therapeutic trial in anemia of pregnancy. Isr J Med Sci.
657 Lung-Kurt S, Boos R, Schmidt W. (1993). Toxoplasmosis during pregnancy. Arch Gynecol Obstet.
658 Mathias L, Nobile L, Mathias R. (1981). Anticonvulsivants in pregnancy - fetal effects. Revista Brasileira de Clinica e Terapeutica.
659 Metneki J, Dudas I, Czeizel AE. (1996). Higher rate of multiple births after periconceptual multivitamin supplementation. Orv Hetil.
660 Metneki J, Dudas I, Czeizel E. (1996). Orv Hetil.
661 Meyer R. (1991). Folic acids in the prevention of spina bifida. Pharm Ztg.
662 Molins A. (2000). Rev Neurol.
663 Nexo E. (1993). Ugeskr Laeger.
664 Olivier D. (2004). J Gynecol Obstet Biol Reprod (Paris).
665 Orn P. (1999). Lakartidningen.
666 Potier de Courcy G. (1997). J Gynecol Obstet Biol Reprod (Paris).
667 Potier De Courcy G, Frelut ML, Gourchala F, et al. (1993). Folate status and fetal development. Gazette Medicale.
668 Queisser-Luft A, Spranger J. (2006). Congenital malformations. Deutsches Arzteblatt.
669 Rasmussen LB, Andersen NL, Ovesen LF. (1993). Ugeskr Laeger.
670 Reinke C. (1993). Prevention of neural tube defects: Folic acid during pregnancy. Schweizerische Apotheker Zeitung.
671 Rincon-Pabon D, Ramirez-Velez R. (2013). Social determinants, prenatal care and postpartum depression: Results from the 2010 National Nutrition Survey: A cross sectional study. Progresos de Obstetricia y Ginecologia.
672 Ritvanen A. (1996). Duodecim.
673 Roegholt LP. (1993). Ned Tijdschr Geneeskd.
674 Rosch C, Steinbicker V, Kolbe M, et al. (1999). Gesundheitswesen.
675 Schneider KTM, Qattawi O. (2002). Folic acid substitution before and during pregnancy. Tagliche Praxis.
676 Steegers-Theunissen RP, Boers GH, Eskes TK. (1993). Ned Tijdschr Geneeskd.
677 Suske-Zirpel VP. (2009). Prevention during pregnancy and lactation: More intensive advice on folate. Pharm Ztg.
678 Teichmann A, Schlicht E. (1995). Med Monatsschr Pharm.
679 Thamm M, Mensink GB, Hermann-Kunz E. (1998). Gesundheitswesen.
680 Tonz O. (1996). Folic acid prophylaxis in the prevention of neural tube defects. Schweizer Apothekerzeitung.
681 Van Veen WA. (1994). Folic acid for expectant mothers. Huisarts en Wetenschap.
682 Vargas MH, Campos-Bedolla P, Segura P. (2012). Salud Publica Mex.
683 Vollmer H. (1995). Prevention of neural tube defects by folic acid. Z Allgemeinmed.
684 Wijnja L. (1993). Ned Tijdschr Geneeskd.
685 Zabala R, Waisman I, Corelli M, et al. (2008). Arch Argent Pediatr.
686 Anneren G. (1991). Lakartidningen.
687 (1993). The significance of folic acid during pregnancy. Med Welt.
688 Bense A, Harmos C, Endrodi T, et al. (2005). Prevention of anaemia in pregnancy with combined iron supplementation containing ferro-sulfate, vitamin B12 and folic acid. Magyar Noorvosok Lapja.
689 Bortolus R.
690 Hajnzic TF. (2002). Macrocytic anaemias in children. Paediatria Croatica, Supplement.
691 Sarella A, Glynou A, Tasiopoulou I. (2014). The role of folic acid in pregnancy. Epitheorese Klinikes Farmakologias kai Farmakokinetikes.