# Appendix B Inclusion/Exclusion Criteria

| Include | Exclude
Populations | KQ 1: Women of childbearing age (postmenarchal and premenopausal; women with the potential for or planning childbearing) KQ 2: Women of childbearing age (postmenarchal and premenopausal; women with the potential for or planning childbearing); fetus, neonate, or child from index pregnancy | KQ 1: Prepubertal girls; men; women without the potential for childbearing (e.g., women who are postmenopausal or have genetic uterine or ovarian abnormalities)
Interventions | Folic acid supplementation, with or without food fortification or naturally occurring folate, for the prevention of neural tube defects and other birth defects Supplementation with micronutrients (e.g., multivitamins, iron) in combination with folic acid for the prevention of neural tube defects only | Food fortification only Naturally occurring folate only Counseling to improve dietary supplementation Supplementation with micronutrients (e.g., multivitamins, iron) in combination with folic acid for the prevention of harms only
Comparisons | KQs 1a, 1b, 2a: Placebo or no treatment; dietary supplementation only; supplementation with prenatal vitamins without folic acid; iron supplements without folic acid KQs 1b, 1c, 2b: All of the above plus folic acid supplementation of varying dosages | KQs 1a, 1b, 2a: Lower or higher doses of folic acid supplementation; folic acid vs. other active comparators KQs 1c, 2b: Folic acid vs. other active comparators (e.g., multivitamins)
Outcomes | Neonatal outcomes: Neural tube defects Harms from treatment: Twins Colorectal cancer or other reported types of cancer Vitamin B12 deficiency Vitamin B6 deficiency Other reported child, neonatal, fetal, or maternal harms | Benefits not specified in inclusion criteria
Timing | KQs 1a, 1b: Supplementation initiated before index pregnancy or in the first trimester KQs 1c, 2a, 2b: All timing | KQs 1a, 1b: Supplementation initiated after the first trimester of pregnancy
Settings | Developed countries categorized as “Very High” on the Human Development Index (as defined by the United Nations Development Programme) | Countries not categorized as “Very High” on the Human Development Index
Study designs | Efficacy (KQ 1): Randomized, controlled trials; controlled clinical trials; cohort or case-control studies Harms (KQ 2): Randomized, controlled trials; controlled clinical trials; or observational studies (case-control, cohort, registry data) | Commentaries, editorials, case reports
Sample size | More than 50 participants | 50 participants or less
Quality | Good and fair quality | Poor quality
Language | English | Non-English studies