# Appendix A Search Strategy and Detailed Methods

## 6/23/14 PubMed Benefits Search

Search | Query | Items found
#1 | Search (Pregnancy[MeSH] OR pregnancy[tw] OR pregnant[tw] OR “pregnant women”[MeSH]) | 786032
#2 | Search (“folic acid”[MeSH] OR “vitamin b9”[tw] OR “vitamin m”[tw] or “Pteroylglutamic Acid”[tw] OR “folvite”[tw] OR “folacin”[tw] OR “folate”[tw] OR “folic acid”[tw]) | 46413
#3 | Search (multivitamin[all fields] OR “prenatal vitamin”[all fields] OR multivitamins[all fields] OR “prenatal vitamins”[all fields] OR “vitamin supplement”[all fields] OR “vitamin supplements”[all fields]) | 4154
#4 | Search (“neural tube defects”[MeSH Terms] OR “spina bifida”[All Fields] OR “neural tube damage”[All Fields] OR “neural tube defect”[All Fields] OR “neural tube defects”[All Fields] OR “neural tube disorders”[All Fields] OR “Neural tube defect, folate-sensitive”[Supplementary Concept] OR Craniorachischisis[tw] OR Craniorachischises[tw] OR Diastematomyelia[tw] OR Diastematomyelias[tw] OR “Tethered Cord Syndrome”[tw] OR “Tethered Cord Syndromes”[tw] OR “Occult Spinal Dysraphism Sequence”[tw] OR “Tethered Spinal Cord Syndrome”[tw] OR “Occult Spinal Dysraphism”[tw] OR “Occult Spinal Dysraphisms”[tw] OR Iniencephaly[tw] OR Iniencephalies[tw] OR “Neurenteric Cyst”[tw] OR “Neurenteric Cysts”[tw] OR “Neuroenteric Cyst”[tw] OR “Neuroenteric Cysts”[tw] OR “Spinal Cord Myelodysplasia”[tw] OR “Spinal Cord Myelodysplasias”[tw] OR Acrania[tw] OR Acranias[tw] OR Exencephaly[tw] OR Exencephalies[tw]) | 27529
#5 | Search (#1 AND (#2 OR #3) AND #4) | 1794
#6 | Search (#1 AND (#2 OR #3) AND #4) Filters: Humans | 1623
#7 | Search (#1 AND (#2 OR #3) AND #4) Filters: Other Animals | 201
#8 | Search (#7 NOT #6) | 96
#9 | Search (#5 NOT #8) | 1698

## 9/4/14 PubMed Benefits Addendum Search

### Added: “5-methyltetrahydropteroylpentaglutamate” [Supplementary Concept] OR “5-methyltetrahydrofolate triglutamate”

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (5-Me-THF OR 5-Me-H4F OR 5-methyltetrahydrofolate OR 5-methyltetrahydropteroylpentaglutamate” [Supplementary Concept] OR 5-methyltetrahydrofolate triglutamate” [Supplementary Concept]) | 2015 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“folic acid”[MeSH] OR “vitamin b9”[tw] OR “vitamin m”[tw] or “Pteroylglutamic Acid”[tw] OR “folvite”[tw] OR “folacin”[tw] OR “folate”[tw] OR “folic acid”[tw] OR multivitamin[all fields] OR “prenatal vitamin”[all fields] OR multivitamins[all fields] OR “prenatal vitamins”[all fields] OR “vitamin supplement”[all fields] OR “vitamin supplements”[all fields]) | 50052 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 NOT #2) | 534 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“neural tube defects”[MeSH Terms] OR “spina bifida”[All Fields] OR “neural tube damage”[All Fields] OR “neural tube defect”[All Fields] OR “neural tube defects”[All Fields] OR “neural tube disorders”[All Fields] OR “Neural tube defect, folate-sensitive”[Supplementary Concept] OR Craniorachischisis[tw] OR Craniorachischises[tw] OR Diastematomyelia[tw] OR Diastematomyelias[tw] OR “Tethered Cord Syndrome”[tw] OR “Tethered Cord Syndromes”[tw] OR “Occult Spinal Dysraphism Sequence”[tw] OR “Tethered Spinal Cord Syndrome”[tw] OR “Occult Spinal Dysraphism”[tw] OR “Occult Spinal Dysraphisms”[tw] OR Iniencephaly[tw] OR Iniencephalies[tw] OR “Neurenteric Cyst”[tw] OR “Neurenteric Cysts”[tw] OR “Neuroenteric Cyst”[tw] OR “Neuroenteric Cysts”[tw] OR “Spinal Cord Myelodysplasia”[tw] OR “Spinal Cord Myelodysplasias”[tw] OR Acrania[tw] OR Acranias[tw] OR Exencephaly[tw] OR Exencephalies[tw]) | 27715 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (Pregnancy[MeSH] OR pregnancy[tw] OR pregnant[tw] OR “pregnant women”[MeSH]) | 792595 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 and #4 and #5) | 5 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 and #4 and #5) Filters: Humans | 4 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 and #4 and #5) Filters: Other Animals | 3 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#8 NOT #7) | 1 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#6 NOT #9) | 4 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)

## 11/10/14 PubMed Benefits Search

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((Pregnancy[MeSH] OR pregnancy[tw] OR pregnant[tw] OR “pregnant women”[MeSH])) | 797377 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“folic acid”[MeSH] OR “vitamin b9”[tw] OR “vitamin m”[tw] or “Pteroylglutamic Acid”[tw] OR “folvite”[tw] OR “folacin”[tw] OR “folate”[tw] OR “folic acid”[tw] OR “5-Me-THF” OR “5-Me-H4F” OR “5-methyltetrahydrofolate” OR “5-methyltetrahydropteroylpentaglutamate”[Supplementary Concept] OR “5-methyltetrahydrofolate triglutamate”[Supplementary Concept]) | 47728 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((multivitamin[all fields] OR “prenatal vitamin”[all fields] OR multivitamins[all fields] OR “prenatal vitamins”[all fields] OR “vitamin supplement”[all fields] OR “vitamin supplements”[all fields])) | 4245 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“neural tube defects”[MeSH Terms] OR “spina bifida”[All Fields] OR “neural tube damage”[All Fields] OR “neural tube defect”[All Fields] OR “neural tube defects”[All Fields] OR “neural tube disorders”[All Fields] OR “Neural tube defect, folate-sensitive”[Supplementary Concept] OR Craniorachischisis[tw] OR Craniorachischises[tw] OR Diastematomyelia[tw] OR Diastematomyelias[tw] OR “Tethered Cord Syndrome”[tw] OR “Tethered Cord Syndromes”[tw] OR “Occult Spinal Dysraphism Sequence”[tw] OR “Tethered Spinal Cord Syndrome”[tw] OR “Occult Spinal Dysraphism”[tw] OR “Occult Spinal Dysraphisms”[tw] OR Iniencephaly[tw] OR Iniencephalies[tw] OR “Neurenteric Cyst”[tw] OR “Neurenteric Cysts”[tw] OR “Neuroenteric Cyst”[tw] OR “Neuroenteric Cysts”[tw] OR “Spinal Cord Myelodysplasia”[tw] OR “Spinal Cord Myelodysplasias”[tw] OR Acrania[tw] OR Acranias[tw] OR Exencephaly[tw] OR Exencephalies[tw])) | 27869 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#1 AND (#2 OR #3) AND #4)) | 1821 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#1 AND (#2 OR #3) AND #4)) Filters: Humans | 1647 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#1 AND (#2 OR #3) AND #4)) Filters: Other Animals | 207 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#7 NOT #6)) | 97 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 NOT #8) | 1724 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“retraction”[All Fields] OR “Retracted Publication”[pt] OR Duplicate Publication [PT] OR Erratum[All Fields]) | 28946 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#9 and #10) | 1 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 NOT #8) Filters: Publication date from 2013/06/23 | 88 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)

## 3/24/15 PubMed Benefits Search

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (Pregnancy[MeSH] OR pregnancy[tw] OR pregnant[tw] OR “pregnant women”[MeSH]) | 807095 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“folic acid”[MeSH] OR “vitamin b9”[tw] OR “vitamin m”[tw] or “Pteroylglutamic Acid”[tw] OR “folvite”[tw] OR “folacin”[tw] OR “folate”[tw] OR “folic acid”[tw] OR “5-Me-THF” OR “5-Me-H4F” OR “5-methyltetrahydrofolate” OR “5-methyltetrahydropteroylpentaglutamate”[Supplementary Concept] OR “5-methyltetrahydrofolate triglutamate”[Supplementary Concept]) | 48429 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (multivitamin[all fields] OR “prenatal vitamin”[all fields] OR multivitamins[all fields] OR “prenatal vitamins”[all fields] OR “vitamin supplement”[all fields] OR “vitamin supplements”[all fields]) | 4335 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“neural tube defects”[MeSH Terms] OR “spina bifida”[All Fields] OR “neural tube damage”[All Fields] OR “neural tube defect”[All Fields] OR “neural tube defects”[All Fields] OR “neural tube disorders”[All Fields] OR “Neural tube defect, folate-sensitive”[Supplementary Concept] OR Craniorachischisis[tw] OR Craniorachischises[tw] OR Diastematomyelia[tw] OR Diastematomyelias[tw] OR “Tethered Cord Syndrome”[tw] OR “Tethered Cord Syndromes”[tw] OR “Occult Spinal Dysraphism Sequence”[tw] OR “Tethered Spinal Cord Syndrome”[tw] OR “Occult Spinal Dysraphism”[tw] OR “Occult Spinal Dysraphisms”[tw] OR Iniencephaly[tw] OR Iniencephalies[tw] OR “Neurenteric Cyst”[tw] OR “Neurenteric Cysts”[tw] OR “Neuroenteric Cyst”[tw] OR “Neuroenteric Cysts”[tw] OR “Spinal Cord Myelodysplasia”[tw] OR “Spinal Cord Myelodysplasias”[tw] OR Acrania[tw] OR Acranias[tw] OR Exencephaly[tw] OR Exencephalies[tw]) | 28158 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#1 AND (#2 OR #3) AND #4)) | 1855 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#1 AND (#2 OR #3) AND #4)) Filters: Humans | 1669 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#1 AND (#2 OR #3) AND #4)) Filters: Other Animals | 211 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 not #6) | 99 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 not #8) | 1756 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“retraction”[All Fields] OR “Retracted Publication”[pt] OR Duplicate Publication [PT] OR Erratum[All Fields]) | 30021 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#9 and #10) | 1 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 not #8) Filters: Publication date from 2014/05/10 | 55 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)

## 7/27/15 PubMed Benefits Search

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (Pregnancy[MeSH] OR pregnancy[tw] OR pregnant[tw] OR “pregnant women”[MeSH]) | 817957 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“folic acid”[MeSH] OR “vitamin b9”[tw] OR “vitamin m”[tw] or “Pteroylglutamic Acid”[tw] OR “folvite”[tw] OR “folacin”[tw] OR “folate”[tw] OR “folic acid”[tw] OR “5-Me-THF” OR “5-Me-H4F” OR “5-methyltetrahydrofolate” OR “5-methyltetrahydropteroylpentaglutamate”[Supplementary Concept] OR “5-methyltetrahydrofolate triglutamate”[Supplementary Concept]) | 49245 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (multivitamin[all fields] OR “prenatal vitamin”[all fields] OR multivitamins[all fields] OR “prenatal vitamins”[all fields] OR “vitamin supplement”[all fields] OR “vitamin supplements”[all fields]) | 4431 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“neural tube defects”[MeSH Terms] OR “spina bifida”[All Fields] OR “neural tube damage”[All Fields] OR “neural tube defect”[All Fields] OR “neural tube defects”[All Fields] OR “neural tube disorders”[All Fields] OR “Neural tube defect, folate-sensitive”[Supplementary Concept] OR Craniorachischisis[tw] OR Craniorachischises[tw] OR Diastematomyelia[tw] OR Diastematomyelias[tw] OR “Tethered Cord Syndrome”[tw] OR “Tethered Cord Syndromes”[tw] OR “Occult Spinal Dysraphism Sequence”[tw] OR “Tethered Spinal Cord Syndrome”[tw] OR “Occult Spinal Dysraphism”[tw] OR “Occult Spinal Dysraphisms”[tw] OR Iniencephaly[tw] OR Iniencephalies[tw] OR “Neurenteric Cyst”[tw] OR “Neurenteric Cysts”[tw] OR “Neuroenteric Cyst”[tw] OR “Neuroenteric Cysts”[tw] OR “Spinal Cord Myelodysplasia”[tw] OR “Spinal Cord Myelodysplasias”[tw] OR Acrania[tw] OR Acranias[tw] OR Exencephaly[tw] OR Exencephalies[tw]) | 28482 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND (#2 OR #3) AND #4) | 1880 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND (#2 OR #3) AND #4) Filters: Humans | 1685 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND (#2 OR #3) AND #4) Filters: Other Animals | 213 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 NOT #6) | 100 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 NOT #8) | 1780 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“retraction”[All Fields] OR “Retracted Publication”[pt] OR Duplicate Publication [PT] OR Erratum[All Fields]) | 34641 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#9 and #10) Retraction Search | 1 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 NOT #8) Filters: Publication date from 2014/10/24 | 49 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)

## 11/18/15 PubMed Benefits Search

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (Pregnancy[MeSH] OR pregnancy[tw] OR pregnant[tw] OR “pregnant women”[MeSH]) | 826665 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“folic acid”[MeSH] OR “vitamin b9”[tw] OR “vitamin m”[tw] or “Pteroylglutamic Acid”[tw] OR “folvite”[tw] OR “folacin”[tw] OR “folate”[tw] OR “folic acid”[tw] OR “5-Me-THF” OR “5-Me-H4F” OR “5-methyltetrahydrofolate” OR “5-methyltetrahydropteroylpentaglutamate”[Supplementary Concept] OR “5-methyltetrahydrofolate triglutamate”[Supplementary Concept])) | 49896 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (multivitamin[all fields] OR “prenatal vitamin”[all fields] OR multivitamins[all fields] OR “prenatal vitamins”[all fields] OR “vitamin supplement”[all fields] OR “vitamin supplements”[all fields]) | 4490 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“neural tube defects”[MeSH Terms] OR “spina bifida”[All Fields] OR “neural tube damage”[All Fields] OR “neural tube defect”[All Fields] OR “neural tube defects”[All Fields] OR “neural tube disorders”[All Fields] OR “Neural tube defect, folate-sensitive”[Supplementary Concept] OR Craniorachischisis[tw] OR Craniorachischises[tw] OR Diastematomyelia[tw] OR Diastematomyelias[tw] OR “Tethered Cord Syndrome”[tw] OR “Tethered Cord Syndromes”[tw] OR “Occult Spinal Dysraphism Sequence”[tw] OR “Tethered Spinal Cord Syndrome”[tw] OR “Occult Spinal Dysraphism”[tw] OR “Occult Spinal Dysraphisms”[tw] OR Iniencephaly[tw] OR Iniencephalies[tw] OR “Neurenteric Cyst”[tw] OR “Neurenteric Cysts”[tw] OR “Neuroenteric Cyst”[tw] OR “Neuroenteric Cysts”[tw] OR “Spinal Cord Myelodysplasia”[tw] OR “Spinal Cord Myelodysplasias”[tw] OR Acrania[tw] OR Acranias[tw] OR Exencephaly[tw] OR Exencephalies[tw]) | 28752 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND (#2 OR #3) AND #4) | 1906 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND (#2 OR #3) AND #4) Filters: Humans | 1707 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND (#2 OR #3) AND #4) Filters: Other Animals | 213 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 NOT #6) | 100 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 NOT #8) | 1806 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“retraction”[All Fields] OR “Retracted Publication”[pt] OR Duplicate Publication [PT] OR Erratum[All Fields]) | 38379 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#9 and #10) Retraction | 1 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 NOT #8) Filters: Publication date from 2015/02/27 | 48 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)

## 1/28/16 PubMed Benefits Search

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (Pregnancy[MeSH] OR pregnancy[tw] OR pregnant[tw] OR “pregnant women”[MeSH]) | 854509 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“folic acid”[MeSH] OR “vitamin b9”[tw] OR “vitamin m”[tw] or “Pteroylglutamic Acid”[tw] OR “folvite”[tw] OR “folacin”[tw] OR “folate”[tw] OR “folic acid”[tw] OR “5-Me-THF” OR “5-Me-H4F” OR “5-methyltetrahydrofolate” OR “5-methyltetrahydropteroylpentaglutamate”[Supplementary Concept] OR “5-methyltetrahydrofolate triglutamate”[Supplementary Concept]))) | 51191 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((multivitamin[all fields] OR “prenatal vitamin”[all fields] OR multivitamins[all fields] OR “prenatal vitamins”[all fields] OR “vitamin supplement”[all fields] OR “vitamin supplements”[all fields])) | 4536 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“neural tube defects”[MeSH Terms] OR “spina bifida”[All Fields] OR “neural tube damage”[All Fields] OR “neural tube defect”[All Fields] OR “neural tube defects”[All Fields] OR “neural tube disorders”[All Fields] OR “Neural tube defect, folate-sensitive”[Supplementary Concept] OR Craniorachischisis[tw] OR Craniorachischises[tw] OR Diastematomyelia[tw] OR Diastematomyelias[tw] OR “Tethered Cord Syndrome”[tw] OR “Tethered Cord Syndromes”[tw] OR “Occult Spinal Dysraphism Sequence”[tw] OR “Tethered Spinal Cord Syndrome”[tw] OR “Occult Spinal Dysraphism”[tw] OR “Occult Spinal Dysraphisms”[tw] OR Iniencephaly[tw] OR Iniencephalies[tw] OR “Neurenteric Cyst”[tw] OR “Neurenteric Cysts”[tw] OR “Neuroenteric Cyst”[tw] OR “Neuroenteric Cysts”[tw] OR “Spinal Cord Myelodysplasia”[tw] OR “Spinal Cord Myelodysplasias”[tw] OR Acrania[tw] OR Acranias[tw] OR Exencephaly[tw] OR Exencephalies[tw])) | 29292 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#1 AND (#2 OR #3) AND #4)) | 1923 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#1 AND (#2 OR #3) AND #4)) Filters: Humans | 1715 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#1 AND (#2 OR #3) AND #4)) Filters: Other Animals | 216 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#7 NOT #6)) | 103 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#5 NOT #8)) | 1820 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“retraction”[All Fields] OR “Retracted Publication”[pt] OR Duplicate Publication [PT] OR Erratum[All Fields])) | 40500 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#9 and #10)) | 1 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#5 NOT #8)) Filters: Publication date from 2015/10/18 | 22 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)

## 9/9/14 PubMed Harms Search

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “folic acid”[mesh] OR “folic acid”[tiab] OR “folvite”[tiab] OR “folacin”[tiab] OR 5-Me-THF OR 5-Me-H4F OR 5-methyltetrahydrofolate OR “5-methyltetrahydropteroylpentaglutamate” [Supplementary Concept] OR “5-methyltetrahydrofolate triglutamate” [Supplementary Concept] | 35919 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (Pregnancy[MeSH] OR pregnancy[tw] OR pregnant[tw] OR “pregnant women”[MeSH]) | 792843 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #2) | 5060 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Colorectal Neoplasms”[Mesh] OR (“Vitamin B 12 Deficiency”[Mesh] OR (“vitamin b 12”[MeSH Terms] AND deficien^*^[Text Word])) OR (“Vitamin B 6 Deficiency”[Mesh] OR (“vitamin b 6”[MeSH Terms] AND deficien^*^[Text Word])) OR (“Drug-Related Side Effects and Adverse Reactions”[Majr] OR “Patient Harm”[Majr] harm[tiab] OR harms[tiab] OR “adverse effect”[tiab] OR “adverse effects”[tiab] OR “adverse event”[tiab] OR “adverse events”[tiab] OR complication[tiab] OR complications[tiab])) | 941528 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 and #4) | 681 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 and #4) Filters: Humans | 586 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 and #4) Filters: Other Animals | 90 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 not #6) | 47 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#5 not #8) | 634 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)

## 11/11/14 PubMed Harms Search

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“folic acid”[mesh] OR “folic acid”[tiab] OR “folvite”[tiab] OR “folacin”[tiab] OR 5-Me-THF OR 5-Me-H4F OR 5-methyltetrahydrofolate OR “5-methyltetrahydropteroylpentaglutamate” [Supplementary Concept] OR “5-methyltetrahydrofolate triglutamate” [Supplementary Concept]) | 36189 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (Pregnancy[MeSH] OR pregnancy[tw] OR pregnant[tw] OR “pregnant women”[MeSH]) | 797435 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #2) | 5102 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Colorectal Neoplasms”[Mesh] OR (“Vitamin B 12 Deficiency”[Mesh] OR (“vitamin b 12”[MeSH Terms] AND deficien^*^[Text Word])) OR “Vitamin B 6 Deficiency”[Mesh] OR (“vitamin b 6”[MeSH Terms] AND deficien^*^[Text Word]) OR “Drug-Related Side Effects and Adverse Reactions”[Majr] OR “Patient Harm”[Majr] harm[tiab] OR harms[tiab] OR “adverse effect”[tiab] OR “adverse effects”[tiab] OR “adverse event”[tiab] OR “adverse events”[tiab] OR complication[tiab] OR complications[tiab] | 952237 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#3 and #4)) | 689 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #5 Filters: Humans | 592 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #5 | 689 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #5 Filters: Other Animals | 93 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 NOT #6) | 49 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 NOT #9) | 640 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 NOT #9) Filters: Publication date from 2013/09/09 | 30 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 | Search (“retraction”[All Fields] OR “Retracted Publication”[pt] OR Duplicate Publication [PT] OR Erratum[All Fields]) | 28984
#13 | Search (#5 and #12) | 2

## 1/6/15 PubMed Harms Addendum Search

Search | Query | Items found
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “folic acid”[mesh] OR “folic acid”[tiab] OR “folvite”[tiab] OR “folacin”[tiab] OR 5-Me-THF OR 5-Me-H4F OR 5-methyltetrahydrofolate OR “5-methyltetrahydropteroylpentaglutamate” [Supplementary Concept] OR “5-methyltetrahydrofolate triglutamate” [Supplementary Concept] | 36405 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((Pregnancy[MeSH] OR pregnancy[tw] OR pregnant[tw] OR “pregnant women”[MeSH])) | 801618 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#4 and #5) | 5145 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Twins”[mesh] OR “Pregnancy, Twin”[mesh] OR twinning OR twins) | 39869 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#6 and #7) | 57 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((“Colorectal Neoplasms”[Mesh] OR (“Vitamin B 12 Deficiency”[Mesh] OR (“vitamin b 12”[MeSH Terms] AND deficien^*^[Text Word])) OR (“Vitamin B 6 Deficiency”[Mesh] OR (“vitamin b 6”[MeSH Terms] AND deficien^*^[Text Word])) OR (“Drug-Related Side Effects and Adverse Reactions”[Majr] OR “Patient Harm”[Majr] harm[tiab] OR harms[tiab] OR “adverse effect”[tiab] OR “adverse effects”[tiab] OR “adverse event”[tiab] OR “adverse events”[tiab] OR complication[tiab] OR complications[tiab]))) | 962466 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#8 NOT #9) | 47 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#8 NOT #9) Filters: Humans | 46 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#8 NOT #9) Filters: Other Animals | 4 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#12 NOT #11) | 0 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#10 NOT #13) | 47 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)

## 3/24/15 and 3/27/15 PubMed Harms Search

Search | Query | Items found
#23 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“folic acid”[mesh] OR “folic acid”[tiab] OR “folvite”[tiab] OR “folacin”[tiab] OR 5-Me-THF OR 5-Me-H4F OR 5-methyltetrahydrofolate OR “5-methyltetrahydropteroylpentaglutamate” [Supplementary Concept] OR “5-methyltetrahydrofolate triglutamate” [Supplementary Concept]) | 36728 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (Pregnancy[MeSH] OR pregnancy[tw] OR pregnant[tw] OR “pregnant women”[MeSH]) | 807095 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#25 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#23 and #24) | 5210 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)
#26 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Colorectal Neoplasms”[Mesh] OR (“Vitamin B 12 Deficiency”[Mesh] OR (“vitamin b 12”[MeSH Terms] AND deficien^*^[Text Word])) OR “Vitamin B 6 Deficiency”[Mesh] OR (“vitamin b 6”[MeSH Terms] AND deficien^*^[Text Word]) OR “Drug-Related Side Effects and Adverse Reactions”[Majr] OR “Patient Harm”[Majr] harm[tiab] OR harms[tiab] OR “adverse effect”[tiab] OR “adverse effects”[tiab] OR “adverse event”[tiab] OR “adverse events”[tiab] OR complication[tiab] OR complications[tiab]) | 821329 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=26)
#27 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#25 and #26) | 332 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=27)
#28 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#25 and #26) Filters: Humans | 284 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=28)
#29 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#25 and #26) Filters: Other Animals | 42 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#30 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#29 not #28) | 21 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=30)
#31 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#27 not #30) | 311 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=31)
#32 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#27 not #30) Filters: Publication date from 2014/05/10 | 11 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=32)
#33 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“retraction”[All Fields] OR “Retracted Publication”[pt] OR Duplicate Publication [PT] OR Erratum[All Fields]) | 30021 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=33)
#34 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#27 and #33) | 0 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=34)

## 6/10/15 PubMed Harms Addendum Search

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((Pregnancy[MeSH] OR pregnancy[tw] OR pregnant[tw] OR “pregnant women”[MeSH])) | 813856 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((“folic acid”[mesh] OR “folic acid”[tiab] OR “folvite”[tiab] OR “folacin”[tiab] OR 5-Me-THF OR 5-Me-H4F OR 5-methyltetrahydrofolate OR “5-methyltetrahydropteroylpentaglutamate” [Supplementary Concept] OR “5-methyltetrahydrofolate triglutamate” [Supplementary Concept])) | 37102 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 and #2) | 5261 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Asthma”[Mesh] | 107710 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search asthma | 150552 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#4 or #5) | 150552 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “adverse effects” [Subheading] | 1765128 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 and #6) | 22 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 and #7) | 779 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#8 or #9) | 788 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#8 or #9) Filters: Humans | 671 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#8 or #9) Filters: Other Animals | 195 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#12 not #11) | 114 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#10 not #13) | 674 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((“Colorectal Neoplasms”[Mesh] OR (“Vitamin B 12 Deficiency”[Mesh] OR (“vitamin b 12”[MeSH Terms] AND deficien^*^[Text Word])) OR (“Vitamin B 6 Deficiency”[Mesh] OR (“vitamin b 6”[MeSH Terms] AND deficien^*^[Text Word])) OR (“Drug-Related Side Effects and Adverse Reactions”[Majr] OR “Patient Harm”[Majr] harm[tiab] OR harms[tiab] OR “adverse effect”[tiab] OR “adverse effects”[tiab] OR “adverse event”[tiab] OR “adverse events”[tiab] OR complication[tiab] OR complications[tiab]) | 992424 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#14 NOT #15) | 562 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)

## 7/27/15 PubMed Harms Search

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“folic acid”[mesh] OR “folic acid”[tiab] OR “folvite”[tiab] OR “folacin”[tiab] OR 5-Me-THF OR 5-Me-H4F OR 5-methyltetrahydrofolate OR “5-methyltetrahydropteroylpentaglutamate” [Supplementary Concept] OR “5-methyltetrahydrofolate triglutamate” [Supplementary Concept]) | 37694 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (Pregnancy[MeSH] OR pregnancy[tw] OR pregnant[tw] OR “pregnant women”[MeSH]) | 817957 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #2) | 5319 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Colorectal Neoplasms”[Mesh] OR (“Vitamin B 12 Deficiency”[Mesh] OR (“vitamin b 12”[MeSH Terms] AND deficien^*^[Text Word])) OR (“Vitamin B 6 Deficiency”[Mesh] OR (“vitamin b 6”[MeSH Terms] AND deficien^*^[Text Word])) OR (“Drug-Related Side Effects and Adverse Reactions”[Majr] OR “Patient Harm”[Majr] OR harm[tiab] OR harms[tiab] OR “adverse effects” [Subheading] OR “adverse effect”[tiab] OR “adverse effects”[tiab] OR “adverse event”[tiab] OR “adverse events”[tiab] OR complication[tiab] OR complications[tiab]) OR “Twins”[mesh] OR “Pregnancy, Twin”[mesh] OR twinning OR twins OR asthma[Mesh] OR asthma)) | 2779068 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 and #4) | 1499 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 and #4) Filters: Humans | 1228 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 and #4) Filters: Other Animals | 271 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 NOT #6) | 158 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 NOT #8) | 1341 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 NOT #8) Filters: Publication date from 2014/07/06 | 40 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“retraction”[All Fields] OR “Retracted Publication”[pt] OR Duplicate Publication [PT] OR Erratum[All Fields]) | 34641
#12 | Search (#5 and #11) Retractions | 2

## 11/18/15 PubMed Harms Search

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“folic acid”[mesh] OR “folic acid”[tiab] OR “folvite”[tiab] OR “folacin”[tiab] OR 5-Me-THF OR 5-Me-H4F OR 5-methyltetrahydrofolate OR “5-methyltetrahydropteroylpentaglutamate” [Supplementary Concept] OR “5-methyltetrahydrofolate triglutamate” [Supplementary Concept]) | 38183 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (Pregnancy[MeSH] OR pregnancy[tw] OR pregnant[tw] OR “pregnant women”[MeSH]) | 826665 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 and #2) | 5404 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Colorectal Neoplasms”[Mesh] OR (“Vitamin B 12 Deficiency”[Mesh] OR (“vitamin b 12”[MeSH Terms] AND deficien^*^[Text Word])) OR (“Vitamin B 6 Deficiency”[Mesh] OR (“vitamin b 6”[MeSH Terms] AND deficien^*^[Text Word])) OR (“Drug-Related Side Effects and Adverse Reactions”[Majr] OR “Patient Harm”[Majr] OR harm[tiab] OR harms[tiab] OR “adverse effects” [Subheading] OR “adverse effect”[tiab] OR “adverse effects”[tiab] OR “adverse event”[tiab] OR “adverse events”[tiab] OR complication[tiab] OR complications[tiab]) OR “Twins”[mesh] OR “Pregnancy, Twin”[mesh] OR twinning OR twins OR asthma[Mesh] OR asthma)) | 2822126 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 and #4) | 1522 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 and #4) Filters: Humans | 1243 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 and #4) Filters: Other Animals | 275 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 NOT #6) | 161 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 not #8) | 1361 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 not #8) Filters: Publication date from 2015/02/27 | 23 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“retraction”[All Fields] OR “Retracted Publication”[pt] OR Duplicate Publication [PT] OR Erratum[All Fields]) | 38379 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 and #11) | 2 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)

## 1/28/16 PubMed Harms Search

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((“folic acid”[mesh] OR “folic acid”[tiab] OR “folvite”[tiab] OR “folacin”[tiab] OR 5-Me-THF OR 5-Me-H4F OR 5-methyltetrahydrofolate OR “5-methyltetrahydropteroylpentaglutamate” [Supplementary Concept] OR “5-methyltetrahydrofolate triglutamate” [Supplementary Concept])) | 39456 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((Pregnancy[MeSH] OR pregnancy[tw] OR pregnant[tw] OR “pregnant women”[MeSH])) | 854509 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((#1 and #2)) | 5507 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (((“Colorectal Neoplasms”[Mesh] OR (“Vitamin B 12 Deficiency”[Mesh] OR (“vitamin b 12”[MeSH Terms] AND deficien^*^[Text Word])) OR (“Vitamin B 6 Deficiency”[Mesh] OR (“vitamin b 6”[MeSH Terms] AND deficien^*^[Text Word])) OR (“Drug-Related Side Effects and Adverse Reactions”[Majr] OR “Patient Harm”[Majr] OR harm[tiab] OR harms[tiab] OR “adverse effects” [Subheading] OR “adverse effect”[tiab] OR “adverse effects”[tiab] OR “adverse event”[tiab] OR “adverse events”[tiab] OR complication[tiab] OR complications[tiab]) OR “Twins”[mesh] OR “Pregnancy, Twin”[mesh] OR twinning OR twins OR asthma[Mesh] OR asthma))) | 2852040 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((#3 and #4)) | 1545 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((#3 and #4)) Filters: Humans | 1324 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((#3 and #4)) Filters: Other Animals | 279 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((#7 NOT #6)) | 164 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((#5 not #8)) | 1381 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((#5 not #8)) Filters: Publication date from 2015/10/18 | 10 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((“retraction”[All Fields] OR “Retracted Publication”[pt] OR Duplicate Publication [PT] OR Erratum[All Fields])) | 40500 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((#5 and #11)) | 2 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)

## 6/23/14 Cochrane Benefits Search

Search | Query | Items found
#1 | [mh Pregnancy] OR pregnancy OR pregnant OR [mh “pregnant women”] | 27927
#2 | [mh “folic acid”] OR “vitamin b9” OR “vitamin m” or “Pteroylglutamic Acid” OR “folvite” OR “folacin” OR “folate” OR “folic acid” | 3775
#3 | Multivitamin OR “prenatal vitamin” OR multivitamins OR “prenatal vitamins” OR “vitamin supplement” OR “vitamin supplements” | 915
#4 | [mh “neural tube defects”] OR “spina bifida” OR “neural tube damage” OR “neural tube defect” OR “neural tube defects” OR “neural tube disorders” OR “Neural tube defect, folate-sensitive” OR Craniorachischisis OR Craniorachischises OR Diastematomyelia OR Diastematomyelias OR “Tethered Cord Syndrome” OR “Tethered Cord Syndromes” OR “Occult Spinal Dysraphism Sequence” OR “Tethered Spinal Cord Syndrome” OR “Occult Spinal Dysraphism” OR “Occult Spinal Dysraphisms” OR Iniencephaly OR Iniencephalies OR “Neurenteric Cyst” OR “Neurenteric Cysts” OR “Neuroenteric Cyst” OR “Neuroenteric Cysts” OR “Spinal Cord Myelodysplasia” OR “Spinal Cord Myelodysplasias” OR Acrania OR Acranias OR Exencephaly OR Exencephalies | 374
#5 | Search (#1 AND (#2 OR #3) AND #4) | 105

## 9/4/14 Cochrane Benefits Addendum Search

ID | Search | Hits
#1 | 5-Me-THF or 5-Me-H4F or 5-methyltetrahydrofolate or 5-methyltetrahydropteroylpentaglutamate or “5-methyltetrahydrofolate triglutamate” | 96
#2 | [mh “folic acid”] or “vitamin b9” or “vitamin m” or “Pteroylglutamic Acid” or “folvite” or “folacin” or “folate” or “folic acid” or Multivitamin or “prenatal vitamin” or multivitamins or “prenatal vitamins” or “vitamin supplement” or “vitamin supplements” | 4467
#3 | #1 not #2 | 16
#4 | [mh Pregnancy] or pregnancy or pregnant or [mh “pregnant women”] | 28255
#5 | #3 and #4 | 2
#6 | [mh “neural tube defects”] or “spina bifida” or “neural tube damage” or “neural tube defect” or “neural tube defects” or “neural tube disorders” or “Neural tube defect, folate-sensitive” or Craniorachischisis or Craniorachischises or Diastematomyelia or Diastematomyelias or “Tethered Cord Syndrome” or “Tethered Cord Syndromes” or “Occult Spinal Dysraphism Sequence” or “Tethered Spinal Cord Syndrome” or “Occult Spinal Dysraphism” or “Occult Spinal Dysraphisms” or Iniencephaly or Iniencephalies or “Neurenteric Cyst” or “Neurenteric Cysts” or “Neuroenteric Cyst” or “Neuroenteric Cysts” or “Spinal Cord Myelodysplasia” or “Spinal Cord Myelodysplasias” or Acrania or Acranias or Exencephaly or Exencephalies | 376
#7 | #5 and #6 | 0

## 11/11/14 Cochrane Benefits Search

ID | Search | Hits
#1 | [mh Pregnancy] or pregnancy or pregnant or [mh “pregnant women”] | 29122
#2 | [mh “folic acid”] or “vitamin b9” or “vitamin m” or “Pteroylglutamic Acid” or “folvite” or “folacin” or “folate” or “folic acid” or 5-Me-THF or 5-Me-H4F or 5-methyltetrahydrofolate | 3909
#3 | Multivitamin or “prenatal vitamin” or multivitamins or “prenatal vitamins” or “vitamin supplement” or “vitamin supplements” | 944
#4 | [mh “neural tube defects”] or “spina bifida” or “neural tube damage” or “neural tube defect” or “neural tube defects” or “neural tube disorders” or “Neural tube defect, folate-sensitive” or Craniorachischisis or Craniorachischises or Diastematomyelia or Diastematomyelias or “Tethered Cord Syndrome” or “Tethered Cord Syndromes” or “Occult Spinal Dysraphism Sequence” or “Tethered Spinal Cord Syndrome” or “Occult Spinal Dysraphism” or “Occult Spinal Dysraphisms” or Iniencephaly or Iniencephalies or “Neurenteric Cyst” or “Neurenteric Cysts” or “Neuroenteric Cyst” or “Neuroenteric Cysts” or “Spinal Cord Myelodysplasia” or “Spinal Cord Myelodysplasias” or Acrania or Acranias or Exencephaly or Exencephalies | 383
#5 | (#1 and (#2 or #3) and #4) | 108
# 6 | (#1 and (#2 or #3) and #4) Publication Year from 2013 to 2014 | 16

## 3/24/15 Cochrane Benefits Search

ID | Search | Hits
#1 | [mh Pregnancy] or pregnancy or pregnant or [mh “pregnant women”] | 29687
#2 | [mh “folic acid”] or “vitamin b9” or “vitamin m” or “Pteroylglutamic Acid” or “folvite” or “folacin” or “folate” or “folic acid” or 5-Me-THF or 5-Me-H4F or 5-methyltetrahydrofolate | 4051
#3 | Multivitamin or “prenatal vitamin” or multivitamins or “prenatal vitamins” or “vitamin supplement” or “vitamin supplements” | 988
#4 | [mh “neural tube defects”] or “spina bifida” or “neural tube damage” or “neural tube defect” or “neural tube defects” or “neural tube disorders” or “Neural tube defect, folate-sensitive” or Craniorachischisis or Craniorachischises or Diastematomyelia or Diastematomyelias or “Tethered Cord Syndrome” or “Tethered Cord Syndromes” or “Occult Spinal Dysraphism Sequence” or “Tethered Spinal Cord Syndrome” or “Occult Spinal Dysraphism” or “Occult Spinal Dysraphisms” or Iniencephaly or Iniencephalies or “Neurenteric Cyst” or “Neurenteric Cysts” or “Neuroenteric Cyst” or “Neuroenteric Cysts” or “Spinal Cord Myelodysplasia” or “Spinal Cord Myelodysplasias” or Acrania or Acranias or Exencephaly or Exencephalies | 392
#5 | (#1 and (#2 or #3) and #4) | 108
#6 | (#1 and (#2 or #3) and #4) Publication Year from 2014 to 2015 | 8

## 7/27/15 Cochrane Benefits Search

ID | Search | Hits
#1 | [mh Pregnancy] or pregnancy or pregnant or [mh “pregnant women”] | 30805
#2 | [mh “folic acid”] or “vitamin b9” or “vitamin m” or “Pteroylglutamic Acid” or “folvite” or “folacin” or “folate” or “folic acid” or 5-Me-THF or 5-Me-H4F or 5-methyltetrahydrofolate 4051 | 4253
#3 | Multivitamin or “prenatal vitamin” or multivitamins or “prenatal vitamins” or “vitamin supplement” or “vitamin supplements” | 1065
#4 | [mh “neural tube defects”] or “spina bifida” or “neural tube damage” or “neural tube defect” or “neural tube defects” or “neural tube disorders” or “Neural tube defect, folate-sensitive” or Craniorachischisis or Craniorachischises or Diastematomyelia or Diastematomyelias or “Tethered Cord Syndrome” or “Tethered Cord Syndromes” or “Occult Spinal Dysraphism Sequence” or “Tethered Spinal Cord Syndrome” or “Occult Spinal Dysraphism” or “Occult Spinal Dysraphisms” or Iniencephaly or Iniencephalies or “Neurenteric Cyst” or “Neurenteric Cysts” or “Neuroenteric Cyst” or “Neuroenteric Cysts” or “Spinal Cord Myelodysplasia” or “Spinal Cord Myelodysplasias” or Acrania or Acranias or Exencephaly or Exencephalies | 408
#5 | (#1 and (#2 or #3) and #4) | 115
#6 | (#1 and (#2 or #3) and #4) Publication Year from 2014 to 2015 | 13

## 11/18/15 Cochrane Benefits Search

ID | Search | Hits
#1 | [mh Pregnancy] or pregnancy or pregnant or [mh “pregnant women”] | 31487
#2 | [mh “folic acid”] or “vitamin b9” or “vitamin m” or “Pteroylglutamic Acid” or “folvite” or “folacin” or “folate” or “folic acid” or 5-Me-THF or 5-Me-H4F or 5-methyltetrahydrofolate 4051 | 4353
#3 | Multivitamin or “prenatal vitamin” or multivitamins or “prenatal vitamins” or “vitamin supplement” or “vitamin supplements” | 1098
#4 | [mh “neural tube defects”] or “spina bifida” or “neural tube damage” or “neural tube defect” or “neural tube defects” or “neural tube disorders” or “Neural tube defect, folate-sensitive” or Craniorachischisis or Craniorachischises or Diastematomyelia or Diastematomyelias or “Tethered Cord Syndrome” or “Tethered Cord Syndromes” or “Occult Spinal Dysraphism Sequence” or “Tethered Spinal Cord Syndrome” or “Occult Spinal Dysraphism” or “Occult Spinal Dysraphisms” or Iniencephaly or Iniencephalies or “Neurenteric Cyst” or “Neurenteric Cysts” or “Neuroenteric Cyst” or “Neuroenteric Cysts” or “Spinal Cord Myelodysplasia” or “Spinal Cord Myelodysplasias” or Acrania or Acranias or Exencephaly or Exencephalies | 411
#5 | (#1 and (#2 or #3) and #4) Publication Year from 2014 to 2015 | 16

## 1/28/16 Cochrane Benefits Search

ID | Search | Hits
#1 | [mh Pregnancy] or pregnancy or pregnant or [mh “pregnant women”] | 32013
#2 | [mh “folic acid”] or “vitamin b9” or “vitamin m” or “Pteroylglutamic Acid” or “folvite” or “folacin” or “folate” or “folic acid” or 5-Me-THF or 5-Me-H4F or 5-methyltetrahydrofolate 4051 | 4403
#3 | Multivitamin or “prenatal vitamin” or multivitamins or “prenatal vitamins” or “vitamin supplement” or “vitamin supplements” | 1115
#4 | [mh “neural tube defects”] or “spina bifida” or “neural tube damage” or “neural tube defect” or “neural tube defects” or “neural tube disorders” or “Neural tube defect, folate-sensitive” or Craniorachischisis or Craniorachischises or Diastematomyelia or Diastematomyelias or “Tethered Cord Syndrome” or “Tethered Cord Syndromes” or “Occult Spinal Dysraphism Sequence” or “Tethered Spinal Cord Syndrome” or “Occult Spinal Dysraphism” or “Occult Spinal Dysraphisms” or Iniencephaly or Iniencephalies or “Neurenteric Cyst” or “Neurenteric Cysts” or “Neuroenteric Cyst” or “Neuroenteric Cysts” or “Spinal Cord Myelodysplasia” or “Spinal Cord Myelodysplasias” or Acrania or Acranias or Exencephaly or Exencephalies | 414
#5 | (#1 and (#2 or #3) and #4) Online Publication Date from Oct 2015 | 5

## 9/9/14 Cochrane Harms Search

ID | Search Terms | Hits
#1 | [mh “folic acid”] or “folic acid” or folvite or folacin 5-Me-THF or 5-Me-H4F or 5-methyltetrahydrofolate or “5-methyltetrahydropteroylpentaglutamate” or “5-methyltetrahydrofolate triglutamate” | 3438
#2 | [mh Pregnancy] or pregnancy or pregnant or [mh “pregnant women”] | 28256
#3 | #1 and #2 | 579
#4 | [mh Twins] or [mh “Pregnancy, Twin”] or twinning or twins or [mh “Colorectal Neoplasms”] or ([mh “Vitamin B 12 Deficiency”] or ([mh “vitamin b 12”] and deficien^*^)) or ([mh “Vitamin B 6 Deficiency”] or ([mh “vitamin b 6”] and deficien^*^)) or ([mh “Drug-Related Side Effects and Adverse Reactions” [mj]] or [mh “Patient Harm” [mj]] or harm or harms or “adverse effect” or “adverse effects” or “adverse event” or “adverse events” or complication or complications) | 217992
#5 | #3 and #4 | 330

## 11/11/14 Cochrane Harms Search

ID | Search | Hits
#1 | [mh “folic acid”] or “folic acid” or folvite or folacin 5-Me-THF or 5-Me-H4F or 5-methyltetrahydrofolate or “5-methyltetrahydropteroylpentaglutamate” or “5-methyltetrahydrofolate triglutamate” | 3511
#2 | [mh Pregnancy] or pregnancy or pregnant or [mh “pregnant women”] | 29122
#3 | #1 and #2 | 598
#4 | [mh Twins] or [mh “Pregnancy, Twin”] or twinning or twins or [mh “Colorectal Neoplasms”] or ([mh “Vitamin B 12 Deficiency”] or ([mh “vitamin b 12”] and deficien^*^)) or ([mh “Vitamin B 6 Deficiency”] or ([mh “vitamin b 6”] and deficien^*^)) or ([mh “Drug-Related Side Effects and Adverse Reactions” [mj]] or [mh “Patient Harm” [mj]] or harm or harms or “adverse effect” or “adverse effects” or “adverse event” or “adverse events” or complication or complications) | 221497
#5 | #3 and #4 | 338
#6 | #3 and #4 Publication Year from 2013 to 2014 | 65

## 3/24/15 Cochrane Harms Search

ID | Search | Hits
#1 | [mh “folic acid”] or “folic acid” or folvite or folacin 5-Me-THF or 5-Me-H4F or 5-methyltetrahydrofolate or “5-methyltetrahydropteroylpentaglutamate” or “5-methyltetrahydrofolate triglutamate” | 3650
#2 | [mh Pregnancy] or pregnancy or pregnant or [mh “pregnant women”] | 29687
#3 | #1 and #2 | 627
#4 | [mh Twins] or [mh “Pregnancy, Twin”] or twinning or twins or [mh “Colorectal Neoplasms”] or ([mh “Vitamin B 12 Deficiency”] or ([mh “vitamin b 12”] and deficien^*^)) or ([mh “Vitamin B 6 Deficiency”] or ([mh “vitamin b 6”] and deficien^*^)) or ([mh “Drug-Related Side Effects and Adverse Reactions” [mj]] or [mh “Patient Harm” [mj]] or harm or harms or “adverse effect” or “adverse effects” or “adverse event” or “adverse events” or complication or complications) | 228315
#5 | #3 and #4 | 338
#6 | #3 and #4 Publication Year from 2014 to 2015 | 41

## 6/10/15 Cochrane Harms Addendum Search

ID | Search | Hits
#1 | [mh “folic acid”] or “folic acid” or folvite or folacin 5-Me-THF or 5-Me-H4F or 5-methyltetrahydrofolate or “5-methyltetrahydropteroylpentaglutamate” or “5-methyltetrahydrofolate triglutamate” | 3752
#2 | [mh Pregnancy] or pregnancy or pregnant or [mh “pregnant women”] | 30578
#3 | #1 and #2 | 649
#4 | asthma | 24345
#5 | #3 and #4 | 22
#6 | [mh /AE] | 105460
#7 | #3 and #6 | 73
#8 | #5 or #7 | 84
#9 | [mh Twins] or [mh “Pregnancy, Twin”] or twinning or twins or [mh “Colorectal Neoplasms”] or ([mh “Vitamin B 12 Deficiency”] or ([mh “vitamin b 12”] and deficien^*^)) or ([mh “Vitamin B 6 Deficiency”] or ([mh “vitamin b 6”] and deficien^*^)) or ([mh “Drug-Related Side Effects and Adverse Reactions” [mj]] or [mh “Patient Harm” [mj]] or harm or harms or “adverse effect” or “adverse effects” or “adverse event” or “adverse events” or complication or complications) | 234745
#10 | #8 not #9 | 0

## 7/27/15 Cochrane Harms Search

ID | Search | Hits
#1 | [mh “folic acid”] or “folic acid” or folvite or folacin 5-Me-THF or 5-Me-H4F or 5-methyltetrahydrofolate or “5-methyltetrahydropteroylpentaglutamate” or “5-methyltetrahydrofolate triglutamate” | 3867
#2 | [mh Pregnancy] or pregnancy or pregnant or [mh “pregnant women”] | 30805
#3 | #1 and #2 | 676
#4 | [mh Twins] or [mh “Pregnancy, Twin”] or twinning or twins or [mh “Colorectal Neoplasms”] or ([mh “Vitamin B 12 Deficiency”] or ([mh “vitamin b 12”] and deficien^*^)) or ([mh “Vitamin B 6 Deficiency”] or ([mh “vitamin b 6”] and deficien^*^)) or ([mh “Drug-Related Side Effects and Adverse Reactions” [mj]] or [mh “Patient Harm” [mj]] or harm or harms or [mh /AE] or “adverse effect” or “adverse effects” or “adverse event” or “adverse events” or complication or complications or [mh Asthma] or asthma) | 256428
#5 | #3 and #4 | 366
#6 | #3 and #4 Publication Year from 2014 to 2015 | 56

## 11/18/15 Cochrane Harms Search

ID | Search | Hits
#1 | [mh “folic acid”] or “folic acid” or folvite or folacin 5-Me-THF or 5-Me-H4F or 5-methyltetrahydrofolate or “5-methyltetrahydropteroylpentaglutamate” or “5-methyltetrahydrofolate triglutamate” | 3962
#2 | [mh Pregnancy] or pregnancy or pregnant or [mh “pregnant women”] | 31487
#3 | #1 and #2 | 710
#4 | [mh Twins] or [mh “Pregnancy, Twin”] or twinning or twins or [mh “Colorectal Neoplasms”] or ([mh “Vitamin B 12 Deficiency”] or ([mh “vitamin b 12”] and deficien^*^)) or ([mh “Vitamin B 6 Deficiency”] or ([mh “vitamin b 6”] and deficien^*^)) or ([mh “Drug-Related Side Effects and Adverse Reactions” [mj]] or [mh “Patient Harm” [mj]] or harm or harms or [mh /AE] or “adverse effect” or “adverse effects” or “adverse event” or “adverse events” or complication or complications or [mh Asthma] or asthma) | 261297
#5 | #3 and #4 Publication Year from 2015 to 2015 | 44

## 1/28/16 Cochrane Harms Search

#1 | [mh “folic acid”] or “folic acid” or folvite or folacin 5-Me-THF or 5-Me-H4F or 5-methyltetrahydrofolate or “5-methyltetrahydropteroylpentaglutamate” or “5-methyltetrahydrofolate triglutamate” | 4011
#2 | [mh Pregnancy] or pregnancy or pregnant or [mh “pregnant women”] | 32013
#3 | #1 and #2 | 722
#4 | [mh Twins] or [mh “Pregnancy, Twin”] or twinning or twins or [mh “Colorectal Neoplasms”] or ([mh “Vitamin B 12 Deficiency”] or ([mh “vitamin b 12”] and deficien^*^)) or ([mh “Vitamin B 6 Deficiency”] or ([mh “vitamin b 6”] and deficien^*^)) or ([mh “Drug-Related Side Effects and Adverse Reactions” [mj]] or [mh “Patient Harm” [mj]] or harm or harms or [mh /AE] or “adverse effect” or “adverse effects” or “adverse event” or “adverse events” or complication or complications or [mh Asthma] or asthma) | 263974
#5 | #3 and #4 Online Publication Date from Oct 2015 | 16

## 6/23/14 EMBASE Benefits Search

No. | Query | Results
#11 | #9 NOT #10 | 543 (http://www.embase.com/search/results?viewsearch=11)
#10 | #9 AND [medline]/lim | 1,373 (http://www.embase.com/search/results?viewsearch=10)
#9 | #5 NOT #8 | 1,916 (http://www.embase.com/search/results?viewsearch=9)
#8 | #7 NOT #6 AND [animals]/lim | 77 (http://www.embase.com/search/results?viewsearch=8)
#7 | #5 AND [animals]/lim | 343 (http://www.embase.com/search/results?viewsearch=7)
#6 | #5 AND [humans]/lim | 1,832 (http://www.embase.com/search/results?viewsearch=6)
#5 | #1 AND (#2 OR #3) AND #4 | 1,993 (http://www.embase.com/search/results?viewsearch=5)
#4 | ‘spinal dysraphism’/exp OR ‘spinal dysraphism’ OR ‘neural tube damage’ OR ‘neural tube defect’/exp OR ‘neural tube defect’ OR ‘neural tube defects’/exp OR ‘neural tube defects’ OR ‘neural tube disorders’ OR ‘neural tube defect, folate-sensitive’ OR craniorachischisis OR craniorachischises OR ‘diastematomyelia’/exp OR diastematomyelia OR diastematomyelias OR ‘tethered cord syndrome’/exp OR ‘tethered cord syndrome’ OR ‘tethered cord syndromes’ OR ‘occult spinal dysraphism sequence’ OR ‘tethered spinal cord syndrome’ OR ‘occult spinal dysraphism’/exp OR ‘occult spinal dysraphism’ OR ‘occult spinal dysraphisms’ OR ‘iniencephaly’/exp OR iniencephaly OR iniencephalies OR ‘neurenteric cyst’ OR ‘neurenteric cysts’ OR ‘neuroenteric cyst’ OR ‘neuroenteric cysts’ OR ‘spinal cord myelodysplasia’ OR ‘spinal cord myelodysplasias’ OR acrania OR acranias OR ‘exencephaly’/exp OR exencephaly OR exencephalies | 30,718 (http://www.embase.com/search/results?viewsearch=4)
#3 | ‘multivitamin’/exp OR multivitamin OR ‘prenatal vitamin’ OR ‘multivitamins’/exp OR multivitamins OR ‘prenatal vitamins’ OR ‘vitamin supplement’ OR ‘vitamin supplements’ | 8,726 (http://www.embase.com/search/results?viewsearch=3)
#2 | ‘vitamin b9’ OR ‘vitamin m’/exp OR ‘vitamin m’ OR ‘pteroylglutamic acid’/exp OR ‘pteroylglutamic acid’ OR ‘folvite’/exp OR ‘folvite’ OR ‘folacin’/exp OR ‘folacin’ OR ‘folate’/exp OR ‘folate’ OR ‘folic acid’/exp OR ‘folic acid’ | 59,344 (http://www.embase.com/search/results?viewsearch=2)
#1 | ‘pregnancy’/exp OR ‘pregnant women’/exp OR ‘pregnancy’/de OR pregnant | 648,650 (http://www.embase.com/search/results?viewsearch=1)

## 9/8/14 EMBASE Benefits Addendum Search

No. | Query | Results
#7 | #5 AND #6 | 0
#6 | ‘spinal dysraphism’/exp OR ‘spinal dysraphism’ OR ‘neural tube damage’ OR ‘neural tube defect’/exp OR ‘neural tube defect’ OR ‘neural tube defects’/exp OR ‘neural tube defects’ OR ‘neural tube disorders’ OR ‘neural tube defect, folate-sensitive’ OR craniorachischisis OR craniorachischises OR ‘diastematomyelia’/exp OR diastematomyelia OR diastematomyelias OR ‘tethered cord syndrome’/exp OR ‘tethered cord syndrome’ OR ‘tethered cord syndromes’ OR ‘occult spinal dysraphism sequence’ OR ‘tethered spinal cord syndrome’ OR ‘occult spinal dysraphism’/exp OR ‘occult spinal dysraphism’ OR ‘occult spinal dysraphisms’ OR ‘iniencephaly’/exp OR iniencephaly OR iniencephalies OR ‘neurenteric cyst’ OR ‘neurenteric cysts’ OR ‘neuroenteric cyst’ OR ‘neuroenteric cysts’ OR ‘spinal cord myelodysplasia’ OR ‘spinal cord myelodysplasias’ OR acrania OR acranias OR ‘exencephaly’/exp OR exencephaly OR exencephalies | 31,029
#5 | #3 AND #4 | 11
#4 | ‘pregnancy’/exp OR ‘pregnant women’/exp OR ‘pregnancy’/de OR pregnant | 655,680
#3 | #1 NOT #2 | 379
#2 | ‘vitamin b9’ OR ‘vitamin m’/exp OR ‘vitamin m’ OR ‘pteroylglutamic acid’/exp OR ‘pteroylglutamic acid’ OR ‘folvite’/exp OR ‘folvite’ OR ‘folacin’/exp OR ‘folacin’ OR ‘folate’/exp OR ‘folate’ OR ‘folic acid’/exp OR ‘folic acid’ OR ‘multivitamin’/exp OR multivitamin OR ‘prenatal vitamin’ OR ‘multivitamins’/exp OR multivitamins OR ‘prenatal vitamins’ OR ‘vitamin supplement’ OR ‘vitamin supplements’ | 66,754
#1 | ‘5 me thf’ OR ‘5 me h4f’ OR ‘5 methyltetrahydrofolate’ OR ‘5 methyltetrahydropteroylpentaglutamate’ OR ‘5-methyltetrahydrofolate triglutamate’ | 1,429

## 3/24/15 EMBASE Benefits Search

No. | Query | Results
#11 | #9 NOT #10 | 70
#10 | #9 AND [medline]/lim | 41
#9 | #8 AND [2014-2015]/py | 111
#8 | #4 NOT #7 | 2,394
#7 | #6 NOT #5 | 101
#6 | #4 AND [animals]/lim | 423
#5 | #4 AND [humans]/lim | 2,288
#4 | #1 AND #2 AND #3 | 2,495
#3 | ‘spinal dysraphism’/exp OR ‘spinal dysraphism’ OR ‘neural tube damage’ OR ‘neural tube defect’/exp OR ‘neural tube defect’ OR ‘neural tube defects’/exp OR ‘neural tube defects’ OR ‘neural tube disorders’ OR ‘neural tube defect, folate-sensitive’ OR craniorachischisis OR craniorachischises OR ‘diastematomyelia’/exp OR diastematomyelia OR diastematomyelias OR ‘tethered cord syndrome’/exp OR ‘tethered cord syndrome’ OR ‘tethered cord syndromes’ OR ‘occult spinal dysraphism sequence’ OR ‘tethered spinal cord syndrome’ OR ‘occult spinal dysraphism’/exp OR ‘occult spinal dysraphism’ OR ‘occult spinal dysraphisms’ OR ‘iniencephaly’/exp OR iniencephaly OR iniencephalies OR ‘neurenteric cyst’ OR ‘neurenteric cysts’ OR ‘neuroenteric cyst’ OR ‘neuroenteric cysts’ OR ‘spinal cord myelodysplasia’ OR ‘spinal cord myelodysplasias’ OR acrania OR acranias OR ‘exencephaly’/exp OR exencephaly OR exencephalies | 31,662
#2 | ‘vitamin b9’ OR ‘vitamin m’/exp OR ‘vitamin m’ OR ‘pteroylglutamic acid’/exp OR ‘pteroylglutamic acid’ OR ‘folvite’/exp OR ‘folvite’ OR ‘folacin’/exp OR ‘folacin’ OR ‘folate’/exp OR ‘folate’ OR ‘folic acid’/exp OR ‘folic acid’ OR ‘multivitamin’/exp OR multivitamin OR ‘prenatal vitamin’ OR ‘multivitamins’/exp OR multivitamins OR ‘prenatal vitamins’ OR ‘vitamin supplement’ OR ‘vitamin supplements’ OR ‘5 me thf’ OR ‘5 me h4f’ OR ‘5 methyltetrahydrofolate’ OR ‘5 methyltetrahydropteroylpentaglutamate’ OR ‘5-methyltetrahydrofolate triglutamate’ | 69,216
#1 | ‘pregnant women’/exp OR ‘pregnant women’ OR ‘pregnancy’/exp OR ‘pregnancy’ OR pregnant | 784,028

## 7/27/15 EMBASE Benefits Search

#9 | #8 AND [24-10-2014]/sd NOT [27-7-2015]/sd | 95 (http://www.embase.com/)
#8 | #4 NOT #7 | 2,456 (http://www.embase.com/)
#7 | #6 NOT #5 | 95 (http://www.embase.com/)
#6 | #4 AND [animals]/lim | 172 (http://www.embase.com/)
#5 | #4 AND [humans]/lim | 2,340 (http://www.embase.com/)
#4 | #1 AND #2 AND #3 | 2,551 (http://www.embase.com/)
#3 | ‘spinal dysraphism’/exp OR ‘spinal dysraphism’ OR ‘neural tube damage’ OR ‘neural tube defect’/exp OR ‘neural tube defect’ OR ‘neural tube defects’/exp OR ‘neural tube defects’ OR ‘neural tube disorders’ OR ‘neural tube defect, folate-sensitive’ OR craniorachischisis OR craniorachischises OR ‘diastematomyelia’/exp OR diastematomyelia OR diastematomyelias OR ‘tethered cord syndrome’/exp OR ‘tethered cord syndrome’ OR ‘tethered cord syndromes’ OR ‘occult spinal dysraphism sequence’ OR ‘tethered spinal cord syndrome’ OR ‘occult spinal dysraphism’/exp OR ‘occult spinal dysraphism’ OR ‘occult spinal dysraphisms’ OR ‘iniencephaly’/exp OR iniencephaly OR iniencephalies OR ‘neurenteric cyst’ OR ‘neurenteric cysts’ OR ‘neuroenteric cyst’ OR ‘neuroenteric cysts’ OR ‘spinal cord myelodysplasia’ OR ‘spinal cord myelodysplasias’ OR acrania OR acranias OR ‘exencephaly’/exp OR exencephaly OR exencephalies | 32,319 (http://www.embase.com/)
#2 | ‘vitamin b9’ OR ‘vitamin m’/exp OR ‘vitamin m’ OR ‘pteroylglutamic acid’/exp OR ‘pteroylglutamic acid’ OR ‘folvite’/exp OR ‘folvite’ OR ‘folacin’/exp OR ‘folacin’ OR ‘folate’/exp OR ‘folate’ OR ‘folic acid’/exp OR ‘folic acid’ OR ‘multivitamin’/exp OR multivitamin OR ‘prenatal vitamin’ OR ‘multivitamins’/exp OR multivitamins OR ‘prenatal vitamins’ OR ‘vitamin supplement’ OR ‘vitamin supplements’ OR ‘5 me thf’ OR ‘5 me h4f’ OR ‘5 methyltetrahydrofolate’ OR ‘5 methyltetrahydropteroylpentaglutamate’ OR ‘5-methyltetrahydrofolate triglutamate’ | 71,041 (http://www.embase.com/)
#1 | ‘pregnant women’/exp OR ‘pregnant women’ OR ‘pregnancy’/exp OR ‘pregnancy’ OR pregnant | 802,358 (http://www.embase.com/)

## 11/18/15 EMBASE Benefits Search

#9 | #8 AND [27-2-2015]/sd NOT [18-11-2015]/sd | 108 (http://www.embase.com/)
#8 | #4 NOT #7 | 2,500 (http://www.embase.com/)
#7 | #6 NOT #5 | 97 (http://www.embase.com/)
#6 | #4 AND [animals]/lim | 176 (http://www.embase.com/)
#5 | #4 AND [humans]/lim | 2,384 (http://www.embase.com/)
#4 | #1 AND #2 AND #3 | 2,597 (http://www.embase.com/)
#3 | ‘spinal dysraphism’/exp OR ‘spinal dysraphism’ OR ‘neural tube damage’ OR ‘neural tube defect’/exp OR ‘neural tube defect’ OR ‘neural tube defects’/exp OR ‘neural tube defects’ OR ‘neural tube disorders’ OR ‘neural tube defect, folate-sensitive’ OR craniorachischisis OR craniorachischises OR ‘diastematomyelia’ OR ‘diastematomyelia’/exp OR diastematomyelia OR diastematomyelias OR ‘tethered cord syndrome’/exp OR ‘tethered cord syndrome’ OR ‘tethered cord syndromes’ OR ‘occult spinal dysraphism sequence’ OR ‘tethered spinal cord syndrome’ OR ‘occult spinal dysraphism’/exp OR ‘occult spinal dysraphism’ OR ‘occult spinal dysraphisms’ OR ‘iniencephaly’ OR ‘iniencephaly’/exp OR iniencephaly OR iniencephalies OR ‘neurenteric cyst’ OR ‘neurenteric cysts’ OR ‘neuroenteric cyst’ OR ‘neuroenteric cysts’ OR ‘spinal cord myelodysplasia’ OR ‘spinal cord myelodysplasias’ OR acrania OR acranias OR ‘exencephaly’ OR ‘exencephaly’/exp OR exencephaly OR exencephalies | 32,708 (http://www.embase.com/)
#2 | ‘vitamin b9’ OR ‘vitamin m’/exp OR ‘vitamin m’ OR ‘pteroylglutamic acid’/exp OR ‘pteroylglutamic acid’ OR ‘folvite’/exp OR ‘folvite’ OR ‘folacin’/exp OR ‘folacin’ OR ‘folate’/exp OR ‘folate’ OR ‘folic acid’/exp OR ‘folic acid’ OR ‘multivitamin’ OR ‘multivitamin’/exp OR multivitamin OR ‘prenatal vitamin’ OR ‘multivitamins’ OR ‘multivitamins’/exp OR multivitamins OR ‘prenatal vitamins’ OR ‘vitamin supplement’ OR ‘vitamin supplements’ OR ‘5 me thf’ OR ‘5 me h4f’ OR ‘5 methyltetrahydrofolate’/exp OR ‘5 methyltetrahydrofolate’ OR ‘5 methyltetrahydropteroylpentaglutamate’ OR ‘5-methyltetrahydrofolate triglutamate’ | 72,556 (http://www.embase.com/)
#1 | ‘pregnant women’/exp OR ‘pregnant women’ OR ‘pregnancy’/exp OR ‘pregnancy’ OR pregnant | 816,404 (http://www.embase.com/)

## 1/28/16 EMBASE Benefits Search

#9 | #8 AND [18-10-2015]/sd | 23 (http://www.embase.com/)
#8 | #4 NOT #7 | 23 (http://www.embase.com/)
#7 | #6 NOT #5 | 2,512 (http://www.embase.com/)
#6 | #4 AND [animals]/lim | 98 (http://www.embase.com/)
#5 | #4 AND [humans]/lim | 177 (http://www.embase.com/)
#4 | #1 AND #2 AND #3 | 2,396 (http://www.embase.com/)
#3 | ‘spinal dysraphism’/exp OR ‘spinal dysraphism’ OR ‘neural tube damage’ OR ‘neural tube defect’/exp OR ‘neural tube defect’ OR ‘neural tube defects’/exp OR ‘neural tube defects’ OR ‘neural tube disorders’ OR ‘neural tube defect, folate-sensitive’ OR craniorachischisis OR craniorachischises OR ‘diastematomyelia’ OR ‘diastematomyelia’/exp OR diastematomyelia OR diastematomyelias OR ‘tethered cord syndrome’/exp OR ‘tethered cord syndrome’ OR ‘tethered cord syndromes’ OR ‘occult spinal dysraphism sequence’ OR ‘tethered spinal cord syndrome’ OR ‘occult spinal dysraphism’/exp OR ‘occult spinal dysraphism’ OR ‘occult spinal dysraphisms’ OR ‘iniencephaly’ OR ‘iniencephaly’/exp OR iniencephaly OR iniencephalies OR ‘neurenteric cyst’ OR ‘neurenteric cysts’ OR ‘neuroenteric cyst’ OR ‘neuroenteric cysts’ OR ‘spinal cord myelodysplasia’ OR ‘spinal cord myelodysplasias’ OR acrania OR acranias OR ‘exencephaly’ OR ‘exencephaly’/exp OR exencephaly OR exencephalies | 2,610 (http://www.embase.com/)
#2 | ‘vitamin b9’ OR ‘vitamin m’/exp OR ‘vitamin m’ OR ‘pteroylglutamic acid’/exp OR ‘pteroylglutamic acid’ OR ‘folvite’/exp OR ‘folvite’ OR ‘folacin’/exp OR ‘folacin’ OR ‘folate’/exp OR ‘folate’ OR ‘folic acid’/exp OR ‘folic acid’ OR ‘multivitamin’ OR ‘multivitamin’/exp OR multivitamin OR ‘prenatal vitamin’ OR ‘multivitamins’ OR ‘multivitamins’/exp OR multivitamins OR ‘prenatal vitamins’ OR ‘vitamin supplement’ OR ‘vitamin supplements’ OR ‘5 me thf’ OR ‘5 me h4f’ OR ‘5 methyltetrahydrofolate’/exp OR ‘5 methyltetrahydrofolate’ OR ‘5 methyltetrahydropteroylpentaglutamate’ OR ‘5-methyltetrahydrofolate triglutamate’ | 32,949 (http://www.embase.com/)
#1 | ‘pregnant women’/exp OR ‘pregnant women’ OR ‘pregnancy’/exp OR ‘pregnancy’ OR pregnant | 73,279 (http://www.embase.com/)

## 9/9/14 EMBASE Harms Search

No. | Query | Results
#11 | #9 NOT #10 | 517
#10 | #9 AND [medline]/lim | 1,422
#9 | #5 NOT #8 | 1,939
#8 | #7 NOT #6 | 75
#7 | #5 AND [animals]/lim | 316
#6 | #5 AND [humans]/lim | 1,777
#5 | #3 AND #4 | 2,014
#4 | ‘colorectal tumor’/exp OR ‘cyanocobalamin deficiency’/exp OR (b12 AND deficien^*^) OR ‘pyridoxine deficiency’/exp OR (b6 AND deficien^*^) OR ‘adverse drug reaction’/exp/mj OR ‘patient harm’/exp/mj OR harm OR harms OR ‘adverse effect’ OR ‘adverse effects’ OR ‘adverse event’ OR ‘adverse events’ OR complication OR complications | 2,688,524
#3 | #1 AND #2 | 6,768
#2 | ‘pregnancy’/exp OR ‘pregnant women’/exp OR ‘pregnancy’/de OR pregnant | 655,686
#1 | ‘folic acid’/exp OR ‘folic acid’:ti OR ‘folic acid’:ab OR folvite:ti OR folvite:ab OR folacin:ti OR folacin:ab OR ‘5 me thf’ OR ‘5 me h4f’ OR ‘5 methyltetrahydrofolate’ OR ‘5 methyltetrahydropteroylpentaglutamate’ OR ‘5-methyltetrahydrofolate triglutamate’ | 49,006

## 11/11/14 EMBASE Harms Search

No. | Query | Results
#11 | #9 NOT #10 | 128
#10 | #9 AND [medline]/lim | 100
#9 | #8 AND [2013-2014]/py | 228
#8 | #4 NOT #7 | 2,362
#7 | #6 NOT #5 | 97
#6 | #4 AND [animals]/lim | 420
#5 | #4 AND [humans]/lim | 2,257
#4 | #1 AND #2 AND #3 | 2,459
#3 | ‘spinal dysraphism’/exp OR ‘spinal dysraphism’ OR ‘neural tube damage’ OR ‘neural tube defect’/exp OR ‘neural tube defect’ OR ‘neural tube defects’/exp OR ‘neural tube defects’ OR ‘neural tube disorders’ OR ‘neural tube defect, folate-sensitive’ OR craniorachischisis OR craniorachischises OR ‘diastematomyelia’/exp OR diastematomyelia OR diastematomyelias OR ‘tethered cord syndrome’/exp OR ‘tethered cord syndrome’ OR ‘tethered cord syndromes’ OR ‘occult spinal dysraphism sequence’ OR ‘tethered spinal cord syndrome’ OR ‘occult spinal dysraphism’/exp OR ‘occult spinal dysraphism’ OR ‘occult spinal dysraphisms’ OR ‘iniencephaly’/exp OR iniencephaly OR iniencephalies OR ‘neurenteric cyst’ OR ‘neurenteric cysts’ OR ‘neuroenteric cyst’ OR ‘neuroenteric cysts’ OR ‘spinal cord myelodysplasia’ OR ‘spinal cord myelodysplasias’ OR acrania OR acranias OR ‘exencephaly’/exp OR exencephaly OR exencephalies | 31,173
#2 | ‘vitamin b9’ OR ‘vitamin m’/exp OR ‘vitamin m’ OR ‘pteroylglutamic acid’/exp OR ‘pteroylglutamic acid’ OR ‘folvite’/exp OR ‘folvite’ OR ‘folacin’/exp OR ‘folacin’ OR ‘folate’/exp OR ‘folate’ OR ‘folic acid’/exp OR ‘folic acid’ OR ‘multivitamin’/exp OR multivitamin OR ‘prenatal vitamin’ OR ‘multivitamins’/exp OR multivitamins OR ‘prenatal vitamins’ OR ‘vitamin supplement’ OR ‘vitamin supplements’ OR ‘5 me thf’ OR ‘5 me h4f’ OR ‘5 methyltetrahydrofolate’ OR ‘5 methyltetrahydropteroylpentaglutamate’ OR ‘5-methyltetrahydrofolate triglutamate’ | 67,655
#1 | ‘pregnant women’/exp OR ‘pregnant women’ OR ‘pregnancy’/exp OR ‘pregnancy’ OR pregnant | 769,699

## 11/11/14 EMBASE Harms Search

No. | Query | Results
#12 | #9 NOT #10 AND [2013-2014]/py | 142
#11 | #9 NOT #10 | 522
#10 | #9 AND [medline]/lim | 1,431
#9 | #5 NOT #8 | 1,953
#8 | #7 NOT #6 | 75
#7 | #5 AND [animals]/lim | 320
#6 | #5 AND [humans]/lim | 1,791
#5 | #3 AND #4 | 2,028
#4 | ‘colorectal tumor’/exp OR ‘cyanocobalamin deficiency’/exp OR (b12 AND deficien^*^) OR ‘pyridoxine deficiency’/exp OR (b6 AND deficien^*^) OR ‘adverse drug reaction’/exp/mj OR ‘patient harm’/exp/mj OR harm OR harms OR ‘adverse effect’ OR ‘adverse effects’ OR ‘adverse event’ OR ‘adverse events’ OR complication OR complications | 2,711,985
#3 | #1 AND #2 | 6,816
#2 | ‘pregnancy’/exp OR ‘pregnant women’/exp OR ‘pregnancy’/de OR pregnant | 660,630
#1 | ‘folic acid’/exp OR ‘folic acid’:ti OR ‘folic acid’:ab OR folvite:ti OR folvite:ab OR folacin:ti OR folacin:ab OR ‘5 me thf’ OR ‘5 me h4f’ OR ‘5 methyltetrahydrofolate’ OR ‘5 methyltetrahydropteroylpentaglutamate’ OR ‘5-methyltetrahydrofolate triglutamate’ | 49,375

## 3/24/15 EMBASE Harms Search

No. | Query | Results
#12 | #9 NOT #10 AND [2014-2015]/py | 77
#11 | #9 NOT #10 | 551
#10 | #9 AND [medline]/lim | 1,446
#9 | #5 NOT #8 | 1,997
#8 | #7 NOT #6 | 76
#7 | #5 AND [animals]/lim | 328
#6 | #5 AND [humans]/lim | 1,835
#5 | #3 AND #4 | 2,073
#4 | ‘colorectal tumor’/exp OR ‘cyanocobalamin deficiency’/exp OR (b12 AND deficien^*^) OR ‘pyridoxine deficiency’/exp OR (b6 AND deficien^*^) OR ‘adverse drug reaction’/exp/mj OR ‘patient harm’/exp/mj OR harm OR harms OR ‘adverse effect’ OR ‘adverse effects’ OR ‘adverse event’ OR ‘adverse events’ OR complication OR complications | 2,778,112
#3 | #1 AND #2 | 6,984
#2 | ‘pregnancy’/exp OR ‘pregnant women’/exp OR ‘pregnancy’/de OR pregnant | 673,619
#1 | ‘folic acid’/exp OR ‘folic acid’:ti OR ‘folic acid’:ab OR folvite:ti OR folvite:ab OR folacin:ti OR folacin:ab OR ‘5 me thf’ OR ‘5 me h4f’ OR ‘5 methyltetrahydrofolate’ OR ‘5 methyltetrahydropteroylpentaglutamate’ OR ‘5-methyltetrahydrofolate triglutamate’ | 50,573

## 6/10/15 EMBASE Harms Addendum Search

No. | Query | Results
#12 | #10 NOT #11 | 164 (http://www.embase.com/)
#11 | #8 NOT #9 AND [medline]/lim | 379 (http://www.embase.com/)
#10 | #8 NOT #9 | 543 (http://www.embase.com/)
#9 | ‘colorectal tumor’/exp OR ‘cyanocobalamin deficiency’/exp OR (b12 AND deficien^*^) OR ‘pyridoxine deficiency’/exp OR (b6 AND deficien^*^) OR ‘adverse drug reaction’/exp/mj OR ‘patient harm’/exp/mj OR harm OR harms OR ‘adverse effect’ OR ‘adverse effects’ OR ‘adverse event’ OR ‘adverse events’ OR complication OR complications | 2,826,063 (http://www.embase.com/)
#8 | #5 OR #7 | 1,016 (http://www.embase.com/)
#7 | #3 AND #6 | 949 (http://www.embase.com/)
#6 | ‘adverse drug reaction’/exp OR ‘adverse drug reaction’ | 1,320,972 (http://www.embase.com/)
#5 | #3 AND #4 | 95 (http://www.embase.com/)
#4 | ‘asthma’ OR ‘asthma’/exp OR asthma | 238,789 (http://www.embase.com/)
#3 | #1 AND #2 | 7,124 (http://www.embase.com/)
#2 | ‘pregnancy’/exp OR ‘pregnant women’/exp OR ‘pregnancy’/de OR pregnant | 682,899 (http://www.embase.com/)
#1 | ‘folic acid’/exp OR ‘folic acid’:ti OR ‘folic acid’:ab OR folvite:ti OR folvite:ab OR folacin:ti OR folacin:ab OR ‘5 me thf’ OR ‘5 me h4f’ OR ‘5 methyltetrahydrofolate’ OR ‘5 methyltetrahydropteroylpentaglutamate’ OR ‘5-methyltetrahydrofolate triglutamate’ | 51,450 (http://www.embase.com/)

## 7/27/15 EMBASE Harms Search

No. | Query | Results
#12 | #11 AND [6-7-2014]/sd NOT [27-7-2015]/sd | 116 (http://www.embase.com/)
#11 | #7 NOT #10 | 827 (http://www.embase.com/)
#10 | #9 NOT #8 | 25 (http://www.embase.com/)
#9 | #7 AND [animals]/lim | 65 (http://www.embase.com/)
#8 | #7 AND [humans]/lim | 730 (http://www.embase.com/)
#7 | #5 NOT #6 | 852 (http://www.embase.com/)
#6 | #5 AND [medline]/lim | 2,191 (http://www.embase.com/)
#5 | #3 AND #4 | 3,043 (http://www.embase.com/)
#4 | ‘colorectal tumor’/exp OR ‘cyanocobalamin deficiency’/exp OR (b12 AND deficien^*^) OR ‘pyridoxine deficiency’/exp OR (b6 AND deficien^*^) OR ‘adverse drug reaction’/exp/mj OR ‘patient harm’/exp/mj OR harm OR harms OR ‘adverse drug reaction’/exp OR ‘adverse drug reaction’ OR ‘adverse effect’ OR ‘adverse effects’ OR ‘adverse event’ OR ‘adverse events’ OR complication OR complications OR ‘twin pregnancy’/exp OR ‘twins’/exp OR twin OR twins OR twinning OR ‘asthma’/exp OR asthma | 3,903,874 (http://www.embase.com/)
#3 | #1 AND #2 | 7,683 (http://www.embase.com/)
#2 | ‘pregnancy’/exp OR ‘pregnant women’/exp OR ‘pregnancy’/de OR pregnant | 687,384 (http://www.embase.com/)
#1 | ‘folic acid’/exp OR ‘folic acid’ OR ‘folic acid’:ti OR ‘folic acid’:ab OR folvite:ti OR folvite:ab OR folacin:ti OR folacin:ab OR ‘5 me thf’ OR ‘5 me h4f’ OR ‘5 methyltetrahydrofolate’/exp OR ‘5 methyltetrahydrofolate’ OR ‘5 methyltetrahydropteroylpentaglutamate’ OR ‘5-methyltetrahydrofolate triglutamate’ | 52,898

## 11/18/15 EMBASE Harms Search

No. | Query | Results
#12 | #11 AND [27-2-2015]/sd NOT [18-11-2015]/sd | 95
#11 | #7 NOT #10 | 853
#10 | #9 NOT #8 | 25
#9 | #7 AND [animals]/lim | 65
#8 | #7 AND [humans]/lim | 755
#7 | #5 NOT #6 | 878
#6 | #5 AND [medline]/lim | 2,210
#5 | #3 AND #4 | 3,088
#4 | ‘colorectal tumor’/exp OR ‘cyanocobalamin deficiency’/exp OR (b12 AND deficien^*^) OR ‘pyridoxine deficiency’/exp OR (b6 AND deficien^*^) OR ‘adverse drug reaction’/exp/mj OR ‘patient harm’/exp/mj OR harm OR harms OR ‘adverse drug reaction’/exp OR ‘adverse drug reaction’ OR ‘adverse effect’ OR ‘adverse effects’ OR ‘adverse event’ OR ‘adverse events’ OR complication OR complications OR ‘twin pregnancy’/exp OR ‘twins’/exp OR twin OR twins OR twinning OR ‘asthma’/exp OR asthma | 3,976,920
#3 | #1 AND #2 | 7,857
#2 | ‘pregnancy’/exp OR ‘pregnant women’/exp OR ‘pregnancy’/de OR pregnant | 698,517
#1 | ‘folic acid’/exp OR ‘folic acid’ OR ‘folic acid’:ti OR ‘folic acid’:ab OR folvite:ti OR folvite:ab OR folacin:ti OR folacin:ab OR ‘5 me thf’ OR ‘5 me h4f’ OR ‘5 methyltetrahydrofolate’/exp OR ‘5 methyltetrahydrofolate’ OR ‘5 methyltetrahydropteroylpentaglutamate’ OR ‘5-methyltetrahydrofolate triglutamate’ | 59,181

## 1/28/16 EMBASE Harms Search

No. | Query | Results
#12 | #11 AND [18-10-2015]/sd | 27
#11 | #7 NOT #10 | 866
#10 | #9 NOT #8 | 25
#9 | #7 AND [animals]/lim | 65
#8 | #7 AND [humans]/lim | 767
#7 | #5 NOT #6 | 891
#6 | #5 AND [medline]/lim | 2,217
#5 | #3 AND #4 | 3,108
#4 | ‘colorectal tumor’/exp OR ‘cyanocobalamin deficiency’/exp OR (b12 AND deficien^*^) OR ‘pyridoxine deficiency’/exp OR (b6 AND deficien^*^) OR ‘adverse drug reaction’/exp/mj OR ‘patient harm’/exp/mj OR harm OR harms OR ‘adverse drug reaction’/exp OR ‘adverse drug reaction’ OR ‘adverse effect’ OR ‘adverse effects’ OR ‘adverse event’ OR ‘adverse events’ OR complication OR complications OR ‘twin pregnancy’/exp OR ‘twins’/exp OR twin OR twins OR twinning OR ‘asthma’/exp OR asthma | 4,017,311
#3 | #1 AND #2 | 7,935
#2 | ‘pregnancy’/exp OR ‘pregnant women’/exp OR ‘pregnancy’/de OR pregnant | 705,446
#1 | ‘folic acid’/exp OR ‘folic acid’ OR ‘folic acid’:ti OR ‘folic acid’:ab OR folvite:ti OR folvite:ab OR folacin:ti OR folacin:ab OR ‘5 me thf’ OR ‘5 me h4f’ OR ‘5 methyltetrahydrofolate’/exp OR ‘5 methyltetrahydrofolate’ OR ‘5 methyltetrahydropteroylpentaglutamate’ OR ‘5-methyltetrahydrofolate triglutamate’ | 59,748

## 7/1/14 Gray Literature Benefits Search

ClinicalTrials.gov – 8

HSRProj (Health Services Research in Progress) – 5

Cochrane Library CENTRAL – no need to search separately, as this was included during the published literature search (there were 59 trials)

WHO ICTRP – searched the neural tube defect terms in the Condition box, and the folate terms in the intervention box, and found 7 trials

NIH RePORTER – used entire quoted search string and retrieved 15 grants

Websites:

NICHD – navigated to publications from the main page, and found and saves 3 pertinent folic acid documents. Also used the search box on the main site to search for “folic acid” and retrieved 45 other links to recent publications.

HRSA Maternal & Child Health Bureau – A search of “folic acid” yielded ∼30 websites.

## 8/6/14 Gray Literature Harms Search

I. SPECIFIC HARMS

(“folic acid” OR folvite OR folacin) AND ((twin OR twin OR twinning) OR “colorectal neoplasms” OR “colorectal cancer” OR “colorectal tumor” OR “vitamin b12 deficiency” OR “vitamin b6 deficiency”) AND (“drug-related side effects” OR “adverse reaction” OR harm OR harms OR “adverse effect” OR “adverse effects” OR “adverse event” OR “adverse events” OR Complication OR Complications)

ClinicalTrials.gov = 421

HSRProj = 0

WHO ICTRP - put folate string in Title search and the other terms in Condition search = 45 records for 36 trials found.

NIH RePORTER - Advanced Search Logic - 2

HRSA Maternal and Child Health Bureau website - 6

NICHD - only small amount of text fits in search box. searched “folic acid” AND (harm^*^ OR adverse^*^) - 10 results

II. GENERAL HARMS

(“folic acid” OR folvite OR folacin) AND (“drug-related side effects” OR “adverse reaction” OR harm OR harms OR “adverse effect” OR “adverse effects” OR “adverse event” OR “adverse events” OR Complication OR Complications)

ClinicalTrials.gov = 1085

HSRProj = 0

WHO ICTRP = 1, duplicate with the specific search above, not saved.

NIH RePORTER - 30

HRSA Maternal and Child Health Bureau website - 21

## 3/27/15 Gray Literature Benefits Search

(Pregnancy OR pregnant OR “pregnant women”) AND (“folic acid” OR “vitamin b9” OR “vitamin m” OR “Pteroylglutamic Acid” OR folvite OR folacin OR folate OR “folic acid” OR multivitamin OR “prenatal vitamin” OR multivitamins OR “prenatal vitamins” OR “vitamin supplement” OR “vitamin supplements” OR 5-Me-THF OR 5-Me-H4F OR 5-methyltetrahydrofolate) AND (“neural tube defects” OR “spina bifida” OR “neural tube damage” OR “neural tube defect” OR “neural tube disorders” OR Craniorachischisis OR Craniorachischises OR Diastematomyelia OR Diastematomyelias OR “Tethered Cord Syndrome” OR “Tethered Cord Syndromes” OR “Tethered Spinal Cord Syndrome” OR “Occult Spinal Dysraphism” OR “Occult Spinal Dysraphisms” OR Iniencephaly OR Iniencephalies OR “Neurenteric Cyst” OR “Neurenteric Cysts” OR “Neuroenteric Cyst” OR “Neuroenteric Cysts” OR “Spinal Cord Myelodysplasia” OR “Spinal Cord Myelodysplasias” OR Acrania OR Acranias OR Exencephaly OR Exencephalies)

ClinicalTrials.gov – 7 studies

HSRProj – 0

WHO ICTRP – searched the neural tube defect terms in the Condition box, and the folate terms in the intervention box, and found 2 trials

NIH RePORTER – Award notice date 7-1-14 or greater – 6 results

## 3/27/15 Gray Literature Harms Search

I. SPECIFIC HARMS

(“folic acid” OR folvite OR folacin) AND ((twin OR twin OR twinning) OR “colorectal neoplasms” OR “colorectal cancer” OR “colorectal tumor” OR “vitamin b12 deficiency” OR “vitamin b6 deficiency”) AND (“drug-related side effects” OR “adverse reaction” OR harm OR harms OR “adverse effect” OR “adverse effects” OR “adverse event” OR “adverse events” OR Complication OR Complications)

ClinicalTrials.gov = 105

HSRProj = 0

WHO ICTRP - put folate string in Title search and the other terms in Condition search = 5 records for 5 trials found.

NIH RePORTER - Advanced Search Logic - 1

II. GENERAL HARMS

(“folic acid” OR folvite OR folacin) AND (“drug-related side effects” OR “adverse reaction” OR harm OR harms OR “adverse effect” OR “adverse effects” OR “adverse event” OR “adverse events” OR Complication OR Complications)

ClinicalTrials.gov = 280

HSRProj = 0

WHO ICTRP = 0

NIH RePORTER - 13

## 6/11/15 Gray Literature Addendum for Asthma

Previous gray literature searches already covered all needed adverse effects terms.

Search strategy:

(“folic acid” OR folvite OR folacin) AND asthma

- ClinicalTrials.gov = 8
- HSRProj = 0
- WHO ICTRP (http://apps.who.int/trialsearch/AdvSearch.aspx ) - put folate string in Title search and asthma in Condition search and search Recruitment status ALL = 56,
- NIH RePORTER (http://projectreporter.nih.gov/reporter.cfm) - Advanced Search Logic – 3
- HRSA Maternal and Child Health Bureau website (mchb.hrsa.gov) – 22
- Eunice Kennedy Shriver National Institute of Child Health and Human Development (NICHD)
  (https://www.nichd.nih.gov/Pages/index.aspx) - 0 results

## 7/28/15 Gray Literature Benefits Search

(Pregnancy OR pregnant OR “pregnant women”) AND (“folic acid” OR “vitamin b9” OR “vitamin m” OR “Pteroylglutamic Acid” OR folvite OR folacin OR folate OR “folic acid” OR multivitamin OR “prenatal vitamin” OR multivitamins OR “prenatal vitamins” OR “vitamin supplement” OR “vitamin supplements” OR 5-Me-THF OR 5-Me-H4F OR 5-methyltetrahydrofolate) AND (“neural tube defects” OR “spina bifida” OR “neural tube damage” OR “neural tube defect” OR “neural tube disorders” OR Craniorachischisis OR Craniorachischises OR Diastematomyelia OR Diastematomyelias OR “Tethered Cord Syndrome” OR “Tethered Cord Syndromes” OR “Tethered Spinal Cord Syndrome” OR “Occult Spinal Dysraphism” OR “Occult Spinal Dysraphisms” OR Iniencephaly OR Iniencephalies OR “Neurenteric Cyst” OR “Neurenteric Cysts” OR “Neuroenteric Cyst” OR “Neuroenteric Cysts” OR “Spinal Cord Myelodysplasia” OR “Spinal Cord Myelodysplasias” OR Acrania OR Acranias OR Exencephaly OR Exencephalies)

ClinicalTrials.gov – 4 studies

HSRProj – 0 added to HSRProj in 2015

WHO ICTRP - searched the neural tube defect terms in the Condition box, and the folate terms in the intervention box, and found 0 trials.

NIH RePORTER – Award notice date 2-1-15 or greater– 10 results.

## 7/28/15 Gray Literature HARMS Search

I. SPECIFIC HARMS

(“folic acid” OR folvite OR folacin) AND ((twin OR twin OR twinning) OR “colorectal neoplasms” OR “colorectal cancer” OR “colorectal tumor” OR “vitamin b12 deficiency” OR “vitamin b6 deficiency”) AND (“drug-related side effects” OR “adverse reaction” OR harm OR harms OR “adverse effect” OR “adverse effects” OR “adverse event” OR “adverse events” OR Complication OR Complications OR asthma)

ClinicalTrials.gov = 114

HSRProj = 0

WHO ICTRP - put all terms in title search = 0 records

NIH RePORTER - Advanced Search Logic - 0

II. GENERAL HARMS

(folic acid OR folvite OR folacin) AND (“drug-related side effects” OR “adverse reaction” OR harm OR harms OR “adverse effect” OR “adverse effects” OR “adverse event” OR “adverse events” OR Complication OR Complications)

ClinicalTrials.gov = 312

HSRProj = 0

WHO ICTRP = 0

NIH RePORTER - 19

## 11/18/15 Gray Literature Benefits Search

Benefits search strategy:

(Pregnancy OR pregnant OR “pregnant women”) AND (“folic acid” OR “vitamin b9” OR “vitamin m” OR “Pteroylglutamic Acid” OR folvite OR folacin OR folate OR “folic acid” OR multivitamin OR “prenatal vitamin” OR multivitamins OR “prenatal vitamins” OR “vitamin supplement” OR “vitamin supplements” OR 5-Me-THF OR 5-Me-H4F OR 5-methyltetrahydrofolate) AND (“neural tube defects” OR “spina bifida” OR “neural tube damage” OR “neural tube defect” OR “neural tube disorders” OR Craniorachischisis OR Craniorachischises OR Diastematomyelia OR Diastematomyelias OR “Tethered Cord Syndrome” OR “Tethered Cord Syndromes” OR “Tethered Spinal Cord Syndrome” OR “Occult Spinal Dysraphism” OR “Occult Spinal Dysraphisms” OR Iniencephaly OR Iniencephalies OR “Neurenteric Cyst” OR “Neurenteric Cysts” OR “Neuroenteric Cyst” OR “Neuroenteric Cysts” OR “Spinal Cord Myelodysplasia” OR “Spinal Cord Myelodysplasias” OR Acrania OR Acranias OR Exencephaly OR Exencephalies)

ClinicalTrials.gov – 2 studies

HSRProj – 0

WHO ICTRP – searched the neural tube defect terms in the Condition box, and the folate terms in the intervention box, and found 0 trials.

NIH RePORTER – Advanced Text search logic/ Award notice date 7-1-15 or greater – 11 results.

## 11/18/15 Gray Literature HARMS Search

I. SPECIFIC HARMS

(“folic acid” OR folvite OR folacin) AND ((twin OR twin OR twinning) OR “colorectal neoplasms” OR “colorectal cancer” OR “colorectal tumor” OR “vitamin b12 deficiency” OR “vitamin b6 deficiency”) AND (“drug-related side effects” OR “adverse reaction” OR harm OR harms OR “adverse effect” OR “adverse effects” OR “adverse event” OR “adverse events” OR Complication OR Complications OR asthma)

ClinicalTrials.gov = 90

HSRProj = 0

WHO ICTRP - put all terms in title search = 0 records

NIH RePORTER - Advanced Search Logic – 1 record

II. GENERAL HARMS

(folic acid OR folvite OR folacin) AND (“drug-related side effects” OR “adverse reaction” OR harm OR harms OR “adverse effect” OR “adverse effects” OR “adverse event” OR “adverse events” OR Complication OR Complications)

ClinicalTrials.gov = 268

HSRProj = 0

WHO ICTRP = 0

NIH RePORTER - 12

## 2/1/16 Gray Literature Benefits Search

Benefits search strategy:

(Pregnancy OR pregnant OR “pregnant women”) AND (“folic acid” OR “vitamin b9” OR “vitamin m” OR “Pteroylglutamic Acid” OR folvite OR folacin OR folate OR “folic acid” OR multivitamin OR “prenatal vitamin” OR multivitamins OR “prenatal vitamins” OR “vitamin supplement” OR “vitamin supplements” OR 5-Me-THF OR 5-Me-H4F OR 5-methyltetrahydrofolate) AND (“neural tube defects” OR “spina bifida” OR “neural tube damage” OR “neural tube defect” OR “neural tube disorders” OR Craniorachischisis OR Craniorachischises OR Diastematomyelia OR Diastematomyelias OR “Tethered Cord Syndrome” OR “Tethered Cord Syndromes” OR “Tethered Spinal Cord Syndrome” OR “Occult Spinal Dysraphism” OR “Occult Spinal Dysraphisms” OR Iniencephaly OR Iniencephalies OR “Neurenteric Cyst” OR “Neurenteric Cysts” OR “Neuroenteric Cyst” OR “Neuroenteric Cysts” OR “Spinal Cord Myelodysplasia” OR “Spinal Cord Myelodysplasias” OR Acrania OR Acranias OR Exencephaly OR Exencephalies)

ClinicalTrials.gov – 0 studies

HSRProj – 0

WHO ICTRP - 0

NIH RePORTER – 1

Advanced Text search logic/ Award notice date 10-18-15 or greater – 1 result.

## 2/1/16 Gray Literature HARMS Search

I. SPECIFIC HARMS

(“folic acid” OR folvite OR folacin) AND ((twin OR twin OR twinning) OR “colorectal neoplasms” OR “colorectal cancer” OR “colorectal tumor” OR “vitamin b12 deficiency” OR “vitamin b6 deficiency”) AND (“drug-related side effects” OR “adverse reaction” OR harm OR harms OR “adverse effect” OR “adverse effects” OR “adverse event” OR “adverse events” OR Complication OR Complications OR asthma)

ClinicalTrials.gov = 73

HSRProj = 0

WHO ICTRP - put all terms in title search = 0 records

NIH RePORTER - Advanced Search Logic – 0 records

II. GENERAL HARMS

(folic acid OR folvite OR folacin) AND (“drug-related side effects” OR “adverse reaction” OR harm OR harms OR “adverse effect” OR “adverse effects” OR “adverse event” OR “adverse events” OR Complication OR Complications)

ClinicalTrials.gov = 245

HSRProj = 0

WHO ICTRP = 0

NIH RePORTER - 3