# References

1 Dube C, Rostom A, Sy R, . The prevalence of celiac disease in average-risk and at-risk Western European populations: a systematic review. Gastroenterology. 2005;128(4 Suppl 1):S57-67. PMID: 15825128.15825128
2 Fasano A, Berti I, Gerarduzzi T, . Prevalence of celiac disease in at-risk and not-at-risk groups in the United States: a large multicenter study. Arch Intern Med. 2003;163(3):286-92. PMID: 12578508.12578508
3 Godfrey JD, Brantner TL, Brinjikji W, . Morbidity and mortality among older individuals with undiagnosed celiac disease. Gastroenterology. 2010;139(3):763-9. PMID: 20685275.20685275
4 Rubio-Tapia A, Ludvigsson JF, Brantner TL, . The prevalence of celiac disease in the United States. Am J Gastroenterol. 2012;107(10):1538-44. PMID: 22850429.22850429
5 Rubio-Tapia A, Kyle RA, Kaplan EL, . Increased prevalence and mortality in undiagnosed celiac disease. Gastroenterology. 2009;137(1):88-93. PMID: 19362553.19362553
6 Riddle MS, Murray JA, Porter CK. The incidence and risk of celiac disease in a healthy US adult population. Am J Gastroenterol. 2012;107(8):1248-55. PMID: 22584218.22584218
7 Ludvigsson JF, Rubio-Tapia A, van Dyke CT, . Increasing incidence of celiac disease in a North American population. Am J Gastroenterol. 2013;108(5):818-24. PMID: 23511460.23511460
8 Green PH, Cellier C. Celiac disease. N Engl J Med. 2007;357(17):1731-43. PMID: 17960014.17960014
9 Crowe SE. Celiac Disease. Ann Intern Med. 2011;154(9):2-16.
10 Vriezinga SL, Auricchio R, Bravi E, . Randomized feeding intervention in infants at high risk for celiac disease. N Engl J Med. 2014;371(14):1304-15. PMID: 25271603.25271603
11 Lionetti E, Castellaneta S, Francavilla R, . Introduction of gluten, HLA status, and the risk of celiac disease in children. The New England journal of medicine. 2014;371(14):1295-303. PMID: CN-01012187.25271602
12 Fasano A, Catassi C. Clinical practice. Celiac disease. N Engl J Med. 2012;367(25):2419-26. PMID: 23252527.23252527
13 Rampertab SD, Pooran N, Brar P, . Trends in the presentation of celiac disease. Am J Med. 2006;119(4):355 e9-14. PMID: 16564784.16564784
14 Green PH. The many faces of celiac disease: clinical presentation of celiac disease in the adult population. Gastroenterology. 2005;128(4 Suppl 1):S74-8. PMID: 15825130.15825130
15 Fasano A. Clinical presentation of celiac disease in the pediatric population. Gastroenterology. 2005;128(4 Suppl 1):S68-73. PMID: 15825129.15825129
16 Rostom A, Murray JA, Kagnoff MF. American Gastroenterological Association (AGA) Institute technical review on the diagnosis and management of celiac disease. Gastroenterology. 2006;131(6):1981-2002. PMID: 17087937.17087937
17 Ludvigsson JF, Leffler DA, Bai JC, . The Oslo definitions for coeliac disease and related terms. Gut. 2013;62(1):43-52. PMID: 22345659.22345659
18 Evans KE, Hadjivassiliou M, Sanders DS. Is it time to screen for adult coeliac disease? Eur J Gastroenterol Hepatol. 2011;23(10):833-8. PMID: 21799421.21799421
19 Tursi A, Elisei W, Giorgetti GM, . Complications in celiac disease under gluten-free diet. Dig Dis Sci. 2009;54(10):2175-82. PMID: 19058000.19058000
20 Tio M, Cox MR, Eslick GD. Meta-analysis: coeliac disease and the risk of all-cause mortality, any malignancy and lymphoid malignancy. Ailment Pharmacol Ther. 2012;35(5):540-51. PMID: 22239821.22239821
21 Mansueto P, Seidita A, D'Alcamo A, . Non-celiac gluten sensitivity: literature review. J Amer Coll Nutr. 2014;33(1):39-54. PMID: 24533607.24533607
22 Biesiekierski JR, Peters SL, Newnham ED, . No effects of gluten in patients with self-reported non-celiac gluten sensitivity after dietary reduction of fermentable, poorly absorbed, short-chain carbohydrates. Gastroenterology. 2013;145(2):320-8 e1-3. PMID: 23648697.23648697
23 Murray JA. Celiac disease in patients with an affected member, type 1 diabetes, iron-deficiency, or osteoporosis? Gastroenterology. 2005;128(4 Suppl 1):S52-6. PMID: 15825127.15825127
24 Mustalahti K, Catassi C, Reunanen A, . The prevalence of celiac disease in Europe: results of a centralized, international mass screening project. Ann Med. 2010;42(8):587-95. PMID: 21070098.21070098
25 Green PHR, Stavropoulos SN, Panagi SG, . Characteristics of adult celiac disease in the USA: results of a national survey. Am J Gastroenterol. 2001;96(1):126-31. PMID: 11197241.11197241
26 Rubio-Tapia A, Hill ID, Kelly CP, . ACG clinical guidelines: diagnosis and management of celiac disease. Am J Gastroenterol. 2013;108(5):656-76. PMID: 23609613.23609613
27 Richey R, Howdle P, Shaw E, . Recognition and assessment of coeliac disease in children and adults: summary of NICE guidance. BMJ. 2009;338:1684-8. PMID: 19474030.19474030
28 Burgin-Wolff A, Mauro B, Faruk H. Intestinal biopsy is not always required to diagnose celiac disease: a retrospective analysis of combined antibody tests. BMC Gastroenterol. 2013;13:19. PMID: 23343249.23343249
29 U.S. Food and Drug Administration. ‘Gluten-Free’ Now Means What It Says. Accessed at http://www.fda.gov/forconsumers/consumerupdates/ucm363069.htm#gluten-free on August 25, 2015.
30 Hall NJ, Rubin G, Charnock A. Systematic review: adherence to a gluten-free diet in adult patients with coeliac disease. Aliment Pharmacol Ther. 2009;30(4):315-30. PMID: 19485977.19485977
31 National Institute for Health and Care Excellence. Coeliac disease: recognition, assessment, and managment: NICE Guideline [NG20]; 2015. Accessed at www.nice.org.uk/guidance/ng20 on September 22, 2015.
32 Medical Advisory Secretariat. Clinical utility of serologic testing for celiac disease in asymptomatic patients: an evidence-based analysis. Ont Health Technol Assess Ser. 2011;11(3):1-63. PMID: 23074415.23074415
33 Hill ID, Dirks MH, Liptak GS, . Guideline for the diagnosis and treatment of celiac disease in children: recommendations of the North American Society for Pediatric Gastroenterology, Hepatology and Nutrition. J Pediatr Gastroenterol Ntr. 2005;40(1):1-19. PMID: 15625418.15625418
34 U.S. Preventive Services Task Force. Procedure Manual. Accessed at http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual on August 25, 2015.
35 Maglione M, Okunogbe A, Ewing B, . Diagnosis of Celiac Disease. Comparative Effectiveness Review No. 162. (Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-2012-00006-I.). Rockville, MD. 2016.
36 Basso D, Guariso G, Bozzato D, . New screening tests enrich anti-transglutaminase results and support a highly sensitive two-test based strategy for celiac disease diagnosis. Clin Chim Acta. 2011;412(17-18):1662-7. PMID: 21640087.21640087
37 Nevoral J, Kotalova R, Hradsky O, . Symptom positivity is essential for omitting biopsy in children with suspected celiac disease according to the new ESPGHAN guidelines. Eur J Pediatr. 2014;173:497-502. PMID: 24233405.24233405
38 Olen O, Gudjonsdottir AH, Browaldh L, . Antibodies against deamidated gliadin peptides and tissue transglutaminase for diagnosis of pediatric celiac disease. J Pediatr Gastroenterol Ntr. 2012;55(6):695-700. PMID: 22722680.22722680
39 Dahlbom I, Korponay-Szabo IR, Kovacs JB, . Prediction of clinical and mucosal severity of coeliac disease and dermatitis herpetiformis by quantification of IgA/IgG serum antibodies to tissue transglutaminase. J Pediatr Gastroenterol Ntr. 2010;50(2):140-6. PMID: 19841593.19841593
40 Mansour AA, Najeeb AA. Coeliac disease in Iraqi type 1 diabetic patients. Arab J Gastroenterol. 2011;12(2):103-5. PMID: 21684484.21684484
41 Mozo L, Gomez J, Escanlar E, . Diagnostic value of anti-deamidated gliadin peptide IgG antibodies for celiac disease in children and IgA-deficient patients. J Pediatr Gastroenterol Ntr. 2012;55(1):50-5. PMID: 22197936.22197936
42 Sakly W, Mankai A, Ghdess A, . Performance of anti-deamidated gliadin peptides antibodies in celiac disease diagnosis. Clin Res Hepatol Gastroenterol. 2012;36(6):598-603. PMID: 22436429.22436429
43 Van Meensel B, Hiele M, Hoffman I, . Diagnostic accuracy of ten second-generation (human) tissue transglutaminase antibody assays in celiac disease. Clin Chem. 2004;50(11):2125-35. PMID: 15388634.15388634
44 Vermeersch P, Geboes K, Marien G, . Serological diagnosis of celiac disease: comparative analysis of different strategies. Clin Chim Acta. 2012;413(21-22):1761-7. PMID: 22771970.22771970
45 DeGaetani M, Tennyson CA, Lebwohl B, . Villous atrophy and negative celiac serology: a diagnostic and therapeutic dilemma. Am J Gastroenterol. 2013;108(5):647-53. PMID: 23644957.23644957
46 Barada K, Habib RH, Malli A, . Prediction of celiac disease at endoscopy. Endoscopy. 2014;46(2):110-9. PMID: 24477366.24477366
47 Cekin AH, Cekin Y, Sezer C. Celiac disease prevalence in patients with iron deficiency anemia. Turk J Gastroenterol. 2012;23(5):490-5. PMID: 23161292.23161292
48 Emami MH, Karimi S, Kouhestani S. Is routine duodenal biopsy necessary for the detection of celiac disease in patients presenting with iron deficiency anemia? Int J Prev Med. 2012;3(4):273-7. PMID: 22624084.22624084
49 Dutta AK, Chacko A, Avinash B. Suboptimal performance of IgG anti-tissue transglutaminase in the diagnosis of celiac disease in a tropical country. Dig Dis Sci. 2010;55(3):698-702. PMID: 19333755.19333755
50 Sugai E, Hwang HJ, Vazquez H, . New serology assays can detect gluten sensitivity among enteropathy patients seronegative for anti-tissue transglutaminase. Clin Chem. 2010;56(4):661-5. PMID: 20022983.20022983
51 Dahle C, Hagman A, Ignatova S, . Antibodies against deamidated gliadin peptides identify adult coeliac disease patients negative for antibodies against endomysium and tissue transglutaminase. Ailment Pharmacol Ther. 2010;32(2):254-60. PMID: 20456302.20456302
52 Harrison E, Li K-K, Petchey M, . Selective measurement of anti-tTG antibodies in coeliac disease and IgA deficiency: an alternative pathway. Postgrad Med J. 2013;89(1047):4-7. PMID: 22872871.22872871
53 Kaukinen K, Collin P, Mykkanen AH, . Celiac disease and autoimmune endocrinologic disorders. Dig Dis Sci. 1999;44(7):1428-33. PMID: 10489930.10489930
54 Srinivas M, Basumani P, Podmore G, . Utility of testing patients, on presentation, for serologic features of celiac disease. Clin Gastroenterol Hepatol. 2014;12(6):946-52. PMID: 24262940.24262940
55 Swallow K, Wild G, Sargur R, . Quality not quantity for transglutaminase antibody 2: the performance of an endomysial and tissue transglutaminase test in screening coeliac disease remains stable over time. Clin Exp Immunol. 2013;171(1):100-6. PMID: 23199329.23199329
56 Vermeersch P, Coenen D, Geboes K, . Use of likelihood ratios improves clinical interpretation of IgA anti-tTG antibody testing for celiac disease. Clin Chim Acta. 2010;411(1-2):13-7. PMID: 19799890.19799890
57 Vermeersch P, Geboes K, Marien G, . Diagnostic performance of IgG anti-deamidated gliadin peptide antibody assays is comparable to IgA anti-tTG in celiac disease. Clin Chim Acta. 2010;411(13-14):931-5. PMID: 20171961.20171961
58 Zanini B, Magni A, Caselani F, . High tissue-transglutaminase antibody level predicts small intestinal villous atrophy in adult patients at high risk of celiac disease. Dig Liver Dis. 2012;44(4):280-5. PMID: 22119616.22119616
59 Kurppa K, Paavola A, Collin P, . Benefits of a gluten-free diet for asymptomatic patients with serologic markers of celiac disease. Gastroenterology. 2014;147(3):610-7 e1. PMID: 24837306.24837306
60 Kurppa K, Collin P, Viljamaa M, . Diagnosing mild enteropathy celiac disease: a randomized, controlled clinical study. Gastroenterology. 2009;136(3):816-23. PMID: 19111551.19111551
61 Johnston SD, Rodgers C, Watson RG. Quality of life in screen-detected and typical coeliac disease and the effect of excluding dietary gluten. Eur J Gastroenterol Hepatol. 2004;16(12):1281-6. PMID: 15618833.15618833
62 Ukkola A, Maki M, Kurppa K, . Diet improves perception of health and well-being in symptomatic, but not asymptomatic, patients with celiac disease. Clin Gastroenterol Hepatol. 2011;9(2):118-23. PMID: 21029791.21029791
63 Vilppula A, Kaukinen K, Luostarinen L, . Clinical benefit of gluten-free diet in screen-detected older celiac disease patients. BMC Gastroenterol. 2011;11:136. PMID: 22176557.22176557
64 Catassi C, Kryszak D, Bhatti B, . Natural history of celiac disease autoimmunity in a USA cohort followed since 1974. Ann Med. 2010;42(7):530-8. PMID: 20868314.20868314
65 Volta U, Caio G, Stanghellini V, . The changing clinical profile of celiac disease: a 15-year experience (1998-2012) in an Italian referral center. BMC Gastroenterol. 2014;14(1):194. PMID: 25404189.25404189
66 Uibo O, Uibo R, Kleimola V, . Serum IgA anti-gliadin antibodies in an adult population sample. High prevalence without celiac disease. Dig Dis Sci. 1993;38(11):2034-7. PMID: 8223078.8223078
67 Johnston SD, Watson RG, McMillan SA, . Coeliac disease detected by screening is not silent--simply unrecognized. QJM. 1998;91(12):853-60. PMID: 10024951.10024951
68 Maki M, Mustalahti K, Kokkonen J, . Prevalence of Celiac disease among children in Finland. N Engl J Med. 2003;348(25):2517-24. PMID: 12815137.12815137
69 van Koppen EJ, Schweizer JJ, Csizmadia CG, . Long-term health and quality-of-life consequences of mass screening for childhood celiac disease: a 10-year follow-up study. Pediatrics. 2009;123(4):e582-8. PMID: 19336349.19336349
70 Lionetti E, Castellaneta S, Pulvirenti A, . Prevalence and natural history of potential celiac disease in at-family-risk infants prospectively investigated from birth. J Pediatr. 2012;161(5):908-14.e2. PMID: 22704250.22704250
71 Metzger M-H, Heier M, Maki M, . Mortality excess in individuals with elevated IgA anti-transglutaminase antibodies: the KORA/MONICA Augsburg cohort study 1989-1998. Eur J Epidemiol. 2006;21(5):359-65. PMID: 16649072.16649072
72 Canavan C, Logan RF, Khaw KT, . No difference in mortality in undetected coeliac disease compared with the general population: a UK cohort study. Aliment Pharmacol Ther. 2011;34(8):1012-9. PMID: 21848796.21848796
73 Lohi S, Maki M, Rissanen H, . Prognosis of unrecognized coeliac disease as regards mortality: a population-based cohort study. Ann Med. 2009;41(7):508-15. PMID: 19551537.19551537
74 Ludvigsson JF, Montgomery SM, Ekbom A, . Small-intestinal histopathology and mortality risk in celiac disease. JAMA. 2009;302(11):1171-8. PMID: 19755695.19755695
75 Leffler D, Beth Israel Deaconnes Medical Center. A prospective trial of celiac disease screening. In: ClinicalTrials.gov [Internet]. Bethesda (MD): National Library of Medicine (US). Accessed at https://www.clinicaltrials.gov/ct2/show/NCT01902368?term=celiac+disease&rank=19 on August 25, 2015. ClinicalTrials.gov Identifier: NCT01902368.
76 Lahdeaho ML. Safety and efficacy of ALV003 for the treatment of celiac disease. In: ClinicalTrials.gov [Internet]. Bethesda (MD): National Library of Medicine (US). Accessed at https://www.clinicaltrials.gov/ct2/show/NCT00959114?term=celiac+disease&rank=14 on August 25, 2015. ClinicalTrials.gov Identifier: NCT00959114.
77 Rasmussen H. A double-blind placebo-controlled study to evaluate larazotide acetate for the treatment of celiac disease. In: ClinicalTrials.gov [Internet]. Bethesda (MD): National Library of Medicine (US). Accessed at https://www.clinicaltrials.gov/ct2/show/NCT01396213?term=celiac+disease&rank=11 on August 25, 2015. ClinicalTrials.gov Identifier: NCT01396213.
78 Leon F. Phase IIb study to study the efficacy of AT1001 to treat celiac disease. In: ClinicalTrials.gov [Internet]. Bethesda (MD): National Library of Medicine (US). Accessed at https://www.clinicaltrials.gov/ct2/show/NCT00492960?term=celiac+disease&rank=24 on August 25, 2015. ClinicalTrials.gov Identifier: NCT00492960
79 Makharia G. Effect of addition of short course of prednisolone to gluten free diet in naive celiac disease patients (celiac disease). In: ClinicalTrials.gov [Internet]. Bethesda (MD): National Library of Medicine (US). Accessed at https://www.clinicaltrials.gov/ct2/show/NCT01045837?term=celiac+disease&rank=29 on August 25, 2015. ClinicalTrials.gov Identifier: NCT01045837
80 Kurppa K, Hietikko M, Sulic AM, . Current status of drugs in development for celiac disease. Expert Opin Investig Drugs. 2014;23(8):1079-91. PMID: 24806736.24806736
81 Hill I, Fasano A, Schwartz R, . The prevalence of celiac disease in at-risk groups of children in the United States. J Pediatr. 2000;136(1):86-90. PMID: 10636980.10636980
82 Tai V, Crowe M, O'Keefe S. Celiac disease in older people. J Am Geriatr Soc. 2000;48(12):1690-6. PMID: 11129763.11129763
83 Mahmud FH, De Melo EN, Noordin K, . The celiac disease and diabetes-dietary intervention and evaluation trial (celiac disease-DIET) protocol: a randomised controlled study to evaluate treatment of asymptomatic coeliac disease in type 1 diabetes. BMJ Open. 2015;5(5):e008097. PMID: 25968008.25968008