# Acknowledgements

The authors acknowledge AHRQ Medical Officers Tracy Wolff, MD, MPH, and Karen Lee, MD, MPH, as well as current and former members of the U.S. Preventive Services Task Force who contributed to topic discussions.